Evidence Table 1 Behavioral intervention trials

Study Reference Study Quality | Study characteristics | Patient characteristics | CONSORT Numbers, Retention | Inclusion/Exclusion Criteria | Description of Intervention Groups | Intervention Components | Treatment Target Individual/Family vs. Group Treatment | Treatment Intensity | Mean Entry Wt (Mean ± SD) | Interv phase 2–11 mo | Interv phase 12–23 mo | Interv phase 24+ mo | Follow-up (≥ 3 mo post-intervention) | Data used for Meta analysis (BMI Change (Mean ± SD), if available) | Physiological Outcomes | Other anthropomorphic Outcomes (list) | Other Beneficial Outcomes | Adverse Effects (report findings)
Doyle et al, 2008^86^ Celio et al 2006^88^ Good | RCT 83 adolescents Setting for enrollment/assessment NR, Internet-based intervention USA (CA and MO) Media adverstisements; flyers in schools, medical facilities, and weight-loss organizations; referrals from pediatricians and school nurses Weight Loss and improved eating disorders attitudes/behaviors | Age: 12–18 (Mean 14.5) 62.5% Female 50% White 12.5% Hispanic 26.3% Black 11.3% Other SES: 43.1% parent college graduate or higher Co-morb: NR | 155 assessed for eligibility 72 excluded: 14 did not meet criteria 25 not interested 33 did not attend/complete screening 83 randomized I: 42 C: 41 [underlined: Retention, in-person outcome assessment (personal communication):] I: 28/42 (66.7%) C: 29/41 (70.3%) Retention, incl self-report (published): I: 33/42 (78.6%) C: 33/41 (80.5%) Intention-to-treat/baseline substitution analysis(published): I: 40/42 (92.2%) C: 40/41 (97.6%) | [underlined: Incl:] Age 12–18; ≥85th %ile for age and sex per CDC 2000 growth charts; Internet access at home or where regular use was possible [underlined: Excl:] Medical condition (e.g. endocrinologic diseases); use of prescription medication assoc with significant weight changes; complications of overweight that contraindicated moderate physical activity (e.g. orthopedic disorders); reading ability <6th grade; curr/past eating disorder diagnosis | I: Student Bodies 2 (SB2), Internet-delivered moderated cognitive-behavioral program; basic educational material; guided behavioral modification for wt loss; cognitive exercises for body image issues; gender-specific interfaces and content; on-line journal for recording food intake, physical activity, weight, triggers for body dissatisfaction; individual e-mail contact with moderator; discussion group; monthly newletter to parents C: Basic information on nutrition and physical activity | I: Diet, Physical Activity, Behavior Modification C: Diet, Physical Activity (Information only) | Child Individual and on-line Group | I: # sessions varied 60–120 min/wk encouraged 16-wks (est 1 hr/wk*16wks=16 hrs) (est 1 hr rather than 1.5 because partic read avg of 30% of material, and 35% of partic read <10% of material) C: 0 sessions (0 hrs) | Of those with complete data (from Table 3): BMI SDS: I: 2.19 ± 0.50 C: 2.19 ± 0.44 per CDC 2000 Growth Charts BMI: I: 34.6 ± 7.8 C: 33.9 ± 6.9 (est exceeds 97th %ile on average) | [underlined: 4-mo], BMI SDS: I: 2.11 ± 0.51 C: 2.20 ± 0.43 p=0.03 BMI: I: 34.0 ± 7.6 C: 34.1 ± 6.6 n.s. | | | [underlined: 8-mo (4-mo post-intervention)], BMI SDS: I: 2.10 ± 0.51 C: 2.15 ± 0.48 p=0.29 BMI: I: 34.4 ± 7.6 C: 34.3 ± 6.9 n.s. Personal communication, ITT (n=40): Change in BMI: I: −0.15 ± 1.75 C: 0.39 ± 2.08 | [underlined: Change in BMI:] I: −0.15 ± 1.75 C: 0.39 ± 2.08 | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | Self-image (Shape Concern) | C group showed greater decline in Shape Concern than I group; no other differences in eating disorder pathology
Epstein et al 2008^87^ Good | RCT 70 children University Children’s hospital USA Media ads, flyers, direct mailings Determine effects of reducing television viewing and computer use on zBMI | Age: 4–7 (Mean 5.9 (c)) 47% Female (c) 24% minority (c) Mean SES 43.2 (c) Comorb: NR | 185 assessed for eligibility 115 did not partic (77 did not meet incl crit, 30 withdrew, 8 lost to fup) 70 randomized: I: 36 C: 34 [underlined: Retention:] I: 35/36 (97%) C: 32/34 (94%) | [underlined: Incl:] Age 4–7; BMI ≥75^th^ percentile for age and sex; ≥14 hrs/week TV or computer viewing; unlimited access to TV; family agreement to have TV monitoring devices attached to every TV and computer in house [underlined: Excl:] Medical conditions that prevented regular physical activity | I: Device attached to all TVs and computers to monitor and control viewing time, financial incentives to children for being under their screen time budget, star charts, parents encouraged to praise children for alternate activities; newletters and encouragement for parents C: Newsletter of parenting tips, activities, and recipes for kids; kids given $2.00/wk; no restrictions on access to TV/computers | I: Physical Activity, Family (Target), screen device C: None | Each family member Family | Not applicable | BMI: (Mean ± SD) I: 19.3 ± 2.5 C: 19.1 ± 3.5 BMI SDS: (Mean ± SD) I: 1.69 ± 0.58 C: 1.51 ± 0.57 (est ≥ 95th %ile on average) | [underlined: 6-mo(mid-treatment):C]hange in BMI SDS from baseline (est from graph for I group): I: -0.15 (SD NR) C:+0.05 (0.29) p=0.02 | [underlined: 12-mo (mid-treatment): change in BMI SDS from baseline (est from graph):] I: -0.16 (SD NR) C:-0.02 (SD NR) p=0.03 | [underlined: 24-mo (post-intervention) change in BMI SDS from baseline (Mean ± SE):] I: -0.24 ± 0.32* C:-0.13 ± 0.37* group*time effect p<.05 SD calculations: I: 0.32*sqrt(35)=1.89 C: 0.37*sqrt(32)=2.09 | | [underlined: BMI SDS] I: -0.24 ± 1.89 C:-0.13 ± 2.09 | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | Energy intake, physical activity, sedentary behavior | NR
Flodmark et al1993^103^ Fair | CCT 43children (plus 50 matched controls) Outpatient referral clinical setting Sweden Screening program in schools Prevention of progression to severe obesity | Age: 10–11 (Mean NR) 52% Female (c) Race/Eth: NR SES: NR Comorb: clinically euthyroid, blood pressures less than140/90, none with signs of endocrine d/o | Treatment groups: 1,906 screened 1,774 parents consent to study participate 49 BMI >23.0 44 randomized: I1 (conventional treatment): 19 I2 (I1 + family therapy): 24 C (matched controls): 50 (excluded 1 patient who was a pilot case) Unclear if controls pulled from same screening population as randomized [underlined: Retention:] I1: 19/19 (100%) I2: 20/24 (83%) C: 48/50 (96%) | Incl: BMI > 23.0 kg/m^2^ | I1: Conventional treatment: dietary counseling with dietitian, monthly visits to experienced pediatrician w interest in wt problems, low fat, 1500–1700 kcal diet prescribed, exercise encouraged I2: Same as above + family therapy C: Matched controls, no treatment | I1: Diet, Physical Activity, Family(Target) I2: Diet, Physical Activity, Family(Target), Mental Health Treatment C: None | I1: Child, parent Individual I2: Family Individual | I1: 0–1 session w dietitian, 5 sessions w/pediatrician minutes NR 14–18 mos (est 6 * 1 hr *2family member=12 hrs) I2: 0–1 session w dietitian, 5 sessions w/pediatrician, 6 family therapy sessions minutes NR14–18 mos (est 12 * 1 hr *2 family member =24 hrs) C: None(0 hrs) | BMI: (Mean ± SE) I1: 25.5 ± 0.53* I2: 24.7 ± 0.36* C: 25.1 ± 0.35* *calculated SD (SE*sqrt(n)): I1: 0.53*sqrt(19)=2.31 I2: 0.36*sqrt(24)=1.76 C: 0.35*sqrt(50)=2.47 (est >95th %ile on average) | NA | [underlined: Post-treatment (14–18 mos):] BMI (Mean ± SE) I1=26.1 ± 0.72 I2=25.0 ± 0.53 C: (data not collected) | | [underlined: ~48-mo (30–34 mos post- intervention)] BMI: (Mean ± SE) I1=27.1 ± 0.88* I2: 25.8 ± 0.73* C: 27.9 ± 0.61* p=.15* calculated SD (SE*sqrt(n)): I1: 0.88*sqrt(19)=3.84 I2: 0.73*sqrt(20)=3.26 C: 0.61*sqrt(48)=4.23 | [underlined: BMI change:] Post-tx (14–18 mos): NA Follow-up (30–34 mo post-tx): I1: (not used in meta- analysis) I2: +1.1 ± 1.85 C: +2.8 ± 2.32 (SDs calc) | Lipids: No Glucose tol: No BP: No Phys fitness: Yes | Triceps, Subscapular, Suprailiac skinfolds | None | NR
Gillis et al 2007^78^ Fair | RCT 27 children Primary care clinics in urban Jewish ultra-orthodox Neighborhoods Israel 2 primary care clinics Weight loss, improvement in adverse metabolic consequences of obesity and obesity-related attitudes | Age: 7–16 (10.6 (calc)) %Male NR Race/Eth: 100% Jewish SES: NR Co-morb: NR | 27 recruited 27 randomized I: 14 C: 13 [underlined: Retention:] 18/27 (66.7%) overall I: 11/14 (78.6%) C: 7/13 (53.8%) | [underlined: Incl:] Age 7–16; BMI>90th %ile; refered to author (endocrinologist) for evaluation of obesity | I: Basic discussion on health diet and exercise (at baseline and 3-months); asked to record food/exercise one day/week; weekly phone call to review food/exercise diary and encourage adherence to prescribed plan C: Basic discussion on health diet and exercise (at baseline and 3-months) | I: Diet, Physical Activity, Behavior Modification, Family (Not target) C: Diet, Physical Activity (brief counseling) | Child Individual | I: 2 1/2 hr clinic visits + 24 weekly calls (est) # Min/session NR 26 weeks (est) (est 2*.5*hr*2(parent+child) + 24*.25 hr = 8 hrs) C: 2 clinic visits # minutes NR (est 2 hrs) | BMI SDS: I: 1.98 ± 0.21 C: 2.16 ± 0.34 (est >95th %ile on average) | [underlined: 6-mo] BMI SDS: I: 1.93 ± 0.37 C: 2.23 ± 0.29 p=0.40 BMI SDS change: I: -0.045 ± 0.19 C: 0.075 ± 0.08 p=0.10 | NA | NA | NA | [underlined: BMI SDS change:] I: -0.045 ± 0.19 C: 0.075 ± 0.08 | Lipids: Yes Glucose tol: Yes BP: No Phys fitness: Yes | None | Diet (self-report of change), Physical Activity (self-report of change) | NR
Golley et al 2007^80^ Good | RCT 111 children teaching hospitals Australia media publicity and school newsletters Weight management in prepubertal children | Age: 6–9 (Mean 8.2) 64% Female (calc) 98% White SES: Index of relative socioeconomic advantage slightly above South Australian average Co-morb: NR | 262 Initial phone screening completed 126 eligibility confirmed at medical screening 115 consented 111 completed baseline assessment 111 randomized: I1 (Parenting group): 37 I2 (Parenting + lifestyle): 38 C:(Wait list): 36 Retention: I1: 29/37 (78.4%) I2: 31/38 (81.6%) C: 31/36 (86.1%) | [underlined: Incl:] Age 6–9; Overweight, per International Obesity Task Force definition); Tanner Stage 1; caregiver willing to attend sessions and able to read and understand English [underlined: Excl:] BMI z-score >3.5; syndromal cause of obesity; medication use that may influence weight; diagnosis of physical or developmental disability; sibling enrolled in study | I1 Parenting skills training, aims to promote parental competence to manage child’s behavior with emphasis on dietary and activity behaviors in program examples, pamphlet covering eating and activity behaviors, I2: Parenting + Intensive lifestyle education covering wide variety of topics related to healthy eating, activity, and emotional sequalae of overweight such as self- esteem and teasing. C: Wait-list Control, 3–4 brief phone calls for encourage retention in study | I1: Diet, Physical Activity, Family(Target), Mental Health Treatment I2: Diet, Physical Activity+, Behavior Modification, Family(Target), Mental Health Treatment C: Diet, Physical Activity (pamphlets only) | Parent Group and Individual | I1: 4 group, 7 individual group=120 min indiv=15–20 min 21 wks (calc) (4*2 hrs + 7*.33 hrs =10.33 hrs) I2: 11 group 120 min # wks NR (22 hrs) C: 3–4 5-minute phone calls (0.33 hrs) | BMI: 24.3 ± 2.6 (overall) BMI z-score: I1: 2.76 ± 0.58 I2: 2.74 ± 0.58 C: 2.75 ± 0.39 (est >97th %ile on average) | [underlined: 6-mo (1-mo post- intervention):] BMI z-score: I1: 2.63 ± 0.53 I2: 2.52 ± 0.53 C: (NR) | | NA | [underlined: 12-mo (7-mos post- intervention):] BMI SDS: I1: 2.56 ± 0.79 I2: 2.43 ± 0.68 C: 2.60 ± 0.57 group^*^time effect p=0.76 Change in BMI SDS: I1: −0.15 ± 0.47 I2: −0.24 ± 0.43 C: −0.13 ± 0.40 group^*^time effect p=0.76 % who increased BMI SDS: I1: 24% I2: 19% C: 45% p<0.03 | [underlined: Change in BMI SDS:] I1 (not used in MA) I2: −0.24 ± 0.43 C: −0.13 ± 0.40 | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | Waist circumference | None | Height change did not differ between treatment and control conditions
McCallum et al, 2007^81^ McCallum et al, 2005^90^ Good | RCT 163 children Oupatient medical clinic Australia GPs recruited from sociodemographically diverse practices Weight loss in moderately overweight children | Age 5–9; (Mean 7.4) 52% Female Race/Eth: NR SES: practices range from <10th to >90th %ile; median practice close to 50th %ile Comorb: NR | 2112 screened 505 overweight or mildly obese 342 excluded or refused, 163 randomized: I: 82 C: 81 [underlined: Retention]: 9-mo fup I: 73/82 (89%) C: 80/81 (99%) 12-mo fup I: 70/82 (85%) C: 76/81 (94%) | [underlined: Incl]: Age 5–9; attending participating medical practice; classified as overweight or mildly obese per International Obesity Task Force definition; not receiving ongoing weight management in secondary or tertiary care program [underlined: Excl:] SDS ≥ 3.0, chromosomal, endocrine, or medical condition/disability/medication which could have an impact on wt or growth | I: General practitioner given folder prior to appointment containing child’s individualized intervention materials, BMI, and 2-page summary of parent responses from baseline questionnaire. Brief solution-focused intervention to set and record appropriate, healthy lifestyle goals with the family; personalized 20-page “Family Folder” containing topic sheets targeting different areas of behavior change C: Usual care | I: Diet, Physical Activity, Behavior participating Modification, Family (Target) C: Usual care | Child, parent Individual | I: 4 sessions minutes NR 12-weeks (assume .5 hrs appointments, 4*.5 hrs*2 fam members=4 hrs total) C: NR (0 hrs) | BMI I: 20.5 ± 2.2 C: 20.0 ± 1.8 BMI SDS I: 2.0 ± 0.5 C: 1.9 ± 0.5 (per UK 1990 Growth Reference) (est >95th %ile on average) | NA | NA | NA | [underlined: 9-mo (6-mo post-intervention)] BMI: I: 21.0 ± 2.6 C: 20.8 ± 2.2 adjusted p=0.25 BMI SDS: I: 1.96 ± 0.64 C: 1.93 ± 0.57 adjusted p=0.12 (per CDC 2000 Growth Charts) [underlined: 15-mo (12-mo post-intervention)] BMI: I: 21.7 ± 3.1 C: 21.2 ± 2.4 adjusted p=1.0 BMI SDS: I: 2.0 ± 0.68 C: 1.92 ± 0.59 adjusted p=0.62 (per CDC 2000 Growth Charts) | [underlined: BMI change] Post-treatment: NR Follow-up (9 mo post-treatment) I: +0.5 ± 1.1 C: +0.8 ± 1.0 Follow-up (12 mo post-treatment) I: +1.2 ± 1.5 C: +1.2 ± 1.1 (calc) | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | Diet (4-day food diary) Physical Activity (4-day activity diary) | “Little evidence of either harm or benefit of the intervention with respect to parent- and child-reported child health status and child-reported body satisfaction and appearance/self-worth.”
Mellin et al 1987^104^ Fair | RCT 66 adolescents Rural health dept; rural nutrition private practice, suburban medical clinic; urban outpatient clinic USA Newspaper announcements, notices to physicians and school personnel Weight loss | Age 12–18 (Mean 15.6) 79% Female 87.9% White 7.6% Hispanic 4.5% Asian or Black (calc) SES: NR Co-morb: NR | 66 responded to recruitment 66 randomized I: 37 C: 29 Retention: I: 34/37 (92%) C: 29/29 (100%) | NR | I: SHAPEDOWN program; cognitive, behavioral, affective treatment encouraging successive, sustainable, small modification in diet, exercies, relationship, lifestyle, communicatins, and attitudes. C: no treatment controls | I: Diet, Physical Activity+, Behavior Modification, Family (Not target) C: No treatment | Child, Parent Group | I: 14 sessions with adolescents 2 parent sessions 90 min/session 14 weeks (16*1.5 hrs =24 hrs) C: None (0 hrs) | % Overweight I: 36.5% (SD NR) C: 29.5% (SD NR) per 1973 US National Center for Health Statistics Wt, kg I: 79.2 (SD NR) C: 77.0 (SD NR) (est >95th %ile on average) | [underlined: 3-mo] change in % overweight I: −5.9 ± 6.8 C: −0.3 ± 6.6 dependent t-test I: p<0.001 C: n.s. | NA | NA | [underlined: 15-mo (12-mo post- intervention)] change in % overweight I: -9.9 ± 15.0 C: -0.1 ± 13.2 dependent t-test I: p<0.01 C: n.s. | 15-mo (12-mo post- intervention) change in % overweight I: -9.9 ± 15.0 C: -0.1 ± 13.2 | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | Weight-related behaviors; depressive symptoms; self- esteem | Depression symptoms improved in treatment group, did not change in control group; self-esteem improved in both groups
Nemet et al 2005^85^ Fair | RCT 54 children Child Health and Sports Center Isreal Self-referral Weight Loss | Age: range 6–16 (Mean 11.1) 43.5% Female Race/Eth: NR (Isreali) SES: NR Co-morb: NR | 54 self-referred to center, randomized: I: 30 C: 24 Retention: 3-mo: I: 24/30 (80.0%) C: 22/24 (91.7%) 12-mo: I:20/30 (66.7%) C: 20/24 (83.3%) | NR, but reported that none of the children had an organic cause for obesity, none received any medication that might interfere with growth or weight control. Unclear if these were exclusion criteria. | I: Twice weekly exercise sessions plus expectation of at least one exercise session at home, 6 semi-monthly parent and/or child meetings with dietician primarily for nutritional counseling, 4 general interest lectures for parents and children on topics related to childhood obesity. C: At least one nutritional counseling session, encouraged to exercise 3 times/week on their own. | I: Diet, Physical Activity+, Behavior Modification, Family (Target) C: Usual Care | I: Child, Parent Individual C: Child, Parent Individual | I: 28 1-hr exercise sessions 6 30–45 min nutrition counseling 4 lecture, minutes NR 14 wks (calc) (28*1 + 1 hr +.75hr + 4*.75*2)=28+1.75+6=35.75 hrs C: 1 or more nutrition counseling sessions, minute NR (Est 1 hr) | BMI: I: 27.7 ± 3.6 C: 28.0 ± 5.2 BMI percentile: I: 98.2 ± 0.3 C: 97.2 ± 0.7 Weight, kg: I: 59.1 ± 15.7 C: 63.4 ± 23.6 (all among those with followup, n=40) | 3-mo BMI: I: 26.8 ± 3.9 C: 27.6 ± 5.6 p<0.05 Weight, kg: I: 61.0 ± 18.3 C: 64.5 ± 24.1 p<0.05 | | | 12-mo (9-mos post-intervention): BMI: I: 26.1 ± 4.7 C: 28.6 ± 5.8 p<0.05 BMI percentile: I: 92.3 ± 3.0 C: 96.1 ± 1.4 p<0.05 Weight, kg: I: 59.7 ± 17.7 C: 68.6 ± 24.8 p<0.05 | [underlined: BMI change:] Follow-up (12-mo post-tx): I: −1.5 ± 2.1 C: +0.6 ± 2.5 (calc) | Lipids: Yes Glucose tol: No BP: No Phys fitness: Yes | triceps, Subscapular skinfolds | Diet, Physical activity, Sedentary behavior | “No adverse events were noted during the intervention”
Reinehr et al 2006^79^ Reinehr et al 2007^89^ Fair | CCT 240 children Overweight specialty treatment unit in medical facility Germany Recruitment NR Weight loss and cardiovascular disease risk profile improvement | Age: 6–14 (Mean 10.4) 46.7% Female Race/Eth: NR SES: NR Co-morb: 0% endocrine disorders | 240 analyzed: I: 203 C: 37 Retention: 12 & 24-mo: I: 174/203 (86%) C: 37/37 (100%) 4-yr*: I: 142/170 (84%) *from Reinehr 2007 | [underlined: Incl:] Age 6–14; BMI >97th %ile per 2001 German norms; participate in local exercise group for ≥ 8 wks to prove motivation [underlined: Excl:] Endocrine disorders, familial hyperlipidemia, or syndromal obesity | I: Multidisciplinary treatment team, program includes physical exercise, nutrition education, behavioral therapy, individual and/or family therapy C: No treatment; Comprised of children who met all criteria but did not participate due to travel distance to the treatment facility | I: Diet, Physical Activity+, Behavior Modification, Family (Target), Mental Health Treatment C: No Treatment | I: Child, parent, family Individual, group C: None | I: 6 1.5-hr parent group sessions 6 1.5-hr child group sessions 3 1-hr parent sessions 52 exercise session (minutes NR) variable number (est 6) 30-minute individual and/or family therapy sessions (12*1.5hr + 3 + 52*1 hr + 6*.5hr = 76.0 hrs) 1 yr C: None (0 hrs) | BMI: I: 27.0 (26.4, 27.6) C: 26.1 (25.2, 27.8) *SD calc: I: (1.2*sqrt(203))/3.92= 4.36 C: (2.2*sqrt(37)))/3.92=4.0 3 BMI SDS: I: 2.4 (2.3, 2.4) C: 2.3 (2.2, 2.4) (est >97th %ile on average) | NA | [underlined: 12-mo] BMI: I: 27.1 (26.4, 27.6)* C: 28.1 (27.0, 29.2)* p=0.013 (treatment × time effect) *SD calc I:(1.2*sqrt(174))/3.92= 4.04 C:(2.2*sqrt(37)))/3.92=3.41 BMI SDS: I: 2.1 (2.1, 2.2) C: 2.3 (2.1, 2.4) p=0.007 (treatment × time effect) | | [underlined: 24-mo (12-mos post-intervention)] BMI: I: 28.2 (27.4, 29.0)* C: 29.0 (28.0, 30.8)* p=0.013 (treatment × time effect) *SD calc: I: (1.6*sqrt(174))/3.92= 5.38 C: (2.8*sqrt(37))/3.92=4.34 BMI SDS: I: 2.1 (2.1, 2.2)* C: 2.3 (2.1, 2.4)* p=0.007 (treatment × time effect) *SD calc: I: (0.1*sqrt(174))/3.92=0.34 C: (0.3*sqrt(37))/3.92=0.46 48-mo (36-mo post-intervention) I group only: BMI SDS reduced in first 3 months (p<.001), then did not change in the rest of the observation period. | [underlined: BMI change] Post-treatment (12- mo) I: +0.1 ± 1.9 C: +2.0 ± 1.8 24-mo (12-mo post-treatment): I: +1.2 ± 2.4 C: +2.9 ± 1.9 (calc) | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | None | None | NR
Rooney et al 2005^82^ Fair | RCT 98 families (353 people, adults and children combined) NR USA NR Increased physical activity | Age: 5–12 (Mean 9.7) 51% Female Race/Eth: NR SES: NR Co-morb: NR | 98 families (n=353) randomized 87 families (n=316) analyzed: I1: 28 families/n=104 I2: 30 families/n=112 C: 29 families/n=100 [underlined: Retention:] 87/98 families (88.8%) 316/353 people (89.5%) Individual children (personal communication): I1: 21 I2: 24 C: 27 (denominators unknown, and unclear of this includes only overweight children or siblings also) | [underlined: Incl:] At least one child aged 5–12 with BMI over 84th %ile; at least one adult willing to participate. (Siblings also invited to participate) | I1: Pedometer group given a pedometer, instructed in its use and told to walk 10,000 steps daily for 12 weeks; biweekly newsletters containing informative articles and fun activity tips. I2: Pedometer + education group; above, plus education sessions covering nutrition, physical activity, other parenting issues. C: Not described | I1: Physical Activity, Family (Target), Pedometer I2: Diet, Physical Activity, Family (Target), Pedometer C: No treatment | Family NR | I1: #session, min NR 12 wks (est 1 hr pedometer instruction*3 fam members=3 hrs) I2: 1 session pedometer instruction (est 1 hr) 6 1-hr wt loss education sessions (est (1hr+7 hrs)*3 family members=21 hrs) 12 wks C: NR (est 0 hrs) | [underlined: BMI:] I1: 21.1 ± 6.24 I2: 22.25 ± 6.23 C: 21.9 ± 5.95 (personal communication) BMI %ile: I1&I2: 80.8 C: 85.6 (per CDC growth charts, year not specified) | [underlined: 3-mo] BMI %ile: I1&I2:82. 3 C: 85.0 p=0.42 | NA | NA | [underlined: 9-mo (6 mos post-intervention)] adjusted BMI ± SE: I1: 21.61 ± 1.19 I2: 23.11 ± 0.82 C: 22.45 ± 1.04 (personal communication) adjusted BMI change ± SE: I1: −0.38 ± 0.22* I2: −0.87 ± 0.26* C: −0.43 ± 0.21* (personal communication) *SDs calc from SE: I1: 0.22*sqrt(21)=1.01 I2: 0.26*sqrt(24) =1.27 C: 0.21*sqrt(27)=1.09 unadjusted BMI %ile: I1&I2: 80.9 (SD NR) C: 84.3 (SD NR) p=0.33 unadjusted change in BMI %ile: I1&I2: +0.31 (SD NR) C: −1.32 (SD NR) p=0.28 | [underlined: BMI change] I1: (not used in MA) I2: −0.87 ± 1.27 C: −0.43 ± 1.09 | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | sedentary activity | NR
Saelens et al 2002^83^ Good | RCT 44 adolescents Primary care clinical setting USA Flyers in pediatric clinic waiting room, pediatrician encouragement to participate Weight loss | Age: 12–16 Mean 14.2 ± 1.2 40.9% Female 70.5% White 15.9% Hispanic 4.5% Black 2.3% Asian 6.8% Multi-ethnic SES: Median household income $60K–69K Co-morb: NR | 59 scheduled baseline assmt 47 complete baseline assmt 44 met weight criteria and were randomized I: 23 C: 21 Retention: I: 18/23 (78%) complete followup C: 19/21 (90%) fup Conducted Intention-to-treat analysis on full sample (n=44), replacing missing values with group change values | [underlined: Incl]: Age 12–16; 20–100% above median (50%ile) for BMI for sex and age per CDC 2000 growth charts; interested in weight control, but not currently engaged in another wt control program; otherwise healthy as determined by pediatrician | I: Healthy habits intervention: computerized assessment; meeting with pediatritian to discuss results of assessment, develop action plan; 10–20 minutes counseling calls; mailed participant manual in three different mailings (part of manual mailed each time); encouraged self-monitoring of food intake and physical activity C: Typical care intervention: 5–10 minute meeting with pediatrician assessing motivation and providing (non-tailored) information on healthy eating and physical activity | I: Diet, Physical Activity, Behavior Modification C: Diet, Physical Activity (Information only) | Child Individual | I: 1 pediatrician session, 11 phone calls Pediatrician visit 5–10 minutes, phone calls 10–20 minutes 14–6 wks total (10 min + 11*20 min = 230 min = 3.8 hrs) C: 1 pediatrician session 5–10 minutes 1 day s(0.2 hrs) | BMI I: 31.0 ± 3.5 C: 30.7 ± 3.1 % OW I: 62.0 ± 20.5 C: 62.3 ± 17.4 (per 2000 CDC growth charts) (est >97th %ile on average) | [underlined: 4-mo] BMI z-score: I: 2.15 (SD NR) C: 2.02 (SD NR) (est from graph) p=0.04 (Intention-to-treat analysis) and p=0.03 (completers) for overall time*treatment effect in repeated measures ANOVA model BMI: I: 30.9 ± 3.8 C: 31.8 ± 3.4 p=NR % Overweight: I: 59.8 ± 21.8 C: 66.2 ± 18.6 p=NR | NA | NA | [underlined: 7-mo (3-mo post intervention)] BMI z-score: I: 2.15 (SD NR) C: 2.01 (SD NR) (est from graph) p=0.04 (ITT analysis) and p=0.03 (completers) for overall time*treatment effect in repeated measures ANOVA model BMI: I: 31.1 ± 4.5 C: 32.1 ± 3.8 p=NR % Overweight: I: 59.6 ± 24.6 C: 66.4 ± 20.1 p=NR | [underlined: BMI change] 7-mo (3 mo post-tx): I: +0.1 ± 2.0 C: +1.4 ± 1.7 (SDs calc) | Lipids: No Glucose tol: No BP: No Phys fitness: No | None | Diet, Physical activity, Sedentary behavior, problematic eating/eating disorder psychopathology | Problematic eating/eating disorder psychopathology did not differ between treatment and control groups
Savoye et al 2007^77^ Good | RCT 174 children and adolescents Pediatric obesity clinic USA NR Changes in BMI, body composition, insulin sensitivity, blood pressure, and lipid profiles | Age: 8–16 (Mean 12.1 (calc)) 60.9% Female (calc) 36.8% White 24.7% Hispanic 38.5% Black (all calc) SES: NR Co-morb: 0% Diabetes | 284 assessed 271 met inclusion criteria 209 consented and randomized I: 105 C: 69 (n=35 in 3rd tx arm which was dropped) [underlined: Retention:] I: 86/105 (81.9%) 6-mo intervtn/assessmt C: 49/69 (71.0%) 6-mo intervtn/assessment I: 75/105 (71.4%) 12-mo intervtn/assessment C: 44/69 (63.8%) 12-mo intervention/assessment All observations (n=174) used in analysis (conducted MI to fill in missing data) | [underlined: Incl]: BMI >95th %ile; age 8–16; English-speaking; caregiver willing to participate. [underlined: Excl]: Diabetes; severe psychiatric disorder or cognitive deficits; serious medical condition that would preclude them from participation; taking medications that could cause significant weight gain; using medications for weight loss; involved in weight management program | I: Bright Bodies Weight Management, twice weekly exercise program; weekly nutrition education and behavior modification class. C: pediatric obesity clinic visit every 6 months for diet and exercise counseling and brief pschosocial counseling with social worker. | I: Diet, Physical Activity+, Behavior Modification, Family (Target) C: Diet, Physical Activity, Mental Health Treatment (brief counseling) | Child, Parent Group | I: 65 sessions (calc) 90 min/session 52 weeks (65*1.5=97.5 hrs) C: 2 sessions (calc) min/sessin NR 52 weeks (est) (2*1 hr=2 hrs) | BMI I: 35.8 ± 7.6 C: 36.2 ± 6.2 Wt, kg I: 87.0 ± 25.1 C: 91.2 ± 23.3 (est >97th %ile on average) | [underlined: 6-mo] Change in BMI I: −2.1 (−2.6, −1.5)* C: 1.1 (0.4, 1.8)* p<0.001 *SD calc: I: 1.1*sqrt(105)/3.92=2.88 C: 1.4*sqrt(69)/3.92=2.97 Change in weight, kg I: −2.6 (−4.2, −0.9) C: 5.0 (2.9, 7.2) p<0.001 | [underlined: 12-mo] Change in BMI I: −1.7 (−2.3, −1.1)* C: 1.6 (0.8, 2.3)* p<0.001 *SD calculated: I: 1.2*sqrt(105)/(2*1.96)]=3.14 C: 1.5*sqrt(69)/(2*1.96)=3.17 Change in weight, kg I: 0.3 (−1.4, 2.0) C: 7.7 (5.3, 10.0) p<0.001 | NA | NA | BMI change Post-tx (12-mo): I: − 1.7 ± 3.14 C: +1.6 ± 3.17 Follow-up: NR | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | % Body fat, Body fat mass | | Found no difference between treatment and control group in changes in height at 6 months or 12 months
Senediak et al 1985^84^ Fair | 35 children Setting NR USA Media ads + publicity to medical professionals Weight loss | Age: 6–12 (calc) (Mean 10.3) 34% Female (est) Race/Eth: NR SES: NR Co-morb: NR | 45 randomized: I1 (rapid schedule): 12 I2 (standard schedule):12 C1 (attention control): 11 C2 (wait-list): 10 (not reported here) Retention: I1: 8/12 (66.7%) I2: 10/12 (83.3%) C1: 7/11 (63.6%) | [underlined: Incl]: At least 20% overweight for height, age, therapy and sex [underlined: Excl:] Height not below 20th %ile for age; no history of psychiatric contact; no history of endocrine or metabolic disorders; not in special education | I1: Rapid schedule Behavioral I2: Gradually decreasing schedule Behavioral therapy C1: Relaxaion, mood management control C2: Wait list (not reported here) | I1&I2: Diet, Physical Activity+, Behavior Modification, Family (Target) C: Mental Health Treatment, Family (Target) | Child, parent Group | All: 8 90-minute sessions (12 hrs) I1&C1: 4 wks I2: 15 wks | Weight, kg (of those with 26-wk outcomes data) I1: 50.6 ± 6.8 I2: 51.4 ± 10.5 C: 44.5 ± 5.3 %Overweight (of those with 26-wk outcomes data) I1: 32.9 ± 14.0 I2: 35.9 ± 12.2 C: 36.7 ± 5.5 (est >95th %ile on average) | NA (report post- treatment, but since post-tx point different (1 mo vs 3.5-mo), will only report post-intervention follow-up | | | [underlined: 6-mo (3–5 mo post-intervention)] Weight, kg I1: 49.5 ± 7.4 I2: 48.6 ± 11.1 C1: 44.8 ± 4.9 p<0.05 (I1 & I2 vs. C1) %Overweight I1: 19.9 ± 14.2 I2: 16.6 ± 11.5 C1: 30.8 ± 10.4 p<0.05 (I1 & I2 vs. C1) | %OW change I1: (not used in MA) I2: -19.22 ± 5.3 C: -5.86 ± 6.0 (calc) | Lipids: No Glucose tol: No BP: No Phys fitness: No | Subscapular skinfold | NR | NR

Abbreviations: I: Intervention; NR: Not reported; DM: Diabetes Mellitus; C: Control Group; T2DM: Type 2 Diabetes Mellitus; SES: Socioeconomic status; A.E: Adverse effects; Mos: months; SD: standard deviation; (c): calculated

Evidence Table 2 Summary table of pharmacological study characteristics

Source | Intervention | No. of months of drug treatment | No. of behavioral intervention sessions | Characteristics | No of study sites | Country | % Attrition | Quality^a^ | Placebo Run-in Period | Funding Source
Sibutramine
Berkowitz et al, 2003^91^ | Sibutramine (5 mg/d for 1 wk, 10 mg/d for 4 wks, then 15 mg) + BI or placebo + BI | 6 | 19 | N randomized: 82 Age: 13–17 Female: 67% | 1 | USA | 10% | Good | Yes | NIH, hospital, pharm
Berkowitz et al, 2006^92^ | Sibutramine (10 mg/day for 6 mos, then 10–15 mg/d) + BI or placebo + BI | 12 | 10 | N randomized: 498 Age: 12–16 Female: 66% | 33 | USA | 28%^b^ | Good | No | Pharm
Garcia-Morales et al, 2006^94^ | Sibutramine (10 mg/d) + BI or placebo + BI | 6 | 8 | N randomized: 51 Age: 14–18 Female: 56% | 1 | Mexico | 22% | Fair | Yes | Pharm
Godoy-Matos et al, 2005^95^ | Sibutramine (10 mg/d) or placebo | 6 | 1 | N randomized: 60 Age: 14–17 Female: 82% | 1 | Brazil | 17%^b^ | Fair | Yes | Pharm
Van Mil et al, 2007^97^ | Sibutramine (5 mg/d for 2 wks, then 10 mg/d) + BI or placebo + BI | 3^c^ | 16 | N randomized: 24 Age: 12–17 Female: 54% | 1 | Netherlands | 17%^b^ | Fair | No | NR
Orlistat
Chanoine et al, 2005^93^ | Orlistat (120 mg, TID) + BI or placebo + BI | 12 | 18 | N: 539 Age: 12–16 Female: 67% | 32 | USA & Canada | 35% | Good | Yes | Pharm
Maahs et al, 2006^96^ | Orlistat (120 mg, TID) + BI or placebo + BI | 6 | 7 | N: 40 Age: 14–18 Female: 67% | 1 | USA | 15% | Fair | No | University supported

Abbreviations: BI - behavioral intervention (with or without a behavioral management program); TID - three times daily; NR - not reported; Pharm-pharmaceutical; NIH-National Institute of Health.

a Quality criteria are described in Appendix B Table 1.

b Attrition rate was different between the intervention and control groups.

c Patients were treated with BT + sibutramine or placebo for 3 mos. and then BT alone for 3 mos.

Evidence Table 3 Pharmacological intervention trials

Study Reference Study Quality | Study Characteristics | Patient Characteristics | CONSORT Numbers Retention | Inclusion/Exclusion | Description of Intervention Groups | Dose/Duration | Mean Entry Wt | Interv phase 6–11 mo | Interv phase12–23 mo | Interv phase24+ mo | Post-Intervention | Physiological Outcomes Reported | Other anthropomorphic Outcomes | Adverse Effects
Sibutramine
Berkowitz et al 2003^91^ Budd et al 2007^101^ Good | RCT 82 adolescents University-based specialty research clinic USA Source NR Weight loss March 1999- August 2002 Funding:NIH; Hospital; Pharmaceutical | Age: 13–17 (Mean 14.1) 67.1% Female 54.9% White 41.5% Black 3.6% Other SES: NR Co-Morb: 0% DM | 146 Evaluated 64 Excluded due to: psychiatric condition (24), not interested (21) Unable to attend group meetings (12), medical conditions (2), other (7) 82 randomized: I: 43 C: 39 Retention: I: 93% follow-up C:87.2% follow-up | [underlined: Inclusion]: Age 13–17; BMI 32–44 [underlined: Exclusion]: cardiovascular disease; Type 1 or 2 diabetes; major psychiatric disorder; pregnancy; use of wt-loss medication; weight loss of ≥5kg in past 6 mos; use of medication associated with weight gain; use of medication contraindicated with use of sibutramine; cigarette smoking | I: Sibutramine + Behavior Therapy C: Placebo + Behavior Therapy | Week 1: placebo Week 2: 5 mg/day Wks 3–6: 10 mg/day Wks 7–6 mos: 15 mg/day (decreased dose if systolic or diastolic BP increased by ≥10 mm Hg or pulse rate increased by ≥15% from baseline for 2 consecutive visits | BMI: I: 37.5 ± 4.0 C: 38.0 ± 3.6 BMI SDS: I: 2.4 ± 0.2 C: 2.5 ± 0.2 | [underlined: 6-mo] % change in BMI: IG: −8.5% ± 6.8% CG: −4.0% ± 5.4% p=0.001 Change in BMI SDS: IG: −0.2 ± 0.2 CG: −0.1 ± 0.1 p=0.003 | NA | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No Pulse: pulse rate higher in IG compared to CG by 5–6 bpm at 3 mos (P < 0.001) and 6 mos (p=0.007) Systolic blood pressure: at 3 mos, mean was increased in IG (1.8 (10.7) mmHG) and decreased in CG (−3.6(8.6); ES 0.55 (95% CI 0.10–1.00);p=0.02) at 6 mos, IG: 0.4 (9.0) mmHg CG: −4.0 (8.9) mmHg ES: 0.45 (−0.02, 0.92) p=0.06 Diastolic blood pressure: no differences between groups Elevated Blood Pressure: IG: 3/43 (7.0%) CG: 0/39 (0%) p=0.06 No statistically significant difference between groups at 6 mos for lipids, triglycerides, serum insulin, serum glucose, HOMA | Waist Circumference Waist Circ(cm) IG: −8.2(6.9) CG: −2.8 (5.6) p<0.001 | Any A.E.: IG: 6/43 (13.9%) CG: 3/39 (7.8%) NS See cardiovascular effects reported in physiological outcomes column Total rate of discontinuation due to A.E. among those taking sibutramine (I group in months 0–6 and 7–12, C group in months 7–12): 10/82 (12.2%); due to increased BP or HR 5/82 (6%), ecchymoses, VPCs or rash of unclear etiology Sexual maturity: NR Height change: NR
Berkowitz et al 2006^92^ Daniels et al 2007^102^ Good | RCT 498 adolescents 33 weight-loss clinics USA Databases of weight loss clinics; advertisements Weight loss July 2000-February 2002 Funding: Pharmaceutical | Age: 12–16 (Mean 13.7) 65.7% Female White: 56.6% Black: 21.1% Hispanic: 15.7% Other: 6.6% SES: NR Co-morb: 0% DM BP > 130/85 I: 5 (1.4%) C: 3 (2.3%) | 498 randomized I: 368 C: 130 Retention: I: 281 (76%) follow-up C: 80 (62%) follow-up | [underlined: Inclusion]: Age 12–16; BMI ≥ 2 SD more than U.S. weighted mean of the 95th %ile based on age/sex per 1998 Rosner norms (ref 17); BMI ≤ 44 [underlined: Exclusion]: cardiovascular disease; Type 1 or 2 diabetes; major psychiatric disorder; pregnancy; use of wt-loss medication or participation in weight loss program for >2 wks; use of medication associated with weight gain; use of medication contraindicated with use of sibutramine; cigarette smoking; Systolic blood pressure >130 mm HG; Diastolic blood pressure >85 mm Hg; pulse rate > 95 beats/min | I: Sibutramine + Behavior Therapy C: Placebo + Behavior Therapy | 10 mg daily, increase to 15 mg daily at 6 mos if have not lost 10% of initial BMI or more. Total of 12 mos. At 6 mos increased to 15 mg dose N=174 (47.9%) of the Sibutramine group | BMI: I: 36.1 ± 3.8 C: 35.9 ± 4.1 NS | NA | [underlined: 12-mo] % change in BMI: IG: −9.4 ± 0.51 CG: −1.2 ± 0.90 p<0.001 Absolute change in BMI: IG: −2.9 CG:−0.3 p<0.001 (using last observation carried forward) | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No [underlined: Mean difference between groups:] Systolic BP: 1.0 mm HG (95% CI 0.1–1.9) p=0.03 Diastolic BP: 1.7 mmHG (95% CI 1.0–2.5) p<0.001 Pulse rate: 2.5 beats per minute (95%CI 1.6–3.3) p<0.001 (For the BP parameters, the differences between groups were a reflection of a reduction in BP in the control group and slight (or no) reduction on average in the sibutramine group.) | Waist circumference WC (cm): IG: −8.2 ± 0.49 CG: −1.8 ± 0.86 p<0.001 | Any A.E.: IG: 327/368 (89%) CG: 111/130 (85%) NS Serious A.E.: IG: 2.7% (10/368) 0.8% (1/130) p=0.30 Discontinuation due to A.E. IG: 23/368 (6%) CG: 7/130 (5%) p=0.83 Tachycardia: IG: 46/368 (13%) CG: 8/130 (6%) p=0.05 Suicide attempt 1/368 (0.3%) 1/130 (0.8%) Depression/depressed state 5/368 (1.4%) 1/130 (0.8%) ECG: No clinically significant QTc prolongation or other mean changes from baseline. Also see additional relevant results in physiological
Van Mil et al, 2007^97^ Fair | RCT 24 adolescents Obesity research center The Netherlands Regional public health department, pediatric outpatient clinic of teaching hospital Weight Loss Time period NR Funding NR | Age: 12–17 yrs (Mean 14.0 (calc)) 54.2% Female Race/Eth: NR SES: NR Co-morb: NR | 24 randomized Retention: I: 11/12 (91.7%) C: 9/12 (75.0%) | [underlined: Inclusion]: Age 12–18; BMI ≥ 97th %ile for age and sex; triceps skinfold thickness ≥ 97th %ile for age and sex per 1996 Dutch norms (ref 9); persisting obesity despite professionally supervised wt loss attempts. [underlined: Exclusion]: Endocrine or other secondary causes of overweight; significant physical or medical illness. | I: Sibutramine + Behavior Therapy C: Placebo + Behavior Therapy | Wks 1–2: 5 mg/day Wks 3–12: 10 mg/day | BMI: I: 30.1 ± 4.5 C: 33.3 ± 5.0 BMI SDS: I: 2.60 ± 0.55 C: 2.97 ± 0.47 | NA | NA | NA | [underlined: 6-mo (3-mo post-intervention)]: BMI change: IG: −0.8 (calc) CG: −1.4 (calc) (could not calculate SD) BMI SDS change: IG: −0.14 (calc) CG: −0.13 (calc) (could not calculate SD) Compliance NR | Lipids: No Glucose tol: No BP: Yes Phys fitness: No | Fat mass, free fat mass | Any adverse effects. # events/# participants IG: 41/12 CG: 22/12 # participants with adverse effects IG: 12/12 (100%) CG: 9/12 (75.0%) NS Abdominal complaints IG: 7/12 (58.3%) CG: 0/12 (0.0%) p<0.01 No differences between groups in heart rate, blood pressure, ECG changes
Garcia-Morales et al, 2006^94^ Fair | RCT 52 adolescents Primary care pediatric obesity clinic Mexico Outpatients attending endocrinology department of children’s hospital. Weight loss August 2001–August 2003 Funding: Pharmaceutical | Age: 14–18 yrs (Mean 15.0 (c)) 56.5% Female(c) Race/Eth NR SES: NR Co-morb: NR | 70 screened 52 randomized I: 26 C: 25 Drop-out before 1 mo of treatment I: 3 C: 2 Completed 6 mo I: 21 (81%) C: 19 (76%) Analyzed I: 23 C: 23 | [underlined: Inclusion]: Living in the Mexico City metropolitan area; 14–18 yrs; BMI > 95 percentile for age and sex. [underlined: Exclusion]: Lactating or pregnant females; females sexually active without contraception; Systolic blood pressure ≥ 140 mmHg or Diastolic blood pressure ≥ 90 mmHg; history of anorexia nervosa or bulimia; no treatment within 30 days with corticosteroids, MAOIs, antidepressants, lithium, weight loss drugs, nasal or respiratory anticongestives, migraine treatment, gastrointestinal prokinetics, or antihistamines; using alcohol or recreational drugs; history of depression or weight loss treatment in last 6 mo; genetic disease associated with obesity; hypothyroidism; cancer; blood disease; gastrointestinal surgery; psychiatric disease; history of work or school problems; weight loss ≥ 3 kg in last 3 mo; unable to follow protocol. | I: Sibutramine + diet/exercise counseling C: Placebo + diet/exercise counseling | 10 mg/day 6 month | BMI I: 35.1 ± 5.3 C: 36.6 ± 5.2 Weight I: 92.6 ± 14.6 C: 98.9 ± 22.7 | BMI IG: −3.4 (−2.5, −4.2) CG: −1.8 (−0.9, −2.6) p< 0.005 (ANOVA testing interaction between treatment and time) Weight IG: −7.7 (−5.2, −10.2) CG: −3.8 (−1.6, −5.9) p< 0.005 (ANOVA testing interaction between treatment and time) | NA | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | Waist Circumference WC and % change in WC: NS between groups | Mild Adverse effects: IG: 3/23 patients (headache, dry mouth; Headache w/nausea; Headache w/weakness and paleness) CG: 3/23 patients (Headache, Headache w/somlolence, headache w/dry mouth) P > 0.05 between groups Withdrawl due to adverse effects: none in either group Sexual maturity: All patients were in Tanner stage IV at baseline and end of study Height: not different between groups
Godoy-Matos, 2005^95^ Fair | RCT 60 adolescents Research setting designed to reflect clinical practice Turkey Recruitment NR Weight loss January 2002-April 2003 Funding: Pharmaceutical | Age: 14–17 yrs 82% Female Race: NR SES: NR Co-morb: None | 68 patients recruited 8 subjects were lost after run-in period 60 randomized I: 30 C: 30 Completed I: 28 C: 22 | [underlined: Inclusion:] 14–17 yrs; BMI 30–45. [underlined: Exclusion:] Diabetes mellitus; endocrine diseases predisposing to obesity; severe hyperlipidemia; systemic or major psychiatric disorders; history of bulimia or anorexia; uncontrolled hypertension (Diastolic blood pressure > 110 mmHg) or other cardiac diseases; weight loss of 3 kg or more within 2 mo or use of weight loss/gain drugs within 3 mo; drug or alcohol abuse; recent tobacco cessation or intention to quit during study period; pregnancy or lactation. | I: Sibutramine + diet/exercise counseling C: Placebo + diet/exercise counseling | 1 mo run-in: placebo 6 mo: 10 mg/day | BMI, at wk -4 I: Female 37.5 ± 3.8 Male 37.6 ± 4.3 C: Female 35.8 ± 4.2 Male 37.4 ± 1.9 NS Weight, kg at wk 0 I: Female 97.7 ± 14.9 Male 115.2 ± 14.7 C: Female 91.9 ± 13.1 Male 110.2 ± 8.8 NS | BMI change I: −3.6 ± 2.5 C: −0.9 ± 0.9 p<0.001 Weight loss, kg I: −10.3 ± 6.6 C: −2.4 ± 2.5 p<0.001 | NA | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | Waist Circumference; waist to hip ratio | Constipation I: 40% C: 13.3% p=0.039 All others NS: dry mouth, heache, constipation, abdominal pain, cold dizzy. No one withdrew due to adverse effects
Orlistat
Chanoine et al, 2005^93^ Good | RCT 539 adolescents 32 institutions with established pediatric obesity treatment programs Canada and USA Advertisements in participant clinics and media, referrals from family physicians Weight loss August 2000–October 2002 Funding: Pharmaceutical | Age: 12–16 (Mean 13.6 (c)) 67% Female (c) 76.0% White (c) 16.9% Black (c) 7.1% Other (c) SES: NR 25.3% metabolic syndrome 1% DM | 588 Evaluated 49 Excluded (did not meet incl crit (42), other (7)) 539 Randomized I: 357 C: 182 Retention: I: 232/257 (65.0%) C: 117/180 (64.3%) | [underlined: Inclusion:] Age 12–16; BMI ≥ 2 SD more than U.S. weighted mean of the 95th %ile based on age/sex per Rosner 1998 norms (ref 1); parent/guardian willing to attend study visits with them; willing to be actively involved in behavioral modification [underlined: Exclusion:] BMI ≥ 44; body weight ≥ 130 kg or <55 kg; weight loss of ≥ 3 kg in past 3 mos; diabetes requiring antidiabetic meds; obesity associated with genetic disorders; psychiatric disorder; use of dexamphetamine or methylphenidate; active gastro-intestinal tract disorder; bulimia or laxative abuse; use of anorexiants or weight-loss treatment in past 3 mos | I: Orlistat + Behavior Therapy C: Placebo + Behavior Therapy | Wks 1–2: placebo Wks 3–54: 360 mg/day Compliance I: 73% C:72% | BMI: I: 35.7 ± 4.2 C: 35.4 ± 4.1 | NA | [underlined: 12-mo:] Adjusted Mean change in BMI: IG: −0.55 CG: +0.31 p<.001 | NA | NA | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | Waist & Hip Circumference, fat mass | Any adverse effects. IG: 97% CG: 94% Serious adverse effect I: 11/352 (3.1%) C: 5/181 (2.8%) Discontinued treatment due to adverse effects: IG: 12/352 (3.4%) CG: 3/181 (1.7%) Also assessed and found no group differences: levels of vitamin A, D, E, & beta carotene; levels of estradiol; change in height; sexual maturation, bone mineral density
Maahs et al 2006^96^ Fair+A13 | RCT 40 adolescents Research clinic USA Physician referral and newpaper advertisement Weight loss December 2002–February 2003 Funding: Universitysupported | Age: 14–18 (Mean 15.8) 67.5% Female(c) 62.5% Hispanic (c) SES: NR Co-morb: NR | 43 evaluated 3 excluded (parent refusal, not interested, psychological issues) 40 randomized I: 20 C: 20 Retention: I: 16/20 (80%) C: 18/20 (90%) p=0.68 | [underlined: Inclusion:] Age 14–18; BMI >85th %ile of age and sex (norms NR) [underlined: Exclusion:] known secondary cause for obesity (e.g., hypothyroidism, daily corticosteroid exposure, genetic disorder); pregnancy | I: Orlistat + monthly diet/exercise counseling C: Placebo + monthly diet/exercise counseling | 360 mg/day, 6 mos | BMI: I: 39.2 ± 1. 2 C: 41.7 ± 2.6 Weight I: 111.1 ± 5.1 C: 114.3 ± 8.6 | [underlined: 6-mo:] BMI: IG: 37.9 ± 1.6 CG: 40.9 ± 3.0 p=0.70, for time-by-group effect (including 3-mo values) Weight IG: 105.6 ± 6.2 CG: 112.7 ± 9.5 p=0.76 | NA | NA | NA | Lipids: Yes Glucose tol: Yes BP: No Phys fitness: No | % body fat by bioelectrical impedance analysis | Discontinue due to A.E.: I: 2/20 (10%) C: 0/20 (0%) p-value NR I group reported higher levels of: soft stools (p=0.002); oily spotting (p<0.001); fatty or oily stools (p<0.001); oily evacuation (p<0.001); liquid stools (p=0.02); cramping (p=0.02); flatus w discharge (p<0.001); fecal incontinence (p<0.001)
Metformin-in special population
Srinivasan et al, 2006^99^ Fair | Cross-over RCT 28 children and adolescents Pediatric endocrine clinic Australia Physician referal to endocrine clinic of pediatric hospital Change in body composition | Age: 9–18 (Mean12.5) 53.6% Female (c) 64% Pacific Islands or Indian subcontinent 25% Northern European 11% Mixed heritage SES: NR Co-morb: 0% DM | 34 assessed for eligibility 28 randomized: Group A (metformin first): 13 Group B (placebo first): 15 Retention: A: 10/13 (76.9%) B: 12/15 (80.0%) follow- up | [underlined: Inclusion:] Age 9–18; referred to endocrine clinic with obesity per International Obesity Task Force definition; clinical suspicion of insulin resistance as defined by either a fasting insuline to glucose ratio >4.5 OR the presence of acanthosis nigricans. [underlined: Exclusion:] Known type 1 or 2 DM; contraindications to metformin; contraindications to MRI; weight >120 kg | A: Metformin, then placebo B: Placebo, then metformin | 6 months metformin, gradually increased (over 3 wks) up to 2 g/day, 6 months placebo Compliance I: 78% (15–99%) C: 78% (35–98%) p=0.689 | BMI, overall: 35.2 ± 5.1 BMI SDS, overall: 2.43 ± 0.28 Weight, kg, overall: 89.9 ± 17.6 | Metformin treatment effect size: Weight, kg: −4.35 p=0.02 BMI −1.26 p=0.002 BMI SDS: −0.12 p=0.005 | | | | Lipids: Yes Glucose tol: Yes BP: Yes Phys fitness: No | Waist circumference, subcutaneous abdominal adipose tissue, visceral abdomnial adipose tissue, % total body fat. | Any adverse effects 2/28 (7%) nausea prevented full dose (both 9-year-olds, youngest age in study) They tolerated 750 mg ×2/day Serious adverse effects0/28 (0%) Discontinued treatment due to adverse effects: NR
Freemark et al., 2001^98^ Fair | RCT 32 adolescents University research clinic USA Recruitment strategy: NR Funding: Pharmaceutical and General Clinical Research Center Grant | Age: 12–19 years (Mean for CG: 15.4 ± 0.5; IG: 14.4 ± 0.6) 62% Female (c*) 55%White(calc*) 45% Black (calc*) SES: NR % Co-morbid:NR 8 pts had acanthosis nigricans (all were black) *=data were reported only for 29/32 who completed trial | #assessed for eligibility: NR 32 randomized I: 15 C: 17 %retention: I: 93% C: 88% analyzed completers only | Inclusion: Age 12–19 who had reached Tanner stage III puberty; BMI > 30 kg/m2; fasting insulin concentration > 15 μU/mL; at least 1 first- or second-degree relative with type 2 diabetes; normal fasting glucose concentration (< 110 mg%) and HbA1c concentration (≤ 6.0%). Exclusion: NR | IG: Metformin CG: Placebo No attempt was made to control the caloric intake or food selection of the patients | Metformin 500 mg or Placebo, twice per day (1 at breakfast; 1 at dinner) × 6 months | BMI: IG: 41.5 ± 0.9 CG: 38.7 ±1.3 (p < 0.05) | [underlined: 6 mos:] BMI SDS IG: −0.12 CG: 0.23 p< 0.02 BMI IG: −0.5 kg/m2 CG: 0.9 kg/m2 p-value NR | N/A | N/A | N/A | Glucose tol=yes lipids=yes | No | No patients discontinued due to adverse events; no episodes of vomiting or lactic acidosis; serum lactate, liver and renal function parameters remained normal IG: 1 pt intermittent nausea in mos 3–4 until metforming dose was reduced by 50%; 3 abdominal discomfort during first 1–2 wks CG: 1 had abdominal discomfort
Love-Osborne et al, 2008^100^ Fair | RCT 85 adolescents Setting: Research clinic; followup in schools or community USA Recruitment Strategy: posted advertisements or through primary care providers Funding: NIH, Barbara Davis Center for Childhood Diabetes, Children’s Hospital Research Institute, Kettering Family Foundation | Age: 12–19 years (Mean for CG: 14.2 ± 4.6; IG: 15.5 ± 1.7) 71% Female (calc) %White NR 34% Black 56% Hispanic SES: NR %Co-morbid: 8% impaired glucose tolerance 0% DM | # Assessed for eligibility: NR # Randomized IG: 60 CG: 25 % Retention: IG: 80% CG: 64% Analyzed completers only | Inclusion: Age 12–19 with fasting insulin level > 25μU/mL or homeostasis model assessment > 3.5 and 2 of 3 risk factors (presence of acanthosis nigricans, obesity (BMI>95%ile), or family history of T2DM) Exclusion:preexisting diabetes, pregnancy, heart disease, serum gamma-glutamyl transferase over 1.5 times the upper limit of normal, or creatinine > 1.5 mg/dL | IG: Metformin + behavioral intervention (personal goal -setting) CG: Placebo + behavioral intervention (personal goal- setting) | Metformin 500 mg or Placebo, once per day × 1 month; then 500 mg twice per day × 1 month; then 850 mg twice per day × 4 months (lowered to previous dose if GI side effects for > 2 weeks) | BMI: IG:39.4 ± 6.5 CG:39.3 ± 7.2 BMI z-score IG: 4.6 ± 1.8: CG: 6.2 ± 8.9 Weight (kg): IG:108.8 ±23.1 CG:110.6 ±23.4 | 6 mos: BMI IG: −0.16 ± 1.89 CG: 0.63 ± 1.29 p-value 0.11 >5% BMI decrease: IG: 11 (22.9%) CG: 0 (0%) p = 0.001 Increase in BMI IG: 20 (41.7%) CG: 11(68.8%) p=0.06 | N/A | N/A | N/A | Lipids: NR Glucose tol: yes BP: NR Phys fitness: NR | NR | Gastro-intestinal side effects IG: 14/48 (29%) CG: 3/16 (19%) (among completers) Dropped out due to GI side effects IG: 2/12 (17%)calc CG: 1/9(11%) calc (Among 21 drop-outs)

Abbreviations: IG: Intervention; NR: Not reported; DM: Diabetes Mellitus; CG: Control Group; T2DM: Type 2 Diabetes Mellitus; SES: Socioeconomic status; A.E: Adverse effects; Mos: months; SD: standard deviation

Evidence Table 4 List of excluded studies

References | Reason for Exclusion
Behavioral interventions
Alexy U, Reinehr T, Sichert-Hellert W, Wollenhaupt A, Kersting M, Andler W. Positive changes of dietary habits after an outpatient training program for overweight children. Nutrition Research 26 (5):202–208, 2006. | Did not meet quality criteria
Amador M, Ramos LT, Morono M, Hermelo MP. Growth rate reduction during energy restriction in obese adolescents. Exp Clin Endocrinol. 1990;96:73–82. | Setting
Ambler C, Eliakim A, Brasel JA, Lee WN, Burke G, Cooper DM. Fitness and the effect of exercise training on the dietary intake of healthy adolescents. Int J Obes Relat Metab Disord. 1998;22:354–362. | Relevance
Arnold, Linda L. The effects of a program of exercise and nutrition on body composition in adolescents and young adults with moderate cognitive disabilities: A descriptive study. Dissertation Abstracts International: Section B: The Sciences and Engineering 65[11-B], 6062. 2005. | Population
Ask AS, Hernes S, Aarek I, Johannessen G, Haugen M. Changes in dietary pattern in 15 year old adolescents following a 4 month dietary intervention with school breakfast--a pilot study. Nutrition Journal 5:33. 2006. | Did not report relevant outcomes
Atlantis E, Barnes EH, Singh MA. Efficacy of exercise for treating overweight in children and adolescents: a systematic review. Int J Obes (Lond). 2006;30:1027–1040. | Design
Balagopal P, George D, Patton N et al. Lifestyle-only intervention attenuates the inflammatory state associated with obesity: a randomized controlled study in adolescents. Journal of Pediatrics146(3):342–8. 2005. | Design
Balagopal P, George D, Yarandi H, Funanage V, Bayne E. Reversal of obesity-related hypoadiponectinemia by lifestyle intervention: a controlled, randomized study in obese adolescents. Journal of Clinical Endocrinology & Metabolism 90(11):6192–7. 2005. | Design
Barbeau P, Johnson MH, Howe CA et al. Ten months of exercise improves general and visceral adiposity, bone, and fitness in black girls. Obesity. 2007;15:2077–2085. | Intervention not primary care
Bauer C, Fischer A, Keller U. Effect of sibutramine and of cognitive-behavioural weight loss therapy in obesity and subclinical binge eating disorder. Diabetes, Obesity & Metabolism 8(3):289–95. 2006. | Design
Baumer JH. Obesity and overweight: its prevention, identification, assessment and management. Archives of Disease in Childhood Education & Practice 92(3):ep92–6. 2007. | Design
Becque MD, Katch VL, Rocchini AP, Marks CR, Moorehead C. Coronary risk incidence of obese adolescents: reduction by exercise plus diet intervention. Am J Clin Nutr. 1988;81:605–612. | Design
Beech BM, Klesges RC, Kumanyika SK et al. Child- and parent-targeted interventions: the Memphis GEMS pilot study. Ethn Dis. 2003;13:S40–S53. | Design
Berry D, Savoye M, Melkus G, Grey M. An intervention for multiethnic obese parents and overweight children. Applied Nursing Research. 2007;63–71, 2007. | Design
Berry D, Sheehan R, Heschel R, Knafl K, Melkus G, Grey M. Family-based interventions for childhood obesity: a review (Structured abstract). SO: Journal of Family Nursing. 2004;10:429–449. | Design
Braet C, Van WM, Van LK. Follow-up results of different treatment programs for obese children. Acta Paediatr. 1997;86:397–402. | Design
Braet C, Tanghe A, Bode PD, Franckx H, Winckel MV. Inpatient treatment of obese children: A multicomponent programme without stringent calorie restriction. Eur J Pediatr. 2003;162:391–396. | Setting
Braet, C. and Winckel, M. V. Long-Term Follow-Up of a Cognitive Behavioral Treatment Program for Obese Children. Behavior Therapy 31, 55–74. 2000. | Design
Brown R, Sothern M, Suskind R, Udall J, Blecker U. Racial differences in the lipid profiles of obese children and adolescents before and after significant weight loss. Clin Pediatr (Phila). 2000;39:427–431. | Design
Brownell KD, Kaye FS. A school-based behavior modification, nutrition education, and physical activity program for obese children. Am J Clin Nutr. 1982;35:277–283. | Design
Butryn ML, Wadden TA. Treatment of overweight in children and adolescents: does dieting increase the risk of eating disorders? (Structured abstract). SO: International Journal of Eating Disorders. 2005;37:285–293. | Design
Campbell KJ, Hesketh KD. Strategies which aim to positively impact on weight, physical activity, diet and sedentary behaviours in children from zero to five years. A systematic review of the literature. Obesity Reviews 8(4):327–38. 2007. | Did not report relevant outcomes
Carrel AL, Clark RR, Peterson SE, Nemeth BA, Sullivan J, Allen DB. Improvement of fitness, body composition, and insulin sensitivity in overweight children in a school-based exercise program: Arandomized, controlled study. Archives of pediatrics & adolescent medicine. 2005;159:963–968. | Setting
Carrel AL, Clark RR, Peterson S, Eickhoff J, Allen DB. School-based fitness changes are lost during the summer vacation. Archives of pediatrics & adolescent medicine. 2007;161:561–564. | Setting
Chang FT, Hu SH, Wang RS. The effectiveness of dietary instruction in obese school children of southern Taiwan. Kaohsiung J Med Sci. 1998;14:528–535. | Setting
Chen W, Chen SC, Hsu HS, Lee C. Counseling clinic for pediatric weight reduction: program formulation and follow-up. J Formos Med Assoc. 1997;96:59–62. | Setting
Clemmens D, Hayman LL. Increasing activity to reduce obesity in adolescent girls: a research review (Provisional record). SO: Journal of Obstetric, Gynecologic and Neonatal Nursing. 2004;33:801–808. | Design
Cliff DP, Wilson A, Okely AD, Mickle KJ, Steele JR. Feasibility of SHARK: A physical activity skill-development program for overweight and obese children. Journal of Science & Medicine in Sport 10(4):263–7. 2007. | Design
Cole K, Waldrop J, D’Auria J, Garner H. An integrative research review: effective school-based childhood overweight interventions. J Spec Pediatr Nurs. 2006;11:166–177. | Design
Coleman KJ, Tiller CL, Sanchez J et al. Prevention of the epidemic increase in child risk of overweight in low-income schools: the El Paso coordinated approach to child health. Archives of Pediatrics & Adolescent Medicine 159(3):217–24. 2005. | Relevance
Collins CE, Warren J, Neve M, McCoy P, Stokes BJ. Measuring effectiveness of dietetic interventions in child obesity: a systematic review of randomized trials. Arch Pediatr Adolesc Med. 2006;160:906–922. | Design
Collins CE, Warren JM, Neve M, McCoy P, Stokes B. Systematic review of interventions in the management of overweight and obese children which include a dietary component (Provisional record). SO: International Journal of Evidence Based Healthcare. 2007;5:2–53. | Design
Daley AJ, Copeland RJ, Wright NP, Roalfe A, Wales JK. Exercise therapy as a treatment for psychopathologic conditions in obese and morbidly obese adolescents: a randomized, controlled trial. Pediatrics 118 (5):2126–34. 2006. | Relevance
Daley AJ, Copeland RJ, Wright NP, Wales JK. Protocol for: Sheffield Obesity Trial (SHOT): a randomised controlled trial of exercise therapy and mental health outcomes in obese adolescents. BMC Public Health 5:113. 2005. | Relevance
Danielzik, S., Pust, S., Landsberg, B., and Muller, M. J. First lessons from the Kiel Obesity Prevention Study (KOPS). International Journal of Obesity 29[Suppl2], S78–S83. 2005. | Relevance
Davee AM, Blum JE, Devore RL et al. The vending and a la carte policy intervention in Maine public high schools. Preventing Chronic Disease 2 Spec no:A14. 2005. | Design
Davis CE, Hunsberger S, Murray DM et al. Design and statistical analysis for the Pathways study. Am J Clin Nutr. 1999;69:760S–763S. | Relevance
Deforche B, De Bourdeaudhuij I, Tanghe A, Debode P, Hills AP, Bouckaert J. Post-treatment phone contact: A weight maintenance strategy in obese youngsters. Int J Obes. 2005;29:543–546. | Study design
DeJongh ED, Binkley TL, Specker BL. Fat mass gain is lower in calcium-supplemented than in unsupplemented preschool children with low dietary calcium intakes. American Journal of Clinical Nutrition 84(5):1123–7. 2006. | Relevance
DeMattia L, Lemont L, Meurer L. Do interventions to limit sedentary behaviours change behaviour and reduce childhood obesity? A critical review of the literature. Obesity Reviews 8(1):69–81. 2007. | Design
Dennison B Russo TJ, Burdick PA, Jenkins PL. An intervention to reduce television viewing by preschool children. Arch Pediatr Adolesc Med. 2004;158:170–176. | Relevance
Dicken KR, Bell MM. Pedometers as a means to increase walking andachieve weight loss. SO: Journal of the American Board of Family Medicine: JABFM. 2006;19:524–525. | Population
Donnelly JE, Jacobsen DJ, Whatley JE, Hill JO, Swift LL, Cherrington A, Polk B, Tran ZV, Reed G. Nutrition and physical activity program to attenuate obesity and promote physical and metabolic fitness in elementary school children. Obes Res 4 (3):229–243, 1996. | Prevention trial
Dreimane D, Safani D, MacKenzie M et al. Feasibility of a hospital-based, family-centered intervention to reduce weight gain in overweight children and adolescents. Diabetes Research & Clinical Practice 75(2):159–68. 2007. | Design
Duffy G, Spence SH. The effectiveness of cognitive self-management as an adjunct to a behavioural intervention for childhood obesity: a research note. J Child Psychol Psychiatry. 1993;34:1043–1050. | Quality
Ebbeling CB, Feldman HA, Osganian SK, Chomitz VR, Ellenbogen SJ, Ludwig DS. Effects of decreasing sugar-sweetened beverage consumption on body weight in adolescents: a randomized, controlled pilot study. Pediatrics 117 (3):673–80. 2006. | Relevance
Ebbeling CB, Garcia-Lago E, Leidig MM, Seger-Shippee LG, Feldman HA, Ludwig DS. Altering portion sizes and eating rate to attenuate gorging during a fast food meal: effects on energy intake. Pediatrics 119 (5):869–75. 2007. | Relevance
Ebbeling CB, Leidig MM, Feldman HA, Lovesky MM, Ludwig DS. Effects of a low-glycemic load vs low-fat diet in obese young adults: a randomized trial. JAMA 297 (19):2092–102. 2007. | Population
Ebbeling CB, Leidig MM, Sinclair KB, Hangen JP, Ludwig DS. A reduced-glycemic load diet in the treatment of adolescent obesity. Archives of Pediatrics & Adolescent Medicine. 2003;157:773–779. | Design
Economos CD, Hyatt RR, Goldberg JP et al. A community intervention reduces BMI z-score in children: Shape Up Somerville first year results. Obesity 15(5):1325–36. 2007. | Relevance
Edwards B. Childhood obesity: a school-based approach to increase nutritional knowledge and activity levels. Nurs Clin North Am. 2005;40:661–6ix. | Not primary care feasible or
Eliakim A, Kaven G, Berger I, Friedland O, Wolach B, Nemet D. The effect of a combined intervention on body mass index and fitness in obese children and adolescents - a clinical experience. Eur J Pediatr. 2002;161:449–454. | Did not report relevant outcomes
Epstein LH, Kuller LH, Wing RR, Valoski A, McCurley J. The effect of weight control on lipid changes in obese children. Am J Dis Child. 1989;143:454–457. | Precedes search period
Epstein LH, McCurley J, Wing RR, Valoski A. Five-year follow-up of family-based behavioral treatments for childhood obesity. J Consult Clin Psychol. 1990;58:661–664. | Design
Epstein LH, McKenzie SJ, Valoski A, Klein KR, Wing RR. Effects of mastery criteria and contingent reinforcement for family-based child weight control 3838. Addictive Behaviors. 1994;19:135–145. | Design
Epstein LH, Paluch RA, Raynor HA. Sex differences in obese children and siblings in family-based obesity treatment. Obesity Research. 2001;9:746–753. | Design
Epstein LH, Saelens BE, O’Brien JG. Effects of reinforcing increases in active behavior versus decreases in sedentary behavior for obese children. Int J Behav Med. 1995;2:41–50. | Did not report relevant outcomes
Epstein LH, Valoski A, McCurley J. Effect of weight loss by obese children on long-term growth. Am J Dis Child. 1993;147:1076–1080. | Design
Epstein LH, Valoski A, Wing RR, McCurley J. Ten-year outcomes of behavioral family-based treatment for childhood obesity. Health Psychol. 1994;13:373–383. | Design
Epstein LH, Valosk Ai, Wing RR, McCurley J. Ten-year follow-up of behavioral, family-based treatment for obese children. JAMA 264 (19):2519–2523, 1990. | Precedes search period
Epstein LH, Valoski AM, Kalarchian MA, McCurley J. Do children lose and maintain weight easier than adults: a comparison of child and parent weight changes from six months to ten years. Obes Res. 1995;3:411–417. | Did not report relevant outcomes
Epstein LH, Wing RR, Koeske R, Andrasik F, Ossip DJ. Child and parent weight loss in family-based behavior modification programs. J Consult Clin Psychol. 1981;49:674–685. | Design
Epstein LH, Wing RR, Koeske R, Valoski A. Effect of parent weight on weight loss in obese children. J Consult Clin Psychol. 1986;54:400–401. | Did not report relevant outcomes
Epstein LH, Wing RR, Koeske R, Valoski A. Long-term effects of family- based treatment of childhood obesity. J Consult Clin Psychol. 1987;55:91–95. | Precedes search period
Epstein LH, Valoski A, Koeske R, Wing RR. Family-based behavioral weight control in obese young children. J Am Diet Assoc 86 (4):481–484, 1986. | Design
Epstein LH, Valoski AM, Vara LS, McCurley J, Wisniewski L, Kalarchian MA, Klein KR, Shrager LR. Effects of decreasing sedentary behavior and increasing activity on weight change in obese children 3814. Health Psychology. 14 (2):109–115, 1995 | Design
Epstein LH, R. Paluch RA, Gordy CC, Dorn J. Decreasing sedentary behaviors in treating pediatric obesity. Arch Pediatr Adolesc Med 154 (3):220–226, 2000. | Design
Epstein LH, Paluch RA, Saelens BE, Ernst MM, Wilfley DE. Changes in eating disorder symptoms with pediatric obesity treatment. J Pediatr 139 (1):58–65, 2001 | Design
Epstein LH, Paluch RA, Kilanowski CK, Raynor HA. The effect of reinforcement or stimulus control to reduce sedentary behavior in the treatment of pediatric obesity. Health Psychol 23 (4):371–380, 2004. | Design
Epstein LH, Paluch RA, Roemmich JN, Beecher MD. Family-based obesity treatment, then and now: Twenty-five years of pediatric obesity treatment. Health Psychol. 26(4):381–391, 2007. | Design
Epstein LH, Wing RR, Valoski A, Penner BC. Stability of food preferences during weight control. A study with 8- to 12-year-old children and their parents. Behav Modif. 1987;11:87–101. | Did not report relevant outcomes
Epstein LH, Wing RR, Penner BC, Kress MJ. Effect of diet and controlled exercise on weight loss in obese children. J Pediatr. 1985;107:358–361. | Comparative effectiveness study
Epstein LH, Wing RR, Koeske R, Valoski A. Effects of diet plus exercise on weight change in parents and children. J Consult Clin Psychol. 1984;52:429–437. | Precedes search date
Epstein LH. Effects of family-based behavioral treatment on obese 5-to-8-year-old children. Behavior Therapy. 1985;16:205–212. | Comparative effectiveness study
Epstein LH, Paluch RA, Beecher MD, Roemmich JN. Increasing healthy eating vs. reducing high energy-dense foods to treat pediatric obesity. Obesity. 2008;16:318–326. | Comparative effectiveness study
Figueroa-Colon R, von Almen TK, Franklin FA, Schuftan C, Suskind RM. Comparison of two hypocaloric diets in obese children. Am J Dis Child. 1993;147:160–166. | Design
Figueroa-Colon R, Franklin FA, Lee JR, von Almen TK, Suskind RM. Feasibility of a clinic-based hypocaloric dietary intervention implemented in a school setting for obese children. Obes Res 4 (5):419–429, 1996. | Design
Fitzgibbon ML, Stolley MR, Schiffer L, Van HL, KauferChristoffel K, Dyer A. Two-year follow-up results for Hip-Hop to Health Jr.: a randomized controlled trial for overweight prevention in preschool minority children. Journal of Pediatrics 146(5):618–25. 2005. | Prevention only
Flodmark, C.-E., Marcus, C., and Britton, M. Interventions to prevent obesity in children and adolescents: A systematic literature review. International Journal of Obesity 30[4], 579–589. 2006. | Relevance
Flores R. Dance for health: improving fitness in African American and Hispanic adolescents. Public Health Rep 110 (2):189–193, 1995. | Outcomes < 6 months
Foster GD, Wadden TA, Brownell KD. Peer-led program for the treatment and prevention of obesity in the schools. J Consult Clin Psychol. 1985;53:538–540. | Design
Gately PJ, Cooke CB, Barth JH, Bewick BM, Radley D, Hill AJ. Children’s residential weight-loss programs can work: a prospective cohort study of short-term outcomes for overweight and obese children. Pediatrics 116(1):73–7. 2005. | Design
Gately PJ, King NA, Greatwood HC et al. Does a High-protein Diet Improve Weight Loss in Overweight and Obese Children? Obesity 15(6):1527–34. 2007. | Design
Gibson LJ, Peto J, Warren JM, dos SS, I. Lack of evidence on diets for obesity for children: a systematic review. International Journal of Epidemiology 35(6):1544–52. 2006. | Design
Golan M, Crow S. Targeting parents exclusively in the treatment of childhood obesity: long-term results. Obes Res. 2004;12:357–361. | Information provided in another publication
Golan M, Weizman A, Apter A, Fainaru M. Parents as the exclusive agents of change in the treatment of childhood obesity. Am J Clin Nutr. 1998;67:1130–1135. | Comparative effectiveness study
Golan M, Kaufman V, Shahar DR. Childhood obesity treatment: Targeting parents exclusively v. parents and children. Br J Nutr. 2006;95:1008–1015. | Comparative effectiveness study
Goldfield GS, Mallory R, Parker T et al. Effects of modifying physical activity and sedentary behavior on psychosocial adjustment in overweight/obese children. Journal of Pediatric Psychology 32(7):783–93. 2007. | Design
Goldfield GS, Epstein LH, Kilanowski CK, Paluch RA, Kogut-Bossler B. Cost-effectiveness of group and mixed family-based treatment for childhood obesity. Int J Obes Relat Metab Disord 25 (12):1843–1849, 2001. | Design
Goldfield GS, Mallory R, Parker T et al. Effects of open-loop feedback on physical activity and television viewing in overweight and obese children: a randomized, controlled trial. Pediatrics 118 (1):e157–66. 2006. | < 6 months followup
Gortmaker SL, Peterson K, Wiecha J et al. Reducing obesity via a school-based interdisciplinary intervention among youth: Planet Health. Arch Pediatr Adolesc Med. 1999;153:409–418. | Relevance
Graf C, Koch B, Bjarnason-Wehrens B et al. Who benefits from intervention in, as opposed to screening of, overweight and obese children? Cardiology in the Young 16(5):474–80. 2006. | Did not report relevant outcomes
Graf C, Rost SV, Koch B et al. Data from the StEP TWO programme showing the effect on blood pressure and different parameters for obesity in overweight and obese primary school children. Cardiol Young. 2005;15:291–298. | Setting
Graves T, Meyers AW, Clark L. An evaluation of parental problem- solving training in the behavioral treatment of childhood obesity. J Consult Clin Psychol. 1988;56:246–250. | Design
Grey M, Berry D, Davidson M, Galasso P, Gustafson E, Melkus G. Preliminary testing of a program to prevent type 2 diabetes among high- risk youth. J Sch Health 74 (1):10–15, 2004. | Design
Gutin B, Barbeau P, Owens S et al. Effects of exercise intensity on cardiovascular fitness, total body composition, and visceral adiposity of obese adolescents. American Journal of Clinical Nutrition. 2002;75:818–826. | Comparative effectiveness study
Gutin B, Yin Z, Johnson M, Barbeau P. Preliminary findings of the effect of a 3-year after-school physical activity intervention on fitness and body fat: the Medical College of Georgia Fitkid Project. International Journal of Pediatric Obesity. 2008;3:Suppl-9. | Intervention not primary care feasible/referable
Harrell JS, Gansky SA, McMurray RG, Bangdiwala SI, Frauman AC, Bradley CB. School-based interventions improve heart health in children with multiple cardiovascular disease risk factors. Am J Clin Nutr. 1998;102:371–380. | Relevance
Harvey-Berino J, Rourke J. Obesity prevention in preschool native- american children: a pilot study using home visiting. Obes Res. 2003;11:606–611. | Relevance
Heymsfield SB, van-Mierlo CA, van-der-Knaap HC, Heo M, Frier H, I. Weight management using a meal replacement strategy: meta and pooling analysis from six studies (Structured abstract). SO: International Journal of Obesity. 2003;27:537–549. | Population
Hills AP, Parker AW. Obesity management via diet and exercise intervention. Child Care Health Dev. 1988;14:409–416. | Design
Huang JS, Norman GJ, Zabinski MF, Calfas K, Patrick K. Body image and self-esteem among adolescents undergoing an intervention targeting dietary and physical activity behaviors. Journal of Adolescent Health 40(3):245–51. 2007. | Relevance
Hughes AR, Stewart L, Chapple J et al. Randomized, controlled trial of a best-practice individualized behavioral program for treatment of childhood overweight: Scottish Childhood Overweight Treatment Trial (SCOTT). Pediatrics. 2008;121:e539–e546. | Comparative effectiveness study
Ildiko V, Zsofia M, Janos M et al. Activity-related changes of body fat and motor performance in obese seven-year-old boys. Journal of Physiological Anthropology 26(3):333–7. 2007. | Setting
Intense diet, behavior, and physical activity intervention effective for obese children. J Fam Pract. 2005;54:579. | Design
Israel A, Solotar LC, Zimand E. An Investigation of Two Parental Involvement Roles in the Treatment of Obese Children. Int.J.Eat.Disord. 9(5):557–564, 1990. | Design
Israel, A., Stolmaker, Laurie, Sharp, Jeanette P, Silverman, W. K., and Simon, Linda G. An Evaluation of Two Methods of Parental Involvement in Treating Obese Children. Behavior Therapy 15, 266–272. 1984. | Comparative effectiveness study
Israel AC, Stolmaker L, Andrian CA. The effects of training parents in general child management skills on a behavioral weight loss program for children. Behavior Therapy. 1985;16:169–180. | Comparative effectiveness study
Jago R, Jonker ML, Missaghian M, Baranowski T. Effect of 4 weeks of Pilates on the body composition of young girls. Preventive Medicine42(3):177–80. 2006. | Relevance
Jago R, Baranowski T, Baranowski JC, Thompson D, Cullen KW, Watson K, Liu Y. Fit for Life Boy Scout badge: outcome evaluation of a troop and Internet intervention. SO: Preventive medicine 42 (3):181–187, 2006. | Prevention Trial
Jelalian E, Mehlenbeck R, Lloyd-Richardson EE, Birmaher V, Wing RR. ‘Adventure therapy’ combined with cognitive-behavioral treatment for overweight adolescents. International Journal of Obesity 30(1):31–9. 2006. | Design
Jelalian E, Wember YM, Bungeroth H, Birmaher V. Practitioner review: bridging the gap between research and clinical practice in pediatric obesity. Journal of Child Psychology & Psychiatry & Allied Disciplines 48 (2):115–27. 2007. | Design
Jiang JX, Xia XL, Greiner T, Lian GL, Rosenqvist U. A two year family based behaviour treatment for obese children. Archives of Disease in Childhood 90(12):1235–8. 2005. | Setting
Johnson WG, Hinkle LK, Carr RE et al. Dietary and exercise interventions for juvenile obesity: long-term effect of behavioral and public health models. Obes Res. 1997;5:257–261. | <6 months followup
Johnston, Craig A. and Steele, Ric G. Treatment of Pediatric Overweight: An Examination of Feasibility and Effectiveness in an Applied Clinical Setting. Journal of Pediatric Psychology 32[1], 106–110. 2007. | Design
Johnston CA, Tyler C, Fullerton G et al. Results of an intensive school- based weight loss program with overweight Mexican American children. Int J Pediatr Obes. 2007;2:144–152. | Setting
Johnston CA, Tyler C, McFarlin B et al. Weight Loss in Overweight Mexican American Children: A Randomized Controlled Trial. Pediatrics. 2007;120:e1450–e1457. | Setting
Jones RA, Okely AD, Collins CE et al. The HIKCUPS trial: a multi-site randomized controlled trial of a combined physical activity skill- development and dietary modification program in overweight and obese children. BMC Public Health 7:15. 2007. | Did not report relevant outcomes
Jones M, Luce KH, Osborne MI et al. Randomized, controlled trial of an internet-facilitated intervention for reducing binge eating and overweight in adolescents. Pediatrics. 2008;121:453–462. | Population
Kalavainen MP, Korppi MO, Nuutinen OM. Clinical efficacy of group- based treatment for childhood obesity compared with routinely given individual counseling. Int J Obes (Lond). 2007;31:1500–1508. | Setting
Kang HS, Gutin B, Barbeau P et al. Physical training improves insulin resistance syndrome markers in obese adolescents. Medicine & Science in Sports & Exercise. 2002;34:1920–1927. | Comparative effectiveness study
Kelly AS, Steinberger J, Olson TP, Dengel DR. In the absence of weight loss, exercise training does not improve adipokines or oxidative stress in overweight children. Metabolism: Clinical & Experimental56(7):1005–9. 2007. | Design
Kitzmann, Katherine M. and Beech, Bettina M. Family-Based Interventions for Pediatric Obesity: Methodological and Conceptual Challenges From Family Psychology. Journal of Family Psychology 20[2], 175–189. 2006. | Design
Klijn PH, van der Baan-Slootweg OH, van Stel HF. Aerobic exercise in adolescents with obesity: preliminary evaluation of a modular training program and the modified shuttle test. BMC Pediatrics 7:19. 2007. | Design
Korsten-Reck U, Kromeyer-Hauschild K, Wolfarth B, Dickhuth HH, Berg A. Freiburg Intervention Trial for Obese Children (FITOC): results of a clinical observation study. International Journal of Obesity 29(4):356 – 61. 2005. | Did not report relevant outcomes
Lansky D, Vance MA. School-based intervention for adolescent obesity: analysis of treatment, randomly selected control, and self-selected control subjects. J Consult Clin Psychol. 1983;51:147–148. | Design
Lauer RM, Obarzanek E, Hunsberger SA, et al. Efficacy and safety of lowering dietary intake of total fat, saturated fat, and cholesterol in children with elevated LDL cholesterol: the Dietary Intervention Study in Children. Am J Clin Nutr 72 (5 Suppl):1332S–1342S, 2000. | Not a weight loss trial
Levine MD, Ringham RM, Kalarchian MA, Wisniewski L, Marcus MD. Is family-based behavioral weight control appropriate for severe pediatric obesity? Int J Eat Disord. 2001;30:318–328. | Design
Lytle LA, Stone EJ, Nichaman MZ et al. Changes in nutrient intakes of elementary school children following a school-based intervention: results from the CATCH Study. Prev Med. 1996;25:465–477. | Relevance
Maffeis C, Castellani M. Physical activity: an effective way to control weight in children? Nutrition Metabolism & Cardiovascular Diseases 17(5):394 –408. 2007. | Design
Martinez V, V, Salcedo AF, Franquelo GR et al. Assessment of an after-school physical activity program to prevent obesity among 9- to 10-year-old children: a cluster randomized trial. Int J Obes. 2008;32:12–22. | Intervention not primary care feasible/referable
Manios Y, Moschandreas J, Hatzis C, Kafatos A. Evaluation of a health and nutrition education program in primary school children of Crete over a three-year period. Prev Med. 1999;28:149–159. | Relevance
McLean N, Griffin S, Toney K, Hardeman W. Family involvement in weight control, weight maintenance and weight-loss interventions: a systematic review of randomised trials (Provisional record). SO: International Journal of Obesity. 2003;27:987–1005. | Design
Meyer AA, Kundt G, Lenschow U, Schuff-Werner P, Kienast W. Improvement of early vascular changes and cardiovascular risk factors in obese children after a six-month exercise program. Journal of the American College of Cardiology 48 (9):1865 –70. 2006. | Did not meet quality criteria
Miraglia del GE, Santoro N, Marotta A, Nobili B, Di TR, Perrone L. Inadequate leptin level negatively affects body fat loss during a weight reduction programme for childhood obesity. Acta Paediatr. 2002;91:132–135. | Study design
Moore, Brie A. and O’Donohue, William T. Physchilogical Approaches to Disease Management. 225–270. 2005. | Design
Moreno LA. Interventions to improve cardiovascular risk factors in obese children. Journal of Pediatric Gastroenterology & Nutrition 43(4):433 –5. 2006. | Design
Mo-suwan L, Pongprapai S, Junjana C, Puetpaiboon A. Effects of a controlled trial of a school-based exercise program on the obesity indexes of preschool children. Am J Clin Nutr. 1998;68:1006–1011. | Setting
Muller MJ, Asbeck I, Mast M, Langnase K, Grund A. Prevention of obesity--more than an intention. Concept and first results of the Kiel Obesity Prevention Study (KOPS). Int J Obes Relat Metab Disord 25 Suppl 1:S66–S74, 2001. | Prevention trial
Nemet D, Berger-Shemesh E, Wolach B, Eliakim A. A combined dietary-physical activity intervention affects bone strength in obese children and adolescents. International Journal of Sports Medicine 27(8):666 –71. 2006. | Design
Nova E, Varela P, Lopez-Vidriero I, Toro O, Cena MJ, Casas J, Marcos A. A one-year follow-up study in anorexia nervosa. Dietary pattern and anthropometrical evolution. Eur J Clin Nutr 55 (7):547–554, 2001. | Population
Nowicka P, Pietrobelli A, Flodmark CE. Low-intensity family therapy intervention is useful in a clinical setting to treat obese and extremely obese children. International Journal of Pediatric Obesity. 2007;2:211–217. | Study design
Nuutinen O, Knip M. Long-term weight control in obese children: persistence of treatment outcome and metabolic changes. Int J Obes Relat Metab Disord. 1992;16:279–287. | Relevance
O’Dea JA, Abraham S. Improving the body image, eating attitudes, and behaviors of young male and female adolescents: a new educational approach that focuses on self-esteem. Int J Eat Disord. 2000;28:43–57. | Relevance
Obarzanek E, Kimm SYS, Barton BA et al. Long-Term Safety and Efficacy of a Cholesterol-Lowering Diet in Children With Elevated Low-Density Lipoprotein Cholesterol: Seven-Year Results of the Dietary Intervention Study in Children (DISC). Pediatrics. 2001;107:256–264. | Quality
Owens S, Gutin B, Allison J et al. Effect of physical training on total and visceral fat in obese children. Med Sci Sports Exerc. 1999;31:143–148. | Design
Paineau DL, Beaufils F, Boulier A et al. Family dietary coaching to improve nutritional intakes and body weight control: a randomized controlled trial. Archives of pediatrics & adolescent medicine. 2008;162:34–43. | Prevention only
Patrick K, Calfas KJ, Norman GJ et al. Randomized controlled trial of a primary care and home-based intervention for physical activity and nutrition behaviors: PACE+ for adolescents. SO: Archives of pediatrics & adolescent medicine. 2006;160:128–136. | Relevance
Peterson KE, Fox MK. Addressing the epidemic of childhood obesity through school-based interventions: what has been done and where do we go from here? Journal of Law, Medicine & Ethics 35(1):113–30. 2007. | Design
Poland BD. Learning to ‘walk our talk’: the implications of sociological theory for research methodologies in health promotion. Can J Public Health. 1992;83 Suppl 1:S31–S46. | Relevance
Ray R, Lim LH, Ling SL. Obesity in preschool children: an intervention programme in primary health care in Singapore. Ann Acad Med Singapore 23 (3):335–341, 1994. | Design
Reinehr T, Kersting M, Alexy U, Andler W. Long-term follow-up of overweight children: after training, after a single consultation session, and without treatment. J Pediatr Gastroenterol Nutr 37 (1):72–74, 2003. | Did not meet quality criteria
Reinehr T, de SG, Wabitsch M. Changes of cardiovascular risk factors in obese children effects of inpatient and outpatient intervention. Journal of Pediatric Gastroenterology & Nutrition 43(4):506–11. 2006. | Information provided in another publication
Reinehr T, de SG, Andler W. Hyperthyrotropinemia in obese children is reversible after weight loss and is not related to lipids. Journal of Clinical Endocrinology & Metabolism 91(8):3088 –91. 2006. | Study design
Resnicow K, Davis R, Rollnick S. Motivational interviewing for pediatric obesity: Conceptual issues and evidence review. Journal of the American Dietetic Association 106(12):2024–33. 2006. | Design
Resnicow K, Yaroch AL, Davis A et al. GO GIRLS!: results from a nutrition and physical activity program for low-income, overweight African American adolescent females. Health Educ Behav. 2000;27:616–631. | Design
Reybrouck T, Vinckx J, Van den BG, Vanderschueren-Lodeweyckx M. Exercise therapy and hypocaloric diet in the treatment of obese children and adolescents. Acta Paediatr Scand. 1990;79:84–89. | Did not meet quality criteria
Reybrouck T, Weymans M, Vinckx J, Stijns H, Vanderschueren- Lodeweyckx M. Cardiorespiratory function during exercise in obese children. Acta Paediatr Scand. 1987;76:342–348. kq1e7 | Did not meet quality criteria
Robbins LB, Gretebeck KA, Kazanis AS, Pender NJ. Girls on the move program to increase physical activity participation. Nursing Research 55(3):206 –16. 2006;-Jun. | Design
Robinson TN. Reducing children’s television viewing to prevent obesity: a randomized controlled trial. JAMA. 1999;282:1561–1567. | Relevance
Rocchini AP, Katch V, Anderson J et al. Blood pressure in obese adolescents: effect of weight loss. Am J Clin Nutr. 1988;82:16–23. | Design
Rocchini AP, Katch V, Schork A, Kelch RP. Insulin and blood pressure during weight loss in obese adolescents. Hypertension. 1987;10:267–273. | Design
Rodearmel SJ, Wyatt HR, Barry MJ et al. A family-based approach to preventing excessive weight gain. Obesity 14(8):1392 –401. 2006. | Design
Rolland-Cachera MF, Thibault H, Souberbielle JC, et al. Massive obesity in adolescents: dietary interventions and behaviours associated with weight regain at 2 y follow-up. Int J Obes Relat Metab Disord 28 (4):514–519, 2004. | Design
Rosenbaum M, Nonas C, Weil R et al. School-based intervention acutely improves insulin sensitivity and decreases inflammatory markers and body fatness in junior high school students. Journal of Clinical Endocrinology & Metabolism 92(2):504 –8. 2007. | Design
Salmon J, Booth ML, Phongsavan P, Murphy N, Timperio A. Promoting Physical Activity Participation among Children and Adolescents. Epidemiologic Reviews 29:144 –59. 2007. | Design
Salmon J, Ball K, Hume C, Booth M, Crawford D. Outcomes of a group-randomized trial to prevent excess weight gain, reduce screen behaviours and promote physical activity in 10-year-old children: switch-play. Int J Obes. 2008;32:601–612. | Intervention not primary care feasible/referable
Sasaki J, Shindo M, Tanaka H, Ando M, Arakawa K. A long-term aerobic exercise program decreases the obesity index and increases the high density lipoprotein cholesterol concentration in obese children. Int J Obes. 1987;11:339–345. | Design
Schwartz RP, Hamre R, Dietz WH et al. Office-based motivational interviewing to prevent childhood obesity: a feasibility study. Archives of Pediatrics & Adolescent Medicine 161(5):495 –501. 2007. | Did not meet quality criteria
Schwingshandl J, Sudi K, Eibl B, Wallner S, Borkenstein M. Effect of an individualised training programme during weight reduction on body composition: a randomised trial. Arch Dis Child. 1999;81:426–428. | Design
Shaibi GQ, Cruz ML, Ball GD et al. Effects of resistance training on insulin sensitivity in overweight Latino adolescent males. Medicine & Science in Sports & Exercise 38(7):1208 –15. 2006. | Design
Sharma M. School-based interventions for childhood and adolescent obesity. Obesity Reviews 7(3):261 –9. 2006. | Design
Shelton, D., LeGros, K., Norton, L., Stanton-Cook, S., Morgan, J., and asterman, P. Randomised controlled trial: A parent-based group education programme for overweight children. Journal of Paediatrics and Child Health 43[12], 799–805. 2007. | <6 months followup
Sherry B. Food behaviors and other strategies to prevent and treat pediatric overweight. International Journal of Obesity 29 Suppl 2:S116 – 26. 2005. | Design
Simon C, Wagner A, Platat C et al. ICAPS: a multilevel program to improve physical activity in adolescents. Diabetes & Metabolism 32(1):41–9. 2006. | Prevention only
Singh AS, Paw MJ, Brug J, van MW. Short-term effects of school-based weight gain prevention among adolescents. Archives of Pediatrics & Adolescent Medicine 161(6):565 –71. 2007. | Relevance
Snethen JA, Broome ME, Cashin SE. Effective weight loss for overweight children: a meta-analysis of intervention studies. Journal of Pediatric Nursing 21(1):45–56. 2006. | Design
Sondike SB, Copperman N, Jacobson MS. Effects of a low-carbohydrate diet on weight loss and cardiovascular risk factor in overweight adolescents. J Pediatr. 2003;142:253–258. | Design
Sothern MS, Despinasse B, Brown R, Suskind RM, Udall JN, Jr., Blecker U. Lipid profiles of obese children and adolescents before and after significant weight loss: differences according to sex. South Med J. 2000;93:278–282. | Design
Sothern MS, Hunter S, Suskind RM, Brown R, Udall JN, Jr., Blecker U. Motivating the obese child to move: the role of structured exercise in pediatric weight management. South Med J. 1999;92:577–584. | Design
Sothern MS, Loftin JM, Udall JN et al. Safety, feasibility, and efficacy of a resistance training program in preadolescent obese children. Am J Med Sci. 2000;319:370–375. | Design
Sothern MS, Schumacher H, von Almen TK, Carlisle LK, Udall JN. Committed to kids: an integrated, 4-level team approach to weight management in adolescents. J Am Diet Assoc. 2002;102:S81–S85. | Design
Sothern, Udall JN, Jr., Suskind RM, Vargas A, Blecker U. Weight loss and growth velocity in obese children after very low calorie diet, exercise, and behavior modification. Acta Paediatr. 2000;89:1036–1043. | Design
Southard DR, Southard BH. Promoting physical activity in children with MetaKenkoh. Clinical & Investigative Medicine - Medecine Clinique et Experimentale 29(5):293 –7. 2006. | Design
Speroni KG, Earley C, Atherton M. Evaluating the effectiveness of the Kids Living Fit program: a comparative study. J Sch Nurs. 2007;23:329–336. | <6 months followup
Spieth LE, Harnish JD, Lenders CM et al. A low-glycemic index diet in the treatment of pediatric obesity. Arch Pediatr Adolesc Med. 2000;154:947–951. | Design
Tanas R, Marcolongo R, Pedretti S, Gilli G. A family-based education program for obesity: a three-year study. BMC Pediatr 7 (1):33, 2007. | Design
Temple JL, Wrotniak BH, Paluch RA, Roemmich JN, Epstein LH. Relationship between sex of parent and child on weight loss and maintenance in a family-based obesity treatment program. International Journal of Obesity 30(8):1260–4. 2006. | Design
Tsiros MD, Sinn N, Brennan L et al. Cognitive behavioral therapy improves diet and body composition in overweight and obese adolescents. Am J Clin Nutr. 2008;87:1134–1140. | <6 months followup
van den Akker, Erica L. T., Puman, Patrycja J., Groen, Mieke, Timman, Reinier, Jongejan, Mieke T. M., and Trijsburg, Wim. A cognitive behavioral therapy program for overweight children. The Journal of Pediatrics 151[3], 280–283. 2007. | Study design
Viner R, Nicholls D. Managing obesity in secondary care: a personal practice. Arch Dis Child. 2005;90:385–390. | Design
Vido L, Facchin P, Antonello I, Gobber D, Rigon F. Childhood obesity treatment: double blinded trial on dietary fibres (glucomannan) versus placebo. Padiatr Padol. 1993;28:133–136. | None of our outcomes
Viski-Stalec N, Stalec J, Kati R, Podvorac D, Katovi D. The impact of dance-aerobics training on the morpho-motor status in female high-schoolers. Collegium Antropologicum 31(1):259–66. 2007. | Setting
Wadden TA, Stunkard AJ, Rich L, Rubin CJ, Sweidel G, McKinney S. Obesity in black adolescent girls: A controlled clinical trial of treatment by diet, behavior modification, and parental support 3928. Pediatrics. 1990;85:345–352. | Comparative effectiveness study
Warschburger P, Fromme C, Petermann F, Wojtalla N, Oepen J. Conceptualisation and evaluation of a cognitive-behavioural training programme for children and adolescents with obesity. Int J Obes Relat Metab Disord. 2001;25 Suppl 1:S93–S95. | Design
White MA. Mediators of weight loss in an internet-based intervention for African-American adolescent girls. Obes Res. 2004;12:1050–1059. kq1e2c; kq3e5a; kq2e2c; kq4e2c; kq5e2c | Comparative effectiveness study
Wilfley DE, Stein RI, Saelens BE et al. Efficacy of maintenance treatment approaches for childhood overweight: A randomized controlled trial. JAMA. 2007;298:1661–1673. | Study design
Williams CL, Strobino BA, Bollella M, Brotanek J. Cardiovascular risk reduction in preschool children: the “Healthy Start” project. J Am Col Nutr. 2004;23:117–123. | Relevance
Williams CL, Strobino BA, Brotanek J. Weight control among obese adolescents: A pilot study. International Journal of Food Sciences & Nutrition 58 (3):217–30. 2007. | Design
Williamson DA, Martin PD, White MA et al. Efficacy of an internet-based behavioral weight loss program for overweight adolescent African- American girls. Eating & Weight Disorders: EWD 10(3):193–203. 2005 | Comparative effectiveness study
Williamson DA, Walden HM, White MA et al. Two-year internet-based randomized controlled trial for weight loss in African-American girls. Obesity 14(7):1231–43. 2006. | Comparative effectiveness study
Wong PC, Chia MY, Tsou IY et al. Effects of a 12-week Exercise Training Programme on Aerobic Fitness, Body Composition, Blood Lipids and C-Reactive Protein in Adolescents with Obesity. Ann Acad Med Singapore. 2008;37:286–288. | Study<6 months followup
Woo J, Sea MM, Tong P et al. Effectiveness of a lifestyle modification programme in weight maintenance in obese subjects after cessation of treatment with Orlistat. J Eval Clin Pract. 2007;13:853–859. | Age
Woo KS, Chook P, Yu CW et al. Effects of diet and exercise on obesity-related vascular dysfunction in children. Circulation. 2004;109:1981–1986. | Comparative effectiveness study
Young KM, Northern JJ, Lister KM, Drummond JA, O’Brien WH. A meta-analysis of family-behavioral weight-loss treatments for children. Clinical Psychology Review 27(2):240–9. 2007. | Design
Young-Hyman D, Schlundt DG, Herman L, De LF, Counts D. Evaluation of the insulin resistance syndrome in 5- to 10-year-old overweight/obese African-American children. Diabetes Care. 2001;24:1359–1364. | Relevance
Zemel MB, Richards J, Mathis S, Milstead A, Gebhardt L, Silva E. Dairy augmentation of total and central fat loss in obese subjects. International Journal of Obesity 29(4):391–7. 2005. | Relevance
Pharmacological interventions
Appolinario JC, Bacaltchuk J, Sichieri R et al. A randomized, double-blind, placebo-controlled study of sibutramine in the treatment of binge-eating disorder. Archives of General Psychiatry 60(11):1109–16. 2003. | Population
Bauer C, Fischer A, Keller U. Effect of sibutramine and of cognitive-behavioural weight loss therapy in obesity and subclinical binge eating disorder. Diabetes, Obesity & Metabolism 8(3):289–95. 2006. | Design
Birkenfeld AL, Schroeder C, Pischon T et al. Paradoxical effect of sibutramine on autonomic cardiovascular regulation in obese hypertensive patients--sibutramine and blood pressure. Clinical Autonomic Research 15(3):200–6. 2005. | Population
Cuellar GE, Ruiz AM, Monsalve MC, Berber A. Six-month treatment of obesity with sibutramine 15 mg; a double-blind, placebo-controlled monocenter clinical trial in a Hispanic population. Obes Res. 2000;8:71–82. | Population
Curran MP, Scott LJ. Orlistat: a review of its use in the management of patients with obesity. Drugs 64(24):2845–64. 2004. | Design
Danielsson P, Janson A, Norgren S, Marcus C. Impact sibutramine therapy in children with hypothalamic obesity or obesity with aggravating syndromes. J Clin Endocrinol Metab. 2007. | Population
Dastjerdi, M. Siavash, Kazemi, F., Najafian, A., Mohammady, M., Aminorroaya, A., and Amini, M. An open-label pilot study of the combination therapy of metformin and fluoxetine for weight reduction. International Journal of Obesity 31[4], 713–717. 2007. | Population
Erdmann J, Lippl F, Klose G, Schusdziarra V. Cholesterol lowering effect of dietary weight loss and orlistat treatment--efficacy and limitations. Alimentary Pharmacology & Therapeutics. 2004;1173–1179. | Population
Fanghanel G, Cortinas L, Sanchez-Reyes L, Berber A. A clinical trial of the use of sibutramine for the treatment of patients suffering essential obesity. Int J Obes Relat Metab Disord. 2000;24:144–150. | Population
Freemark M. Pharmacotherapy of childhood obesity: an evidence-based, conceptual approach. Diabetes Care. 2007;30:395–402. | Design
Gilliam FG, Veloso F, Bomhof MA et al. A dose-comparison trial of topiramate as monotherapy in recently diagnosed partial epilepsy. Neurology 60(2):196–202. 2003. | Relevance
Gottschalk M, Danne T, Vlajnic A, Cara JF. Glimepiride versus metformin as monotherapy in pediatric patients with type 2 diabetes: a randomized, single-blind comparative study. Diabetes Care 30(4):790–4. 2007. | Comparative effectiveness study
Greenway FL, De JL, Blanchard D, Frisard M, Smith SR. Effect of a dietary herbal supplement containing caffeine and ephedra on weight, metabolic rate, and body composition. Obesity Research 12(7):1152–7. 2004. | Population
Guimaraes C, Pereira LR, Iucif JN et al. Tolerability and effectiveness of fluoxetine, metformin and sibutramine in reducing anthropometric and metabolic parameters in obese patients. Arq Bras Endocrinol Metabol. 2006;50:1020–1025. | Age
Hamilton J, Cummings E, Zdravkovic V, Finegood D, Daneman D. Metformin as an adjunct therapy in adolescents with type 1 diabetes and insulin resistance: a randomized controlled trial. Diabetes Care 26(1):138–43. 2003. | Population
Henness S, Perry CM. Orlistat: a review of its use in the management of obesity. Drugs 66(12):1625–56. 2006. | Design
Ioannides-Demos LL, Proietto J, Tonkin AM, McNeil JJ. Safety of drug therapies used for weight loss and treatment of obesity. Drug Safety 29(4):277–302. 2006. | Design
James WP, Astrup A, Finer N et al. Effect of sibutramine on weight maintenance after weight loss: a randomised trial. STORM Study Group. Sibutramine Trial of Obesity Reduction and Maintenance. Lancet. 2000;356:2119–2125. | Population
Jordan J, Scholze J, Matiba B, Wirth A, Hauner H, Sharma AM. Influence of Sibutramine on blood pressure: evidence from placebo-controlled trials. International Journal of Obesity 29(5):509–16. 2005. | Population
Junior AC, Savassi-Rocha PR, Coelho LG et al. Botulinum A toxin injected into the gastric wall for the treatment of class III obesity: a pilot study. Obesity Surgery 16(3):335–43. 2006. | Population
Kay JP, Alemzadeh R, Langley G, D’Angelo L, Smith P, Holshouser S. Beneficial effects of metformin in normoglycemic morbidly obese adolescents. Metabolism. 2001;50:1457–1461. | Did not meet quality criteria
Larsen TM, Toubro S, Gudmundsen O, Astrup A. Conjugated linoleic acid supplementation for 1 y does not prevent weight or body fat regain. American Journal of Clinical Nutrition 83 (3):606–12. 2006. | Population
Li Z, Maglione M, Tu W et al. Meta-analysis: pharmacologic treatment of obesity. Ann Intern Med. 2005;142:532–546. | Population
McDuffie JR, Calis KA, Booth SL, Uwaifo GI, Yanovski JA. Effects of orlistat on fat-soluble vitamins in obese adolescents. Pharmacotherapy. 2002;22:814–822. | Design
McDuffie JR, Calis KA, Uwaifo GI et al. Efficacy of orlistat as an adjunct to behavioral treatment in overweight African American and Caucasian adolescents with obesity-related co-morbid conditions. Journal of Pediatric Endocrinology 17(3):307–19. 2004. | Design
McDuffie JR, Calis KA, Uwaifo GI et al. Three-month tolerability of orlistat in adolescents with obesity-related comorbid conditions. Obes Res. 2002;10:642–650. | Design
McElroy SL, Shapira NA, Arnold LM et al. Topiramate in the long-term treatment of binge-eating disorder associated with obesity. Journal of Clinical Psychiatry 65(11):1463–9. 2004. | Population
Norgren S, Danielsson P, Jurold R, Lotborn M, Marcus C. Orlistat treatment in obese prepubertal children: a pilot study. Acta Paediatrica 92(6):666–70. 2003. | Design
Ozkan B, Bereket A, Turan S, Keskin S. Addition of orlistat to conventional treatment in adolescents with severe obesity. Eur.J.Pediatr. 163 (12):738–741, 2004 | Design
Reith D, Burke C, Appleton DB, Wallace G, Pelekanos J. Tolerability of topiramate in children and adolescents. Journal of Paediatrics & Child Health 39(6):416–9. 2003. | Relevance
Reisler G, Tauber T, Afriat R, Bortnik O, Goldman M. Sibutramine as an adjuvant therapy in adolescents suffering from morbid obesity. Isr.Med Assoc J 8 (1):30–32, 2006. | Design
Scheen AJ, Finer N, Hollander P, Jensen MD, Van Gaal LF, and RIO-Diabetes Study Group. Efficacy and tolerability of rimonabant in overweight or obese patients with type 2 diabetes: a randomised controlled study. Lancet.368.(9548.):1660–72, 2006. | Population
Summaries for patients. Effects of drug treatment for obesity in adolescence.[original report in Ann Intern Med. 2006 Jul 18;145(2):81–90; PMID: 16847290]. Annals of Internal Medicine 145 (2):I16. 2006. | Design
Zhi J, Moore R, Kanitra L. The effect of short-term (21-day) orlistat treatment on the physiologic balance of six selected macrominerals and microminerals in obese adolescents. Journal of the American College of Nutrition 22(5):357–62. 2003. | Not relevant outcomes
Zilberstein B, Pajecki D, Garcia de Brito AC, Gallafrio ST, Eshkenazy R, Andrade CG. Topiramate after adjustable gastric banding in patients with binge eating and difficulty losing weight. Obesity Surgery 14(6):802–5. 2004;-Jul. | Population