# Detailed Methods

## Key Questions and Analytic Framework

Using the methods of the USPSTF,70 we developed three key questions (KQ) (with six sub-key questions) and an analytic frame work (Figure 3) in conjunction with members of the USPSTF to update its 2005 recommendation on Screening for Childhood Overweight and Obesity2. These KQs were designed to evaluate the effectiveness and safety of behavioral and pharmacological treatments for overweight and/or obese children. Each KQ focused on a different area of the evidence. KQ1 evaluates the effectiveness of interventions in reducing or stabilizing weight using short-term (6–12 months since enrolling in treatment), while KQ2 focuses on the maintenance of BMI improvements through medium-term (between 1 to 5 years since enrollment and at least 12 months since treatment ended). KQ3 assesses adverse effects of behavioral and pharmacological interventions. KQ1a and KQ2a consider other beneficial outcomes arising from the interventions. KQ1b, KQ2b, KQ1c, and KQ2c consider whether specific program components and population or environmental factors can be identified for short-or longer-term effective weight management programs.

## Literature Search Strategy

We searched for systematic reviews in Ovid MEDLINE®, PsycINFO, Database of Abstracts of Reviews of Effects (DARE), the Cochrane Database of Systematic Reviews (CDSR), Cochrane Central Register of Controlled Trials (CCRCT), and Education Resources Information Center (ERIC) 2004 to 2007. We selected relevant, good quality systematic reviews where available to assist in conducting our literature search. Quality criteria were based on USPSTF methods,70 supplemented by NICE methodology9(see Appendix A Table 3). A 2006 comprehensive NICE report was based on a series of systematic reviews and addressed the prevention and management of obesity in adults and children.9 Relevant portions of this report served as a basis for the primary search for the literature included in the current report. The NICE report only included orlistat and sibutramine. Therefore, we used another good-quality review of pharmacological treatments54 as the basis for our search for pharmacological treatments. We conducted update searches in Ovid MEDLINE®, PsycINFO, Database of Abstracts of Reviews of Effects, the Cochrane Database of Systematic Reviews, Cochrane Central Register of Controlled Trials, and Education Resources Information Center from 2005 (2003 for pharmacological treatments) to June 10, 2008, to identify literature that was published after the search dates of these reports (Appendix A Table 1). The literature search and reports9,54 were supplemented by hand-searching the reference lists of other good-quality reviews of childhood obesity treatment,2,7,117–119 suggestions from experts, and reviewing reference lists of included trials. We did not search for data from non-peer-reviewed sources.

Appendix A Table 3 Quality rating criteria

Design | U.S. Preventive Services Task Force quality rating criteria70 | National Institute for Health and Clinical Excellence methodology checklists132
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - The study addresses an appropriate and clearly focused question; - A description of the methodology used is included; - The literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - The study addresses an appropriate and clearly focused question; - The cases and controls are taken from comparable populations; - The same exclusion criteria are used for both cases and controls; - What percentage of each group (cases and controls) participated in the study?; - Comparison is made between participants and non-participants to establish their similarities or differences; - Cases are clearly defined and differentiated from controls; - Is it clearly established that controls are non-cases?; - Measures have been taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid and reliable way; - The main potential confounders are identified and taken into account in the design and analysis; - Have confidence intervals been provided?
Randomized controlled trials (RCTs) | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The assignment of subjects to treatment groups is randomized; - An adequate concealment method is used; - Subjects and investigators are kept ‘blind’ about treatment allocation; - The treatment and control groups are similar at the start of the trial; - The only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid and reliable way; - What percentage of the individuals or clusters recruited into each treatment arm of the study dropped out before the study was completed?; - All the subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - Where the study is carried out at more than one site, results are comparable for all sites
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - The study indicates how many of the people asked to take part did so, in each of the groups being studied; - The likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - What percentage of individuals or clusters recruited into each arm of the study dropped out before the study was completed?; - Comparison is made between full participants and those lost to follow-up, by exposure status; - The outcomes are clearly defined; - The assessment of outcome is made blind to exposure status; - Where blinding was not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - The measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - The main potential confounders are identified and taken into account in the design and analysis; - Have confidence intervals been provided?
Diagnostic accuracy studies | - Screening test relevant, available for primary care, adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate result in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test | - The nature of the test being studied is clearly specified; - The test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - The test and gold standard are measured independently (blind) of each other; - The test and gold standard are applied as close together in time as possible; - Results are reported for all patients that are entered into the study; - A pre-diagnosis is made and reported

Hierarchy of research design

I Properly conducted randomized controlled trial (RCT)

II-1: Well-designed controlled trial without randomization

II-2: Well-designed cohort or case-control analytic study

II-3: Multiple time series with or without the intervention; dramatic results from uncontrolled experiments

III: Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees

Appendix A Table 1 Exact search string

Database: MEDLINE, Database of Abstracts of Reviews of Effectiveness, Education Resource Information Center, Cochrane Central Register of Controlled Trials, Cochrane Database of Systematic Reviews, NICE, PsycInfo <2003 to June 2008>
Search Strategy:
1 | exp “Obesity”/
2 | “Weight-Gain”/
3 | “Weight-Loss”/
4 | (obesity or obese).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
5 | (weight gain or weight loss).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
6 | (overweight or over weight or overeat$ or over eat$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
7 | weight change$.mp.
8 | ((bmi or body mass index) adj2 (gain or loss or change)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
9 | weight maintenance.mp.
10 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11 | limit 10 to child <6 to 12 years>
12 | limit 10 to adolescent <13 to 18 years>
13 | limit 10 to preschool child <2 to 5 years>
14 | (child$ or adolescen$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
15 | (teenage$ or young people or young person or young adult$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
16 | (schoolchildren or school children).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
17 | (pediatr$ or paediatr$).ti,ab.
18 | (boys or girls or youth or youths).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
19 | 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18
20 | exp “Behavior-Therapy”/
21 | Social Support/
22 | Family-Therapy/
23 | exp “Psychotherapy-Group”/
24 | ((psychological or behavio?r$) adj (therapy or modif$ or strateg$ or intervention$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
25 | (group therapy or family therapy or cognitive therapy).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
26 | ((lifestyle or life style) adj (chang$ or intervention$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
27 | counsel?ing.mp.
28 | social support.mp.
29 | (peer adj2 support).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
30 | ((children adj3 parent$) and therapy).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
31 | 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30
32 | exp OBESITY/dt [Drug Therapy]
33 | exp Anti-Obesity Agents/
34 | lipase inhibitor$.mp.
35 | (orlistat or xenical or tetrahydrolipstatin).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
36 | (appetite adj (suppressant$ or depressant$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
37 | sibutramine.mp. or meridia.ti,ab. [mp=title, original title, abstract, name of substance word, subject heading word]
38 | (dexfenfluramine or fenfluramine or phentermine).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
39 | bulking agent$.mp.
40 | (methylcellulose or celevac).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
41 | ((antiobesity or anti obesity) adj (drug$ or agent$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
42 | guar gum.mp.
43 | (metformin or glucophage).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
44 | (fluoxetine or prozac).mp.
45 | (Sertraline or zoloft).mp.
46 | Diethylpropion.mp.
47 | zonisamide.mp.
48 | topiramate.mp.
49 | (Octreotide or somatostatin or sandostatin).mp.
50 | (Amantadine or symmetrel).mp.
51 | (Glucagon-Like Peptide 1 or glp-1).mp.
52 | (rimonabant or acomplia).mp.
53 | (SLV 319 or SLV319).mp.
54 | exenatide.mp.
55 | liraglutide.mp.
56 | vildagliptin.mp.
57 | sitagliptin.mp.
58 | (qnexa or contrave or excalia).mp.
59 | exp OBESITY/dh [Diet Therapy]
60 | “Diet-Fat-Restricted”/
61 | “Diet-Reducing”/
62 | “Diet-Therapy”/
63 | “Fasting”/
64 | (diet or diets or dieting).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
65 | (diet$ adj (modif$ or therapy or intervention$ or strateg$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
66 | (low calorie or calorie control$ or healthy eating).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
67 | (fasting or modified fast$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
68 | exp “Dietary-Fats”/
69 | (fruit or vegetable$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
70 | (high fat$ or low fat$ or fatty food$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
71 | formula diet$.mp.
72 | 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71
73 | “Exercise”/
74 | “Exercise-Therapy”/
75 | exercis$.mp.
76 | (aerobics or physical therapy or physical activity or physical inactivity).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
77 | (fitness adj (class$ or regime$ or program$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
78 | (physical training or physical education).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
79 | dance therapy.mp.
80 | sedentary behavio?r reduction.mp.
81 | 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80
82 | exp OBESITY/su [Surgery]
83 | “Surgical-Staplers”/
84 | “Surgical-Stapling”/
85 | “Lipectomy”/
86 | “Gastric-Bypass”/
87 | “Gastroplasty”/
88 | (dental splinting or jaw wiring).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
89 | (gastroplasty or gastric band$ or gastric bypass).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
90 | (intragastric balloon$ or vertical band$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
91 | (stomach adj (stapl$ or band$ or bypass)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
92 | biliopancreatic diversion$.mp.
93 | liposuction.mp.
94 | 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93
95 | exp “Alternative-Medicine”/
96 | (alternative medicine or complementary therap$ or complementary medicine).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
97 | (hypnotism or hypnosis or hypnotherapy).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
98 | (acupuncture or homeopathy).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
99 | (chinese medicine or indian medicine or herbal medicine or ayurvedic).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
100 | 95 or 96 or 97 or 98 or 99
101 | ((diet or dieting or slim$) adj (club$ or organi?ation$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
102 | (weightwatcheR$ or weight watcher$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
103 | (correspondence adj (course$ or program$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
104 | (fat camp$ or diet$ camp$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
105 | 101 or 102 or 103 or 104
106 | (family intervention$ or parent$ intervention$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
107 | (parent$ adj2 (behavio?r or involve$ or control$ or attitude$ or educat$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
108 | 106 or 107
109 | (systematic$ review$ or systematic$ overview$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
110 | (quantitative$ review$ or quantitative$ overview$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
111 | Evidence-Based Medicine/
112 | evidence based review$.mp.
113 | exp “Controlled-Clinical-Trials”/
114 | exp “Research-Design”/
115 | ((singl$ or doubl$ or trebl$ or tripl$) adj5 (blind$ or mask$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
116 | (CONTROLLED-CLINICAL-TRIAL or RANDOMIZED CONTROLLED TRIAL or META-ANALYSIS).pt.
117 | (control$ and (trial$ or stud$ or evaluation$ or experiment$)).ti,ab.
118 | (comparison group$ or control group$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
119 | random$.ti,ab.
120 | matched pairs.mp.
121 | (outcome study or outcome studies).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
122 | (quasiexperimental or quasi experimental or pseudo experimental).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
123 | (nonrandomi?ed or non randomi?ed or pseudo randomi?ed).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
124 | cohort studies/
125 | (cohort adj (study or studies)).ti,ab.
126 | cohort analys$.ti,ab.
127 | case series.ti,ab.
128 | longitudinal studies/
129 | longitudinal$.ti,ab.
130 | follow-up studies/
131 | (follow up adj (study or studies)).ti,ab.
132 | prospective studies/
133 | prospective$.ti,ab.
134 | 109 or 110 or 111 or 112 or 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125 or 126 or 127 or 128 or 129 or 130 or 131 or 132 or 133
135 | 10 and 19
136 | 32 or 33 or 34 or 36 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58
137 | 134 and 135 and 136
138 | limit 137 to yr=“2003–2007”
139 | 31 or 35 or 37 or 72 or 81 or 94 or 100 or 105 or 108
140 | 134 and 135 and 139
141 | limit 140 to yr=“2005–2007”
142 | 138 or 141
143 | limit 142 to animals
144 | limit 142 to humans
145 | 143 not 144
146 | 142 not 145
147 | limit 146 to english language

## Article Review and Data Abstraction

Two investigators independently reviewed 2786 abstracts and 369 articles. Every abstract was considered for inclusion in each key question. Discrepancies were resolved by consensus. Detailed inclusion/exclusion criteria can be found in Appendix A Table 2. Briefly, the study population included overweight or obese 2 to 18 year-olds. We excluded studies of children with idiosyncratic weight management issues due to behavioral, cognitive, or medical factors. Trials were required to be designed to promote weight loss or maintenance and report weight outcomes of at least 6 months, although we included immediate harms when these were also reported. Interventions using mazindol were excluded because it is no longer used in current practice. Trials were required to have a minimal intervention or control group and randomize at least 10 participants in each arm. Only controlled trials (RCTs and CCTs) were included for efficacy (short-term and maintenance) of behavioral and pharmacological treatments. Weight management programs reporting pre-specified adverse events resulting in death, hospitalization, or need for urgent medical or psychiatric treatment were included to assess harms (KQ3) for all treatment modalities, even if they did not report one of our specified weight outcomes or did not meet the minimum 6-month followup required for the other key questions. In addition, we abstracted all reports of harms or potential harms in included studies.

Appendix A Table 2 Study eligibility criteria

1. Populations. The following apply to all Key Questions:; a. Age 2–18. If study substantially overlaps our age range (e.g., 14–65), include article if results for younger participants reported separately. For study of “young adult” or “college-aged”, exclude unless average age is <19 or “college freshmen” is specified.; b. Either (a) entire sample is overweight or obese (85^th^ percentile for age and sex-specific BMI, or who meet previously accepted criteria for overweight based on ideal body weight) or (b) ≥50% of the sample are overweight or obese AND ≥80% of the sample have one of the following risk factors for overweight or obesity-related medical problems: Children of overweight parents; Hispanic, Black, or American Indian/Alaska Native; children with the following medical conditions: diabetes, metabolic syndrome, hypertension, lipid abnormalities, or other cardiovascular-related disorders.; c. Primary care population or comparable.; d. Exclude trials in which the sample is limited to youth: (1) with eating disorders, (2) pregnant/post-partum, (3) overweight/obesity secondary to genetic or medical condition, including Polycystic ovarian syndrome, hypothyroid, Cushings, GH deficiency, insulinoma, hypothalamic disorders (e.g. Froehlich’s syndrome), Laurence-Moon-Biedl syndrome, Prader-Willi syndrome, weight gain secondary to medications (e.g., antipsychotics), or (4) other idiosyncratic weight-loss issues.; 2. Study Design.; a. All studies for KQ1 and KQ2 (including sub-KQ) must have an outcomes assessment at 6 months or later post-baseline. No minimum follow-up is required for serious (i.e., requiring urgent medical care) adverse events, KQ3.; b. Behavioral interventions: limit to RCT or CCT with minimal intervention or placebo control, with a minimum of 10 subjects per treatment arm; c. Pharmacological interventions: RCT with placebo pill control, with a minimum of 10 subjects per treatment arm; 3. Setting.; a. For Behavioral interventions: all KQ except serious (i.e., requiring urgent medical care) adverse effects (KQ3): limit to countries listed as “high” human development on Human Development Index (over .90): Australia, Austria, Belgium, Canada, Denmark, Finland, France, Germany, Greece, Hong Kong, Iceland, Ireland, Israel, Italy, Japan, Korea, Luxembourg, Netherlands, New Zealand, Norway, Portugal, Singapore, Slovenia, Spain, Sweden, Switzerland, United Kingdom, United States.; b. Excluded trials in settings not feasible for implementation in primary care or health care systems to which primary care providers could refer, such as schools and inpatient settings.; 4. Intervention.; a. Include behavioral (published ≥1985), pharmacological, complimentary/alternative, or health care system interventions, singly or combined, designed to promote weight control/loss or weight maintenance, or an important components of weight loss (e.g., physical activity).; b. Intevention must be either conducted in primary care, feasible for conduct in primary care, or comparable to programs widely available for referral from primary care. We also accepted programs that would be feasible for implementation in a health care system and therefore could be available for referral from primary care, if available.; c. Exclude trials in which intervention focuses primary prevention, changes in the build environment, mazindol.; 5. Outcomes.; a. KQ1 and KQ2 (and sub-KQs): Must provide acceptable adiposity outcome (2-C, 3-C or 4-C models, except 2-C models not using Lohman’s age and sex-specific equation or using the measurement of total bady fat K+) or weight outcome (e.g., baseline and post-intervention weight, weight change, net weight change over control group, or a related measures (such as BMI, BMI SDS, etc.); b. KQ3: All potential harms reported in KQ1 & KQ2 trials will be included. For trials that are not included for KQ1 or KQ2, outcomes are limited to serious adverse events, such as death, need for medical or psychiatric treatment, or growth retardation

We limited our consideration of behavioral interventions to those published in or after 1985. We did this because the dramatic increases in overweight in children that occurred during the 1980s and 1990s and changes in environmental and social factors related to weight gain, such as types and quantities of food readily available to children (e.g., fast food purveyors in school cafeterias, vending machines with soft drinks and candy widely available in schools) and the increased availability of sedentary activities in the home (such as computers, home DVD/video players, and video games) made the generalizability of studies to the current environment questionable.

We only examined other beneficial outcomes (KQ1a & KQ2a), important components of care (KQ1b & KQ2b) and population or environmental factors (KQ1c & KQ3c) using trials that were included for KQ1 (short-term efficacy) or KQ2 (maintenance efficacy). When reported, we abstracted data on beneficial outcomes, including impact on co-morbidities.

We used a two-step process to determine which specific intervention components we examined for KQ1b and KQ2b. First, we examined prior literature and identified several factors that may affect weight outcomes in behavioral interventions. These include whether or not studies included organized physical activity sessions,73 behavioral management techniques2,10 (for dietary and physical activity), or involved parents or families in addition to the child (clarifying extent to which parental involvement is important, for what ages).10,74,119 Second, we examined the distribution of treatment elements between successful and unsuccessful treatment trials. To do this, we coded the age of the participants (C=Children only (only included children aged 12 and under); A=Adolescents only (only included those aged 10 and older); B=Both age groups (age range included both younger children and adolescents)). We coded the three main components of behavioral interventions as follows: (1) presence of organized physical activity sessions (0=did not provide organized physical activity session, 1=provided organized physical activity); (2) used of behavioral modification principles (0=no or minimal use of behavioral modification principles,1=applied behavioral modification principles in treatment); (3) family involvement (0=no parental involvement beyond consent/receiving materials; 1=parent attended 1 to 3 sessions, less intensive involvement than child; 2=parent was also a primary recipient of treatment).

One investigator abstracted data from included studies into evidence tables. A second investigator verified the evidence tables’ content. Two investigators independently quality rated all studies using established design-specific criteria (Appendix A Table 3). Discrepancies were resolved by consensus or consultation with a third investigator. Poor-quality studies were excluded. Eight trials of behavioral interventions120–127 and one of pharmacological treatment128 were excluded because they did not meet our quality criteria.

Treatment intensity was categorized by hours of contact as follows: very low intensity (less than 10 hours); low (10 to 25 hours); medium (26 to 75 hours), high (over 75 hours). Thus, at the least, a high-intensity program would amount to twice-weekly hour-long meetings for 6 months and once-weekly hour-long meetings for the next 6 months, assuming no more than 2 sessions are missed. The lowest end of the medium intensity range would involve weekly hour-long meetings for 6 months. Weight outcomes were categorized as short-term (6 to 12 months since beginning treatment) or medium-term (between 1 and 4 years after beginning treatment and at least 12 months after ending active treatment). The longest followup reported in any of the included trials was 4 years. Maintenance was evaluated where possible using multiple measurements in the same individuals at least 12 months after an active intervention ended, or by using single post-baseline-measurements in the medium term. Weight outcomes were abstracted as reported, and included many different measures: endpoint BMI, absolute change in BMI from baseline, percent change in BMI from baseline, absolute change in BMI SDS from baseline, endpoint weight, and absolute change in weight from baseline.

In addition, we evaluated whether or not a treatment was comprehensive. Interventions were considered comprehensive if they included all of the following elements: (1) counseling for weight loss or healthy diet, (2) counseling for physical activity or a physical activity program, and (3) instruction in and support for the use of behavioral management techniques to help make and sustain changes in diet and physical activity were considered comprehensive. An intervention was considered to use behavioral management techniques if any of the following elements were described: self-monitoring (having the child document diet-related behaviors or physical activity), stimulus control (modifying factors that appear to serve as cues leading to inappropriate eating, such as while watching television); eating management (techniques specifically aimed at modifying the act of eating, such as eating slowly); contingency management (contingency contracting, where rewards are given for desired eating or exercise behaviors, weight loss, or treatment adherence); cognitive-behavioral techniques (the attempt to alter maladaptive cognitions related to health behaviors, or use cognitive approaches to enhance behavior change, such as problem-solving to cope with high-risk situations).

## Literature Synthesis

This review included studies of both behavioral interventions and pharmacological agents. We address each type of intervention for each of the six key questions listed in our analytic framework. We discuss each pharmacological agent as a separate intervention.

Where possible, data were synthesized using quantitative methods. For most questions, however, we relied on qualitative synthesis due to significant heterogeneity in setting, age range, intervention approach, weight outcome reported, and timing of outcome reporting among the limited number of studies available for each overall type of intervention. We modeled typical cases to more clearly articulate the magnitude of weight or weight change in pounds. In these cases, we used growth charts published by the Centers for Disease Control and Prevention (CDC)14 to estimate average height for age and to translate between percentile scores, BMI, and percent overweight (based on CDC-published 50^th^ percentile scores for weight or BMI). We also employed on-line calculators provided at the CDC web site75,76 for calculating BMI and BMI percentiles. We used the following formula to convert BMI to pounds for an illustrative child of a given age and height: Pounds = (BMI*inches2)/703.

Studies reported a variety of weight outcomes including BMI, BMI percentile scores, BMI standard deviation or z-scores, and percent overweight. All of these measures have strengths and limitations. While BMI is reliably measured and widely used, it can be problematic when averaging BMI change over a wide age range where younger children would naturally show smaller changes. Percentile scores are helpful when describing weight change in children of many ages because they are a measure of relative overweight, rather than absolute weight. The limitation of percentile scores, however, is that there can be a large range in the highest extremes (above the 99^th^ percentile).

To avoid the difficulties with an limited upper range of BMI percentile scores, many researchers report BMI standard deviation scores (SDS, also known as z-scores) or measures of “percent overweight.” Both of these are measures of the relative degree of overweight similar to percentile scores, but without a truncated upper limit. BMI SDS is calculated as the number of standard deviation units above or below the median, based on statistically derived curves.129 BMI SDS requires the use of published computer programs that access reference data and formulae, such as that published by the CDC130 Percent overweight is calculated by the simple formula:

100^*^ ( child ’ s BMI / 50^th^ percentile BMI for child ’ s age and sex ) .

This method was used chiefly in earlier studies, published before computer programs were available to calculated BMI SDS. The disadvantage of using percent overweight scores is that they do not account for the known weight distribution.

### Quantitative Synthesis

For the behavioral interventions, we conducted meta-analyses of short-term and maintenance outcomes separately. Most trials reported weight outcomes as post-intervention BMI or changes in BMI from baseline and compared these changes between intervention and control groups. Among trials that did not report BMI or change in BMI, three trials reported weight outcomes as changes in BMI standard deviation scores (SDS),78,80,87 and one trial reported changes in percent overweight.84 Three79,80,87 of the trials that reported BMI or related measures between groups at followup statistically tested only whether shape and slope of the curves from baseline through followup were significantly different. For one of these trials87 we used 24-month outcomes as an estimate for 12-month outcomes, which were shown graphically, but did not report means and standard deviations. The 24-month outcome is a slight underestimate of the 12-month effect, and although the 24-month effect was not statistically significant cross-sectionally, we show it as being statistically significant in Table 3 and in the text descriptions since the graphical display in the article indicated non-overlapping confidence intervals at 12-month followup

We focused on the change in BMI from baseline as the preferred measure of weight change when it was available. If BMI change was unavailable and could not be calculated, we used change in BMI SDS as our second choice, and change in percent overweight as the third choice. Because we combined different outcomes, we analyzed standardized effect sizes. We also ran a meta-analysis examining only those reporting BMI change and found that that pattern of results and magnitude of effects were very similar to those seen in the primary meta-analysis that included all trials (and allowed different measures of weight change). We report the more comprehensive results in the meta-analysis including all trials.

The number of observations included in the analysis of interest to this review (as opposed to the number randomized, or the number with complete data, for example) was used as the n in the meta-analysis. If both intention-to-treat (ITT) and completers-only analyses were reported, we selected the ITT analysis for inclusion in the meta-analysis. If a trial involved two active treatment arms, the arm with a greater number of treatment hours or that was judged to be most comprehensive was selected for the meta-analysis. If outcomes were reported at multiple time points in the short-term, we chose the one closest to 12 months post-baseline. No trials reported maintenance outcomes at more than one time point for both intervention and control groups. We used random effects models because the trials varied considerably along many dimensions that would impact both baseline BMI (e.g., age, minimum overweight inclusion criteria) and change in BMI (e.g., intensity of intervention, comprehensiveness of treatment program). All meta-analyses were conducted using RevMan 4.2.

Trials were grouped according to comprehensiveness and intensity into the following categories: (1) comprehensive, medium (26–75 hours of contact) to high (76 or more hours) intensity; (2) comprehensive, low intensity (11–25 hours); (3) comprehensive, very low intensity (fewer than 10 hours); (4) focused interventions. Interventions were considered to be comprehensive if they provided dietary counseling, physical activity counseling, and employed behavior modification principles to assist with behavior change. Trials were only statistically combined within category. All trials reporting maintenance outcomes (KQ2) fell into different categories, and were therefore not statistically combined, though the forest plot is presented to facilitate comparison with across trials.

If mean change scores from baseline for each group were not reported, we calculated an unadjusted difference between the mean baseline and mean followup scores for each group using simple subtraction. Standard deviations (SDs) of the change scores were reported in five trials with post-treatment outcomes and one trial with followup outcome. In addition, two authors who did not report them in published articles provided us with these unpublished data.82,88 We calculated standard deviations for trials that did not report them. Baseline BMI is highly correlated with post-treatment and follow-up BMI, and we had to take this correlation into account when calculating the standard deviations of the change scores. In order to estimate the degree of correlation, we examined data from a recently published trial in a school setting131 that reported both the SDs of the change scores (which we were attempting to calculate) and the SDs of the baseline and post-treatment BMIs (which we would use to calculate of the SDs of the change scores). Although this trial was excluded from the current review due to setting, it used an intervention approach and population comparable to those targeted by this review. From this trial, we ascertained that the correlation between the baseline and post-treatment BMI was approximately 0.90. Therefore, we assumed a correlation of 0.90 for the remaining trials and calculated SDs of BMI change using the following formula:

SD_baseline - followup_ = sqrt ( SD^2^ baseline + SD^2^ followup - 2^*^ 0.90^*^ SD_baseline_ * SD_followup_ ) .

When given standard errors rather than standard deviations, we calculated standard deviations by multiplying the standard error by the square root of n. When given symmetric confidence limits rather than standard deviations, we determined the standard deviation using the following formula:

Std Dev = (( CI width ) ( sqrt ( n ) ))/(2^*^ ( 1.96 ))

Appendix A Figure 1 Search results and article flow

*Includes bariatric surgery articles.