# Acronyms

AE: adverse effects
B: black
BT: behavioral treatment
BIA: bio-electrical impedance analysis
BMI: body mass index
BP: blood pressure
BT: behavioral therapy
calc: calculated from given data
CI: 95% confidence interval
CDC: Center for Disease Control
CHD: coronary heart disease
CVD: cardiovascular disease
CV: cardiovascular
D: dietary
DBP: diastolic blood pressure
DEXA: dual x-ray absorptiometry
DM: diabetes mellitus, type 2
EST: estimated from given data
F: female
FC: family counseling
FFM: fat free mass
FM: fat mass
FPG: fasting plasma glucose
GP: general practitioner
H: height
HDL: high-density lipoprotein cholesterol
HOMA: homeostasis model assessment of insulin sensitivity
HMO: health maintenance organization
HR: hazards ratio
IGT: impaired glucose tolerance
ITT: intention-to-treat
Kcal: kilocalorie
Kg: kilogram
Kg/m^2^: kilograms divided by meters squared (formula for BMI)
KQ: key question
LDL: low-density lipoprotein cholesterol
LOCF: last observation carried forward
M: male
MA: Mexican American
MM: millimeters
MRI: magnetic resonance imaging
N: number
NA: not applicable
NHANES: National Health and Nutrition Examination Survey
NHB: non-Hispanic blacks
NHW: non-Hispanic whites
NIH: National Institutes of Health
NR: not reported
OGTT: Oral Glucose Tolerance Test
OR: odds ratio
OW: overweight
P: P-value
PA: physical activity
PCP: primary care provider
PT: parent training
RYGB: Roux-en-Y Gastric Bypass
SA: sedentary activity
SBP: systolic blood pressure
SD: standard deviation
SDS: standard deviation score
SE: standard error
SKF: skin fold thickness
SSF: subscapular skinfold thickness
TC: total cholesterol
TG: triglycerides
TSF: triceps skinfold
W: white
WHO: World Health Organization
WT: weight