# Reference List

1 Pignone M, Gaynes B, Rushton J, et al. Screening for depression: A systematic review. Agency for Healthcare Research and Quality. 2002.
2 American Psychiatric Association. Diagnostic and Statical Manual of Mental Disorders. Fourth ed. Washington, DC. American Psychiatric Association. 1994.
3 Kessler RC, Chiu WT, Demler O, Merikangas KR, Walters EE. Prevalence, severity, and comorbidity of 12-month DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62:617-627. [pmid: 15939839].
4 Hasin D, Goodwin RD, Stinson F, Grant B. Epidemiology of Major Depressive Disorder: Results From the National Epidemiologic Survey on Alcoholism and Related Conditions. Arch Gen Psychiatry. 2005;62:1097-1106. [pmid: 16203955].
5 Narrow WE, Rae DS, Robins LN, Regier DA. Revised prevalence estimates of mental disorders in the United States: using a clinical significance criterion to reconcile 2 surveys’ estimates. Arch Gen Psychiatry. 2002;59:115-123. [pmid: 11825131].
6 Horwath E, Cohen R, Weissman MM. Epidemiology of Depressive and Anxiety Disorders. Tsuang M, Tohen M, editors. Textbook in Psychiatric epidemiology. 2nd ed. Hoeboken, NJ. John Wiley & Sons, Inc. 2002:389-426.
7 Beekman AT, Copeland JR, Prince MJ. Review of community prevalence of depression in later life. Br J Psychiatry. 1999;174:307-311. [pmid: 10533549].
8 Norton MC, Skoog I, Toone L, et al. Three-year incidence of first-onset depressive syndrome in a population sample of older adults: the Cache County study. Am J Geriatr Psychiatry. 2006;14:237-245. [pmid: 16505128].
9 Simon GE, VonKorff M. Recognition, management, and outcomes of depression in primary care. Arch Fam Med. 1995;4:99-105. [pmid: 7842160].
10 Williams J, Mulrow CD, Kroenke K. Case-finding for depression in primary care: a randomized trial. The American journal of medicine. 1999;106:36-43. [pmid: 10320115].
11 Coyne JC, Fechner-Bates S, Schwenk TL. Prevalence, nature, and comorbidity of depressive disorders in primary care. Gen Hosp Psychiatry. 1994;16:267-276. [pmid: 7926703].
12 Spitzer RL, Williams JB, Kroenke K, et al. Utility of a new procedure for diagnosing mental disorders in primary care. The PRIME-MD 1000 study. JAMA. 1994;272:1749-1756. [pmid: 7966923].
13 Lyness JM, Caine ED, King DA, Cox C, Yoediono Z. Psychiatric disorders in older primary care patients. J Gen Intern Med. 1999;14:249-254. [pmid: 10203638].
14 Schulberg HC, Mulsant B, Schulz R, Rollman BL, Houck PR, Reynolds CF III. Characteristics and course of major depression in older primary care patients. Int J Psychiatry Med. 1998;28:421-436. [pmid: 10207741].
15 Gaynes BN, Rush AJ, Trivedi MH, et al. Major depression symptoms in primary care and psychiatric care settings: a cross-sectional analysis. Ann Fam Med. 2007;5:126-134. [pmid: 17389536].
16 Gaynes BN, Rush AJ, Trivedi M, et al. A direct comparison of presenting characteristics of depressed outpatients from primary vs. specialty care settings: preliminary findings from the STAR*D clinical trial. General Hospital Psychiatry. Apr. 27. 2005;(2):87-96. [pmid: 15763119].
17 Depression Guideline Panel. Depression in primary care: Detection and Diagnosis Clinical Practice Guideline: Number 5 AHCPR Publication No 93-0550. United States Department of Health and Human Services, Public Health Service; Agency for Health Care Policy and Research. 1993.
18 Olfson M, Broadhead WE, Weissman MM, et al. Subthreshold psychiatric symptoms in a primary care group practice. Arch Gen Psychiatry. 1996;53:880-886. [pmid: 8857864].
19 World Health Organization (WHO). Global Burden of Disease in 2002: data sources, methods and results. World Health Organization (WHO). 2007. Global Programme on Evidence for Health Policy Discussion Paper 54.
20 Unutzer J, Patrick DL, Diehr P, Simon G, Grembowski D, Katon W. Quality adjusted life years in older adults with depressive symptoms and chronic medical disorders. Int Psychogeriatr. 2000;12:15-33. [pmid: 10798451].
21 Kessler RC, Berglund P, Demler O, et al. The epidemiology of major depressive disorder: results from the National Comorbidity Survey Replication (NCS-R). JAMA. 2003;289:3095-3105. [pmid: 12813115].
22 Simon GE. Social and economic burden of mood disorders. Biol Psychiatry. 2003;54:208-215. [pmid: 12893097].
23 Beck CT. Maternal depression and child behaviour problems: a meta-analysis. J Adv Nurs. 1999;29:623-629. [pmid: 10210459].
24 Downey G, Coyne JC. Children of depressed parents: an integrative review. Psychol Bull. 1990;108:50-76. [pmid: 2200073].
25 Kane P, Garber J. The relations among depression in fathers, children’s psychopathology, and father-child conflict: a meta-analysis. Clin Psychol Rev. 2004;24:339-360. [pmid: 15245835].
26 Penninx BW, Leveille S, Ferrucci L, van Eijk JT, Guralnik JM. Exploring the effect of depression on physical disability: longitudinal evidence from the established populations for epidemiologic studies of the elderly. Am J Public Health. 1999;89:1346-1352. [pmid: 10474551].
27 Bruce ML, Seeman TE, Merrill SS, Blazer DG. The impact of depressive symptomatology on physical disability: MacArthur Studies of Successful Aging. Am J Public Health. 1994;84:1796-1799. [pmid: 7977920].
28 Ormel J, VonKorff M, Oldehinkel AJ, Simon G, Tiemens BG, Ustun TB. Onset of disability in depressed and non-depressed primary care patients. Psychol Med. 1999;29:847-853. [pmid: 10473311].
29 Katon W, Ciechanowski P. Impact of major depression on chronic medical illness. J Psychosom Res. 2002;53:859-863. [pmid: 12377294].
30 Ferketich AK, Schwartzbaum JA, Frid DJ, Moeschberger ML. Depression as an antecedent to heart disease among women and men in the NHANES I study. National Health and Nutrition Examination Survey. Arch Intern Med. 2000;160:1261-1268. [pmid: 10809028].
31 Katon W, Russo J, Frank E, et al. Predictors of nonresponse to treatment in primary care patients with dysthymia. General Hospital Psychiatry. 2002;24:20-27. [pmid: 11814530].
32 Wulsin LR, Vaillant GE, Wells VE. A systematic review of the mortality of depression. Psychosom Med. 1999;61:6-17. [pmid: 10024062].
33 Unutzer J, Patrick DL, Marmon T, Simon GE, Katon WJ. Depressive symptoms and mortality in a prospective study of 2,558 older adults. Am J Geriatr Psychiatry. 2002;10:521-530. [pmid: 12213686].
34 McCusker J, Cole M, Ciampi A, Latimer E, Windholz S, Belzile E. Does depression in older medical inpatients predict mortality?. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2006;61:975-981.
35 Simon GE, VonKorff M. Suicide mortality among patients treated for depression in an insured population. Am J Epidemiol. 1998;147:155-160. [pmid: 9457005].
36 Chisholm D. The Economic Consequences of Depression. Dawson A, Tylee A, editors. Depression: Social and Economic Timebomb. World Health Organization. 2001:121-9.
37 Greenberg PE, Kessler RC, Birnbaum HG, et al. The economic burden of depression in the United States: how did it change between 1990 and 2000?. J Clin Psychiatry. 2003;64:1465-1475. [pmid: 14728109].
38 von KL, Akerblad AC, Bengtsson F, Carlsson A, Ekselius L. Cost of depression: effect of adherence and treatment response. Eur Psychiatry. 2006;21:349-354. [pmid: 16777385].
39 Rice D, Miller L. The Economic Burden of Affective Disorder. Br J Psychiatry. 1995;166:34-42.
40 Pearson SD, Katzelnick DJ, Simon GE, Manning WG, Helstad CP, Henk HJ. Depression among high utilizers of medical care. J Gen Intern Med. 1999;14:461-468. [pmid: 10491229].
41 Scott J. Depression should be managed like a chronic disease. BMJ. 2006;332:985-986. [pmid: 16644810].
42 Goldberg D. The “NICE Guideline” on the treatment of depression. Epidemiol Psichiatr Soc. 2006;15:11-15. [pmid: 16584098].
43 Pincus HA, Tanielian TL, Marcus SC, et al. Prescribing Trends in Psychotropic Medications: Primary Care, Psychiatry, and Other Medical Specialties. JAMA: The Journal of the American Medical Association. 1998;279:526-531. [pmid: 9480363].
44 Harman JS, Veazie PJ, Lyness JM. Primary care physician office visits for depression by older Americans. J Gen Intern Med. 2006;21:926-930. [pmid: 16918736].
45 Coryell W, Akiskal HS, Leon AC, et al. The time course of nonchronic major depressive disorder. Uniformity across episodes and samples. National Institute of Mental Health Collaborative Program on the Psychobiology of Depression--Clinical Studies. Arch Gen Psychiatry. 1994;51:405-410. [pmid: 8179464].
46 Rush AJ, Trivedi MH, Wisniewski SR, et al. Acute and longer-term outcomes in depressed outpatients requiring one or several treatment steps: a STAR*D report. Am J Psychiatry. 2006;163:1905-1917. [pmid: 17074942].
47 Goldberg D, Privett M, Ustun B, Simon G, Linden M. The effects of detection and treatment on the outcome of major depression in primary care: a naturalistic study in 15 cities. Br J Gen Pract. 1998;48:1840-1844. [pmid: 10198504].
48 Kessler D, Bennewith O, Lewis G, Sharp D. Detection of depression and anxiety in primary care: follow up study. BMJ. 2002;325(7371):1016-7. [pmid: 12411363].
49 Thompson C, Ostler K, Peveler RC, Baker N, Kinmonth AL. Dimensional perspective on the recognition of depressive symptoms in primary care: The Hampshire Depression Project 3. Br J Psychiatry. 2001;179:317-323. [pmid: 11581111].
50 Gaynes BN, Rush AJ, Trivedi MH, et al. Primary versus specialty care outcomes for depressed outpatients managed with measurement-based care: results from STAR*D. J Gen Intern Med. 2008;23:551-560. [pmid: 18247097].
51 Patten SB. A major depression prognosis calculator based on episode duration. Clin Pract Epidemol Ment Health. 2006;2:13.
52 Clinical Practice and Epidemiology in Mental Health. 2007:1-30. [pmid: 17274830].
53 Trivedi MH, Rush AJ, Wisniewski SR, et al. Evaluation of outcomes with citalopram for depression using measurement-based care in STAR*D: implications for clinical practice. Am J Psychiatry. 2006;163:28-40. [pmid: 16390886].
54 Mitchell AJ, Subramaniam H. Prognosis of depression in old age compared to middle age: a systematic review of comparative studies. Am J Psychiatry. 2005;162:1588-1601. [pmid: 16135616].
55 Cole MG, Bellavance F, Mansour A. Prognosis of depression in elderly community and primary care populations: a systematic review and meta-analysis. Am J Psychiatry. 1999;156:1182-1189. [pmid: 10450258].
56 Lyness JM, Caine ED, King DA, Conwell Y, Duberstein PR, Cox C. Depressive disorders and symptoms in older primary care patients: one-year outcomes. Am J Geriatr Psychiatry. 2002;10:275-282. [pmid: 11994214].
57 National Collaborating Centre for Mental Health. Depression: Management of Depression in Primary and Secondary Care. Clinical Guideline. 2004;23:1-63. London. National Institute for Clinical Excellence.
58 Riolo SA, Nguyen TA, Greden JF, King CA. Prevalence of depression by race/ethnicity: findings from the National Health and Nutrition Examination Survey III. Am J Public Health. 2005;95:998-1000. [pmid: 15914823].
59 Grant BF, Stinson FS, Dawson DA, et al. Prevalence and co-occurrence of substance use disorders and independent mood and anxiety disorders: results from the National Epidemiologic Survey on Alcohol and Related Conditions. Arch Gen Psychiatry. 2004;61:807-816. [pmid: 15289279].
60 Simon GE. Treating depression in patients with chronic disease: recognition and treatment are crucial; depression worsens the course of a chronic illness. West J Med. 2001;175:292-293. [pmid: 11694462].
61 Lorant V, Deliege D, Eaton W, Robert A, Philippot P, Ansseau M. Socioeconomic inequalities in depression: a meta-analysis. Am J Epidemiol. 2003;157:98-112. [pmid: 12522017].
62 Ames D. Depression and the elderly. Dawson A, Tylee A, editors. Depression: Social and exonomic timebomb. London. BMJ Publishing Group, BMA House;Tavistock Square. 2001:49-62.
63 NIH consensus conference. Diagnosis and treatment of depression in late life. JAMA. 1992;268:1018-1024. [pmid: 1501308].
64 Luoma JB, Martin CE, Pearson JL. Contact with mental health and primary care providers before suicide: a review of the evidence. Am J Psychiatry. 2002;159:909-916. [pmid: 12042175].
65 Serby M, Yu M. Overview: depression in the elderly. Mt Sinai J Med. 2003;70:38-44. [pmid: 12516008].
66 Krishnan KR, Delong M, Kraemer H, et al. Comorbidity of depression with other medical diseases in the elderly. Biol Psychiatry. 2002;52:559-588. [pmid: 12361669].
67 Practice guideline for the treatment of patients with major depressive disorder (revision). American Psychiatric Association. Am J Psychiatry. 2000;157:1-45.
68 Rush AJ, Kraemer HC, Sackeim HA, et al. Report by the ACNP Task Force on response and remission in major depressive disorder. Neuropsychopharmacology. 2006;31:1841-1853. [pmid: 16794566].
69 Judd LL, Akiskal HS, Zeller PJ, et al. Psychosocial disability during the long-term course of unipolar major depressive disorder. Arch Gen Psychiatry. 2000;57:375-380. [pmid: 10768699].
70 Penninx BW, Guralnik JM, Ferrucci L, Simonsick EM, Deeg DJ, Wallace RB. Depressive symptoms and physical decline in community-dwelling older persons. JAMA. 1998;279:1720-1726. [pmid: 9624025].
71 Pignone MP, Gaynes BN, Rushton JL, et al. Screening for depression in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136:765-776. [pmid: 12020146].
72 Arroll B, MacGillivray S, Ogston S, et al. Efficacy and tolerability of tricyclic antidepressants and SSRIs compared with placebo for treatment of depression in primary care: a meta-analysis. Annals of Family Medicine. 2005;3(5):449-56. Oct. [pmid: 16189062].
73 Bech P, Cialdella P, Haugh MC, et al. Meta-analysis of randomised controlled trials of fluoxetine v. placebo and tricyclic antidepressants in the short-term treatment of major depression. Br J Psychiatry. 2000;176:421-428. [pmid: 10912216].
74 Geddes JR, Freemantle N, Mason J, Eccles MP, Boynton J. Selective serotonin reuptake inhibitors (SSRIs) versus other antidepressants for depression. Cochrane Database of Systematic Reviews. 2005.
75 Williams JW Jr, Mulrow CD, Chiquette E, Noel PH, Aguilar C, Cornell J. A systematic review of newer pharmacotherapies for depression in adults: evidence report summary. Ann Intern Med. 2000;132:743-756. [pmid: 10787370].
76 Shah Rajen, Uren Z, Baker A, Majeed A. Deaths from antidepressants in England and Wales 1993–1997. Analysis of a new national database. Psychological Medicine. 2001;31(7):1203-1210. [pmid: 11681546].
77 Pirraglia PA, Stafford RS, Singer DE. Trends in Prescribing of Selective Serotonin Reuptake Inhibitors and Other Newer Antidepressant Agents in Adult Primary Care. Prim Care Companion J Clin Psychiatry. 2003;5:153-157. [pmid: 15213776].
78 Zuvekas SH. Prescription drugs and the changing patterns of treatment for mental disorders, 1996–2001. Health Aff (Millwood). 2005;24:195-205. [pmid: 15647230].
79 Corey-Lisle PK, Nash R, Stang P, Swindle R. Response, partial response, and nonresponse in primary care treatment of depression. Arch Intern Med. 2004;164:1197-1204. [pmid: 15197045].
80 Thase ME, Entsuah AR, Rudolph RL. Remission rates during treatment with venlafaxine or selective serotonin reuptake inhibitors. Br J Psychiatry. 2001;178:234-241. [pmid: 11230034].
81 Thase ME, Haight BR, Richard N, et al. Remission rates following antidepressant therapy with bupropion or selective serotonin reuptake inhibitors: a meta-analysis of original data from 7 randomized controlled trials. J Clin Psychiatry. 2005;66:974-981. [pmid: 16086611].
82 Casacalenda N, Perry JC, Looper K. Remission in major depressive disorder: a comparison of pharmacotherapy, psychotherapy, and control conditions. Am J Psychiatry. 2002;159(8):1354-1360. [pmid: 12153828].
83 Churchill R, Hunot V, Corney R, et al. A systematic review of controlled trials of the effectiveness and cost-effectiveness of brief psychological treatments for depression. Health Technol Assess. 2001;5(35):1-173. [pmid: 12387733].
84 U.S. Department of Health and Human Services. Mental Health and Mental Health Disorder. 2nd ed. Washington, D.C. U.S. Governement Priting Office. 2000.
85 Robinson WD, Geske JA, Prest LA, Barnacle R. Depression treatment in primary care. J Am Board Fam Pract. 2005;18:79-86. [pmid: 15798136].
86 Dobscha SK, Gerrity MS, Corson K, Bahr A, Cuilwik NM. Measuring adherence to depression treatment guidelines in a VA primary care clinic. General Hospital Psychiatry. Aug. 2003;25(4):230-7. [pmid: 12850654].
87 Simon GE. Evidence review: efficacy and effectiveness of antidepressant treatment in primary care. Gen Hosp Psychiatry. 2002;24:213-224. [pmid: 12100832].
88 Olfson M, Marcus SC, Tedeschi M, Wan GJ. Continuity of antidepressant treatment for adults with depression in the United States. Am J Psychiatry. 2006;163:101-108. [pmid: 16390896].
89 Solberg LI, Trangle MA, Wineman AP. Follow-up and follow-through of depressed patients in primary care: the critical missing components of quality care. J Am Board Fam Pract. 2005;18:520-527. [pmid: 16322414].
90 Anderson IM. Selective serotonin reuptake inhibitors versus tricyclic antidepressants: a meta-analysis of efficacy and tolerability. J Affect Disord. 2000;58(1):19-36. [pmid: 10760555].
91 Beasley CM Jr, Nilsson ME, Koke SC, Gonzales JS. Efficacy, adverse events, and treatment discontinuations in fluoxetine clinical studies of major depression: a meta-analysis of the 20-mg/day dose. J Clin Psychiatry. 2000;61:722-728. [pmid: 11078032].
92 Gartlehner G, Hansen RN, Thieda P, DeVeaugh-Geiss A, Gaynes BN, Krebs EE, Morgan LC, Lux LJ, Shumate JA, Monroe LG, Lohr KN. Comparative Effectiveness of Second-generation Antidepressants in the Pharmacologic Treatment of Adult Depression. 7. 2007. Rockville, MD. Agency for Healthcare Research and Quality.
93 MacGillivray S, Arroll B, Hatcher S, et al. Efficacy and tolerability of selective serotonin reuptake inhibitors compared with tricyclic antidepressants in depression treated in primary care: systematic review and meta-analysis. BMJ. 2003;326:1014. [pmid: 12742924].
94 Mottram P, Wilson K, Strobl J. Antidepressants for depressed elderly. Cochrane Database of Systematic Reviews (1). 2006.
95 Mulrow CD, Williams JW, Chiquette E, et al. Efficacy of newer medications for treating depression in primary care patients. Am J Med. 2000;108(1):54-64. [pmid: 11059441].
96 Kroenke K, West SL, Swindle R, et al. Similar effectiveness of paroxetine, fluoxetine, and sertraline in primary care: a randomized trial. JAMA. 2001;286:2947-2955. [pmid: 11743835].
97 Depression Guideline Panel. Depression in Primary Care: Volume 2 Treatment of Major Depression AHCPR Publication No 93-0550. United States Department of Health and Human Services. Public Health Service; Agency for Health Care Policy and Research. 1993.
98 The Management of Major Depressive Disorder Working Group. Veterans Health Administration/Department of Defense Performance Measures for the Management of Major Depressive Disorder in Adults. 2000. Washington. Veterans Health Administration and the Department of Defense.
99 Work Group On Major Depressive Disorder. Practice Guideline for the Treatment of Patients With Major Depressive Disorder. Second Edition. Washington. American Psychiatric Publishing, Inc. 2000.
100 Gilbody S, House AO, Sheldon TA. Screening and case finding instruments for depression. Cochrane Database of Systematic Reviews. 2005;(4).
101 Gilbody S, Whitty P, Grimshaw J, Thomas R. Educational and organisational interventions to improve the management of depression in primary care. JAMA. 2003;289(23):3145-3151. [pmid: 12813120].
102 Coyne J, Palmer S, Sullivan P. Screening for Depression in Adults. Ann Intern Med. 2003;138:767-768. [pmid: 12729435].
103 Hickie IB, Davenport TA, Ricci CS. Screening for depression in general practice and related medical settings. Med J Aust. 2002;177(Suppl):S111-S116. [pmid: 12358569].
104 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
105 Medicines and Healthcare Products Regulatory Agency. Report of the CSM Expert Working Group on the Safety of Selective Serotonin Reuptake Inhibitor Antidepressants. MHRA. 2004.
106 National Institute for Clinical Excellence. Guideline Development Methods: Information for National Collaborating Centres and Guideline Developers. 2004. London.
107 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44:1271-1278. [pmid: 1834807].
108 Pignone M, Gaynes B, Lohr K, Rushton JL, Mulrow C. Screening for Depression in Adults. Ann Intern Med. 2003;138:767-768.
109 Rost K. Improving depression outcomes in community primary care practice: A randomized trial of the QuEST intervention. J Gen Intern Med. 2001;16:143-149. [pmid: 11318908].
110 Wells KB, Sherbourne C, Schoenbaum M, et al. Impact of disseminating quality improvement programs for depression in managed primary care: a randomized controlled trial. JAMA. 2000;283(2):212-20. [pmid: 10634337].
111 Whooley MA, Stone B. Randomized trial of case-finding for depression in elderly primary care patients. Journal of general internal medicine: official journal of the Society for Research and Education in Primary Care Internal Medicine. 2000;15:293-300.
112 Callahan CM, Hendrie HC, Dittus RS, Brater DC, Hui SL, Tierney WM. Improving treatment of late life depression in primary care: a randomized clinical trial. J Am Geriatr Soc. 1994;42:839-846. [pmid: 8046193].
113 Bergus GR, Hartz AJ, Noyes R Jr, et al. The limited effect of screening for depressive symptoms with the PHQ-9 in rural family practices. Journal of Rural Health. 2005;21(4):303-9. [pmid: 16294652].
114 Jarjoura D, Polen A, Baum E, Kropp D, Hetrick S, Rutecki G. Effectiveness of screening and treatment for depression in ambulatory indigent patients. Journal of General Internal Medicine. 2004:78-84. [pmid: 14748864].
115 Bosmans Judith, de Bruijne Martine, van Hout Hein, van Marwijk Harm, Beekman Aartjan, Bouter Lex, Stalman Wim, van Tulder Maurits. Cost-Effectiveness of a Disease Management Program for Major Depression in Elderly Primary Care Patients. Journal of General Internal Medicine. 2006;21(10):1020-1026. [pmid: 16836625].
116 Rubenstein LZ, Alessi CA, Josephson KR, Trinidad HM, Harker JO, Pietruszka FM. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. 2007;55:166-174. [pmid: 17302651].
117 van Marwijk H, Grundmeijer Hglm, Breuren MM. Guidelines on Depression of the Dutch College of General Practitioners. Huisarts Wet. 1994:482-490.
118 Wells K, Sherbourne C, Schoenbaum M, et al. Five-year impact of quality improvement for depression: Results of a group-level randomized controlled trial. Arch Gen Psychiatry. 2004;61:378-386. [pmid: 15066896].
119 Rost K. Treatment effect. 2006.
120 Pinquart M, Duberstein PR, Lyness JM. Treatments for later-life depressive conditions: a meta-analytic comparison of pharmacotherapy and psychotherapy. Am J Psychiatry. 2006;163:1493-1501. [pmid: 16946172].
121 Wilson K, Mottram P, Sivanranthan A, Nightingale A. Antidepressant versus placebo for depressed elderly. Cochrane Database Syst Rev. 2000.
122 Cuijpers Pim, van Straten Annemieke, Smit Filip. Psychological treatment of late-life depression: A meta-analysis of randomized controlled trials. International Journal of Geriatric Psychiatry. 2006;21(12):1139-1149. [pmid: 16955421].
123 Pinquart M, Sorensen S. How effective are psychotherapeutic and other psychosocial interventions with older adults? A meta-analysis. Journal of Mental Health and Aging. 2001;7:207-243.
124 Stone M, Jones ML. Clinical Review. Relationship Between Antidepressant Drugs and Suicidality in Adults. 2006.
125 Levenson M, Holland C. Statistical Evaluation of Suicidality in Adults Treated with Antidepressants. 2006.
126 Khan A, Khan S, Kolts R, Brown WA. Suicide rates in clinical trials of SSRIs, other antidepressants, and placebo: analysis of FDA reports. Am J Psychiatry. 2003;160:790-792. [pmid: 12668373].
127 Jick SS, Dean AD, Jick H. Antidepressants and suicide. BMJ. 1995;310:215-218. [pmid: 7677826].
128 Martinez C, Rietbrock S, Wise L, et al. Antidepressant treatment and the risk of fatal and non-fatal self harm in first episode depression: nested case-control study. BMJ. 2005;330:389. [pmid: 15718538].
129 Simon GE, Savarino J, Operskalski B, Wang PS. Suicide risk during antidepressant treatment. American Journal of Psychiatry. 2006;163(1):41-7. [pmid: 16390887].
130 Fergusson D, Doucette S, Glass KC, et al. Association between suicide attempts and selective serotonin reuptake inhibitors: systematic review of randomised controlled trials. BMJ. 2005;330(7488):396. [pmid: 15718539].
131 GlaxoSmithKline. Paroxetine Adult Suicidality Analysis: Major Depressive Disorder and Non-Major Depressive Disorder. 2006.
132 Dalton SO, Sorensen HT, Johansen C. SSRIs and upper gastrointestinal bleeding: what is known and how should it influence prescribing?. CNS Drugs. 2006;20:143-151. [pmid: 16478289].
133 de Abajo FJ, Rodriguez LA, Montero D. Association between selective serotonin reuptake inhibitors and upper gastrointestinal bleeding: population based case-control study. BMJ. 1999;319:1106-1109. [pmid: 10531103].
134 van Walraven C, Mamdani MM, Wells PS, Williams JI. Inhibition of serotonin reuptake by antidepressants and upper gastrointestinal bleeding in elderly patients: retrospective cohort study. BMJ. 2001;323:655-658. [pmid: 11566827].
135 Dalton SO, Johansen C, Mellemkjaer L, Norgard B, Sorensen HT, Olsen JH. Use of selective serotonin reuptake inhibitors and risk of upper gastrointestinal tract bleeding: a population-based cohort study. Arch Intern Med. 2003;163:59-64. [pmid: 12523917].
136 Tata LJ, Fortun PJ, Hubbard RB, et al. Does concurrent prescription of selective serotonin reuptake inhibitors and non-steroidal anti-inflammatory drugs substantially increase the risk of upper gastrointestinal bleeding?. Aliment Pharmacol Ther. 2005;22:175-181. [pmid: 16091054].
137 Hammad TA, Laughren TP, Racoosin JA. Suicide rates in short-term randomized controlled trials of newer antidepressants. J Clin Psychopharmacol. 2006;26:203-207. [pmid: 16633153].
138 Gunnell D, Saperia J, Ashby D. Selective serotonin reuptake inhibitors (SSRIs) and suicide in adults: meta-analysis of drug company data from placebo controlled, randomised controlled trials submitted to the MHRA’s safety review. BMJ. 2005;330:385. [pmid: 15718537].
139 Saperia J, Ashby D, Gunnell D. Suicidal behaviour and SSRIs: updated meta-analysis. BMJ. 2006;332:1453. [pmid: 16777898].
140 Storosum JG, van Zwieten BJ, van den BW, Gersons BP, Broekmans AW. Suicide risk in placebo-controlled studies of major depression. Am J Psychiatry. 2001;158:1271-1275. [pmid: 11481162].
141 Melander H, Ahlqvist-Rastad J, Meijer G, Beermann B. Evidence b(i)ased medicine--selective reporting from studies sponsored by pharmaceutical industry: review of studies in new drug applications. BMJ. 2003;326:1171-1173. [pmid: 12775615].
142 Lexchin J, Bero LA, Djulbegovic B, Clark O. Pharmaceutical industry sponsorship and research outcome and quality: systematic review. BMJ. 2003;326:1167-1170. [pmid: 12775614].
143 Mackay FJ, Dunn NR, Mann RD. Antidepressants and the serotonin syndrome in general practice. Br J Gen Pract. 1999;49:871-874. [pmid: 10818650].
144 Sondergard L, Kvist K, Andersen PK, Kessing LV. Do antidepressants prevent suicide?. Int Clin Psychopharmacol. 2006;21:211-218. [pmid: 16687992].
145 Mackay FJ, Dunn NR, Wilton LV, Pearce GL, Freemantle SN, Mann RD. A comparison of fluvoxamine, fluoxetine, sertraline and paroxetine examined by observational cohort studies. Pharmacoepidemiol Drug Saf. 1997;6:235-246. [pmid: 15073774].
146 Gibbons RD, Brown CH, Hur K, Marcus SM, Bhaumik DK, Mann JJ. Relationship between antidepressants and suicide attempts: an analysis of the Veterans Health Administration data sets.[see comment]. Am J Psychiatry. 2007;164:1044-1049. [pmid: 17606656].
147 Mackay FR, Dunn NR, Martin RM, Pearce GL, Freemantle SN, Mann RD. Newer antidepressants: a comparison of tolerability in general practice. Br J Gen Pract. 1999;49:892-896. [pmid: 10818655].
148 Jick H, Kaye JA, Jick SS. Antidepressants and the risk of suicidal behaviors. JAMA. 2004;292:338-343. [pmid: 15265848].
149 Csizmadi I, Collet J, Boivin J. Bias and Confounding in Pharmacoepidemiology. Strom B, editor. Pharmacoepidemiology. Fourth ed. Philadelphia. John Wiley & Sons, Ltd. 2005:791-809.
150 Didham RC, McConnell DW, Blair HJ, Reith DM. Suicide and self-harm following prescription of SSRIs and other antidepressants: confounding by indication. Br J Clin Pharmacol. 2005;60:519-525. [pmid: 16236042].
151 Medicines and Healthcare Products Regulatory Agency. Venlafaxine (Effexor) Summary of Basis for Regulatory Position. Medicines and Healthcare Products Regulatory Agency. 2006. 1-29-2007.
152 Solomon DA, Keller MB, Leon AC, et al. Recovery from major depression. A 10-year prospective follow-up across multiple episodes. Arch Gen Psychiatry. 1997;54:1001-1006. [pmid: 9366656].
153 Layton D, Clark DW, Pearce GL, Shakir SA. Is there an association between selective serotonin reuptake inhibitors and risk of abnormal bleeding? Results from a cohort study based on prescription event monitoring in England. Eur J Clin Pharmacol. 2001;57:167-176. [pmid: 11417450].
154 Meijer WE, Heerdink ER, Nolen WA, Herings RM, Leufkens HG, Egberts AC. Association of risk of abnormal bleeding with degree of serotonin reuptake inhibition by antidepressants. Arch Intern Med. 2004;164:2367-2370. [pmid: 15557417].
155 Richards JB, Papaioannou A, Adachi JD, et al. Effect of selective serotonin reuptake inhibitors on the risk of fracture. Archives of Internal Medicine. 2007;167(2):188-94. [pmid: 17242321].
156 Gilbody S, Sheldon T, Wessely S. Should we screen for depression?. BMJ. 2006;332:1027-1030. [pmid: 16644833].
157 Palmer SC, Coyne JC. Screening for depression in medical care: pitfalls, alternatives, and revised priorities. J Psychosom Res. 2003;54:279-287. [pmid: 12670603].
158 Schwenk TL, Coyne JC, Fechner-Bates S. Differences between detected and undetected patients in primary care and depressed psychiatric patients. Gen Hosp Psychiatry. 1996;18:407-415. [pmid: 8937906].
159 Oxman TE, Sengupta A. Treatment of minor depression. Am J Geriatr Psychiatry. 2002;10(3):256-264. [pmid: 11994212].
160 Swindle RW, Rao JK, Helmy A, et al. Integrating clinical nurse specialists into the treatment of primary care patients with depression. [References]. Int J Psychiatry Med. 2003;33:17-37. [pmid: 12906341].
161 Rost K, Nutting P, Smith J, Coyne JC, Cooper-Patrick L, Rubenstein L. The role of competing demands in the treatment provided primary care patients with major depression. Arch Fam Med. 2000;9:150-154. [pmid: 10693732].
162 Kessler D, Lloyd K, Lewis G, Gray DP. Cross sectional study of symptom attribution and recognition of depression and anxiety in primary care. BMJ. 1999;318:436-439. [pmid: 9974461].
163 Meredith LS, Orlando M, Humphrey N, Camp P, Sherbourne CD. Are better ratings of the patient-provider relationship associated with higher quality care for depression?. Medical Care. 2001;39(4):349-60.
164 Simon GE, Fleck M, Lucas R, Bushnell DM. Prevalence and predictors of depression treatment in an international primary care study. Am J Psychiatry. 2004;161:1626-1634. [pmid: 15337653].
165 Williams JB, Spitzer RL, Linzer M, et al. Gender differences in depression in primary care. Am J Obstet Gynecol. 1995;173:654-659. [pmid: 7645648].
166 Badamgarav E, Weingarten SR, Henning JM, et al. Effectiveness of disease management programs in depression: a systematic review. American Journal of Psychiatry. 2003;160(12):2080-90. [pmid: 14638573].
167 Gensichen J, Beyer M, Muth C, Gerlach FM, Von KM, Ormel J. Case management to improve major depression in primary health care: a systematic review. Psychol Med. 2006;36:7-14. [pmid: 16356292].
168 Neumeyer-Gromen A, Lampert T, Stark K, Kallischnigg G. Disease management programs for depression: a systematic review and meta-analysis of randomized controlled trials. Med Care. 2004;42(12):1211-223. 1221. [pmid: 15550801].
169 Williams JW Jr, Gerrity M, Holsinger T, Dobscha S, Gaynes B, Dietrich A. Systematic review of multifaceted interventions to improve depression care. Gen Hosp Psychiatry. 2007;29:91-116. [pmid: 17336659].
170 Wang PS, Simon G, Kessler RC. The economic burden of depression and the cost-effectiveness of treatment. Int J Methods Psychiatr Res. 2003;12:22-33. [pmid: 12830307].
171 Solberg LI, Trangle MA, Wineman AP. Follow-up and follow-through of depressed patients in primary care: the critical missing components of quality care. J Am Board Fam Pract. 2005;18:520-527. [pmid: 16322414].
172 Unutzer J, Schoenbaum M, Druss BG, Katon WJ. Transforming mental health care at the interface with general medicine: report for the presidents commission. Psychiatr Serv. 2006;57:37-47. [pmid: 16399961].
173 Von Korff M, Goldberg D. Improving outcomes in depression. BMJ. 2001;323:948-949. [pmid: 11679372].
174 Rost K, Pyne JM, Dickinson LM, LoSasso AT. Cost-Effectiveness of Enhancing Primary Care Depression Management on an Ongoing Basis. Annals of Family Medicine. 2005;3:7-14. [pmid: 15671185].
175 Skultety KM, Zeiss A. The treatment of depression in older adults in the primary care setting: an evidence-based review. Health Psychol. 2006;25:665-674. [pmid: 17100494].
176 Hunkeler EM, Katon W, Tang L, et al. Long term outcomes from the IMPACT randomised trial for depressed elderly patients in primary care. BMJ. 2006;332:259-263. [pmid: 16428253].
177 Alexopoulos GS, Katz IR, Bruce ML, et al. Remission in depressed geriatric primary care patients: a report from the PROSPECT study. American Journal of Psychiatry. 2005;162(4):718-24. [pmid: 15800144].
178 Katon WJ, Schoenbaum M, Fan MY, et al. Cost-effectiveness of improving primary care treatment of late-life depression. Arch Gen Psychiatry. 2005;62:1313-1320. [pmid: 16330719].
179 Katon WJ, Unutzer J, Simon G. Treatment of depression in primary care: where we are, where we can go. Med Care. 2004;42:1153-1157. [pmid: 15550794].
180 Ernst CL, Goldberg JF. Antisuicide properties of psychotropic drugs: a critical review. Harv Rev Psychiatry. 2004;12:14-41. [pmid: 14965852].
181 Juurlink DN, Mamdani MM, Kopp A, Redelmeier DA. The risk of suicide with selective serotonin reuptake inhibitors in the elderly. Am J Psychiatry. 2006;163:813-821. [pmid: 16648321].
182 Barak Y, Olmer A, Aizenberg D. Antidepressants reduce the risk of suicide among elderly depressed patients. Neuropsychopharmacology. 2006;31:178-181. [pmid: 16123751].
183 Bruce ML, Ten Have TR, Reynolds CFI, et al. Reducing Suicidal Ideation and Depressive Symptoms in Depressed Older Primary Care Patients: A Randomized Controlled Trial. JAMA: Journal of the American Medical Association. 2004;291:1081-1091. [pmid: 14996777].
184 Gaynes BN, West SL, Ford CA, Frame P, Klein J, Lohr KN. Screening for suicide risk in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140:822-835. [pmid: 15148072].
185 Schulberg HC, Lee PW, Bruce ML, et al. Suicidal ideation and risk levels among primary care patients with uncomplicated depression. Ann Fam Med. 2005;3:523-528. [pmid: 16338916].
186 Milane MS, Suchard MA, Wong ML, Licinio J. Modeling of the temporal patterns of fluoxetine prescriptions and suicide rates in the United States. PLoS Medicine/Public Library of Science. 2006;3:e190.
187 Roy-Byrne PP, Perera P, Pitts CD, Christi JA. Paroxetine response and tolerability among ethnic minority patients with mood or anxiety disorders: a pooled analysis. J Clin Psychiatry. 2005;66:1228-1233. [pmid: 16259535].
188 Shi L, Thiebaud P, McCombs JS. The impact of unrecognized bipolar disorders for patients treated for depression with antidepressants in the fee-for-services California Medicaid (Medi-Cal) program. J Affect Disord. 2004;82:373-383. [pmid: 15555688].
189 Sherbourne CD, Wells KB, Duan N, et al. Long-term effectiveness of disseminating quality improvement for depression in primary care. Arch Gen Psychiatry. 2001;58:696-703. [pmid: 11448378].
190 Rost K, Nutting PA, Smith J, Werner JJ. Designing and implementing a primary care intervention trial to improve the quality and outcome of care for major depression. General Hospital Psychiatry. Apr. 2000;22(2):66-77. [pmid: 10822094].
191 Rost K, Nutting P, Smith JL, Elliott CE, Dickinson M. Managing depression as a chronic disease: a randomised trial of ongoing treatment in primary care. BMJ. 2002;325:934. [pmid: 12399343].
192 Beasley CM Jr, Koke SC, Nilsson ME, Gonzales JS. Adverse events and treatment discontinuations in clinical trials of fluoxetine in major depressive disorder: an updated meta-analysis. Clin Ther. 2000;22:1319-1330. [pmid: 11117656].
193 Gilbody SM, Whitty PM, Grimshaw JM, Thomas RE. Improving the detection and management of depression in primary care. [Review] [103 refs]. Quality & Safety in Health Care. 2003;12(2):149-55. [pmid: 12679514].
194 Oslin DW, Sayers S, Ross J, et al. Disease management for depression and at-risk drinking via telephone in an older population of veterans. Psychosomatic Medicine. Dec. 2003;65(6):931-7. [pmid: 14645769].
195 Datto CJ, Thompson R, Horowitz D, Disbot M, Oslin DW. The pilot study of a telephone disease management program for depression. Gen Hosp Psychiatry. 2003;25:169-177. [pmid: 12748029].
196 Katon WJ, Von Korff M, Lin EH, et al. The Pathways Study: a randomized trial of collaborative care in patients with diabetes and depression. Arch Gen Psychiatry. 2004;61:1042-1049. [pmid: 15466678].
197 Fortney JC, Pyne JM, Edlund MJ, et al. A randomized trial of telemedicine-based collaborative care for depression. Journal of general internal medicine: official journal of the Society for Research and Education in Primary Care Internal Medicine. 2007;22:1086-1093.
198 Wang PS, Simon GE, Avorn J, et al. Telephone screening, outreach, and care management for depressed workers and impact on clinical and work productivity outcomes: a randomized controlled trial. JAMA. 2007;298:1401-1411. [pmid: 17895456].
199 Unutzer J, Katon W, Callahan CM, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA. 2002;288:2836-2845. [pmid: 12472325].
200 Dietrich AJ, Oxman TE, Williams JW Jr, et al. Going to scale: re-engineering systems for primary care treatment of depression. Ann Fam Med. 2004;2:301-304. [pmid: 15335127].
201 Hedrick SC, Chaney EF, Felker B, et al. Effectiveness of collaborative care depression treatment in Veterans’ Affairs primary care. Journal of General Internal Medicine. 2003;18(1):9-16. [pmid: 12534758].
202 Katzelnick DJ, Simon GE, Pearson SD, et al. Randomized trial of a depression management program in high utilizers of medical care. Archives of Family Medicine. 2000.
203 Hunkeler EM, Meresman JF, Hargreaves WA, et al. Efficacy of nurse telehealth care and peer support in augmenting treatment of depression in primary care. Archives of Family Medicine. 2000;9(8):700-8. [pmid: 10927707].
204 Simon GE, VonKorff M, Rutter C, Wagner E. Randomised trial of monitoring, feedback, and management of care by telephone to improve treatment of depression in primary care.[see comment]. BMJ. 2000;320:550-554. [pmid: 10688563].
205 Peveler R, George C, Kinmonth AL, Campbell M, Thompson C. Effect of antidepressant drug counselling and information leaflets on adherence to drug treatment in primary care: randomised controlled trial. BMJ. 1999;319:612-615. [pmid: 10473477].
206 Banerjee S, Shamash K, MacDonald AJ, Mann AH. Randomised controlled trial of effect of intervention by psychogeriatric team on depression in frail elderly people at home.[see comment]. BMJ. 1996;313:1058-1061. [pmid: 8898601].
207 Schulberg HC, Block MR, Madonia MJ, et al. Treating major depression in primary care practice. Eight-month clinical outcomes. Arch Gen Psychiatry. 1996;53:913-919. [pmid: 8857868].
208 Katon W, Von KM, Lin E, et al. Collaborative management to achieve treatment guidelines. Impact on depression in primary care. JAMA. 1995;273:1026-1031. [pmid: 7897786].
209 Katon W, Robinson P, Von KM, et al. A multifaceted intervention to improve treatment of depression in primary care. Arch Gen Psychiatry. 1996;53:924-932. [pmid: 8857869].
210 Katon W, Von Korff M, Lin E, et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: a randomized trial. Arch Gen Psychiatry. 1999;56:1109-1115. [pmid: 10591288].
211 Blanchard MRWA. The effect of primary care nurse intervention upon older people screened as depressed. International Journal of Geriatric Psychiatry. 1995;10(4):289-298.
212 Ell K, Unutzer J, Aranda M, Gibbs NE, Lee PJ, Xie B. Managing depression in home health care: a randomized clinical trial. Home Health Care Serv Q. 2007;26:81-104. [pmid: 17804354].
213 Finley PR, Rens HR, Pont JT, et al. Impact of a collaborative care model on depression in a primary care setting: a randomized controlled trial. Pharmacotherapy. 2003;23:1175-1185. [pmid: 14524649].
214 Capoccia KL. BDBDEACDSNKWSS. Randomized trial of pharmacist interventions to improve depression care and outcomes in primary care. American journal of health-system pharmacy: AJHP: official journal of the American Society of Health-System Pharmacists. 2004:364-372. [pmid: 15011764].
215 Adler DA, Bungay KM, Wilson IB, et al. The impact of a pharmacist intervention on 6-month outcomes in depressed primary care patients. General Hospital Psychiatry. Jun. 2004;26(3):199-209. [pmid: 15121348].
216 Dobscha SK, Corson K, Hickam DH, Perrin NA, Kraemer DF, Gerrity MS. Depression decision support in primary care: a cluster randomized trial. Ann Intern Med. 2006;145:477-487. [pmid: 17015865].
217 Brook OH, van HH, Stalman W, et al. A pharmacy-based coaching program to improve adherence to antidepressant treatment among primary care patients. Psychiatr Serv. 2005;56:487-489. [pmid: 15812103].
218 Rollman BL, Hanusa BH, Lowe HJ, Gilbert T, Kapoor WN, Schulberg HC. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med. 2002;17:493-503. [pmid: 12133139].
219 Haw C, Houston K, Townsend E, Hawton K. Deliberate self-harm patients with alcohol disorders: characteristics, treatment, and outcome. Crisis: Journal of Crisis Intervention & Suicide. 2001;22(3):93-101.
220 Dowrick C. Does testing for depression influence diagnosis or management by general practitioners?. Fam Pract. 1995;12:461-465. [pmid: 8826066].
221 Thompson C, Kinmonth AL, Stevens L, et al. Effects of a clinical-practice guideline and practice-based education on detection and outcome of depression in primary care: Hampshire Depression Project randomised controlled trial.[see comment]. Lancet. 2000;355(9199):185-91. [pmid: 10675118].
222 Brown JB, Shye D, McFarland BH, Nichols GA, Mullooly JP, Johnson RE. Controlled trials of CQI and academic detailing to implement a clinical practice guideline for depression. Jt Comm J Qual Improv. 2000;26:39-54. [pmid: 10677821].
223 Goldberg HI, Wagner EH, Fihn SD, et al. A randomized controlled trial of CQI teams and academic detailing: can they alter compliance with guidelines?. Joint Commission Journal on Quality Improvement. 1998;24(3):130-42. [pmid: 9568553].
224 Mann AHBR. An evaluation of practice nurses working with general practitioners to treat people with depression. British Journal of General Practice. 1998;48(426):875-879. [pmid: 9604408].
225 Coleman EAGLS. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults see comments. Journal of the American Geriatrics Society. 1999;47(7):775. [pmid: 10404919].
226 Bashir K, Blizard B, Bosanquet A, Bosanquet N, Mann A, Jenkins R. The evaluation of a mental health facilitator in general practice: effects on recognition, management, and outcome of mental illness. Br J Gen Pract. 2000;50:626-629. [pmid: 11042913].
227 Solberg LI, Fischer LR, Wei F, et al. A CQI intervention to change the care of depression: a controlled study. Eff Clin Pract. 2001;4:239-249. [pmid: 11769296].
228 Arthur AJ, Jagger C, Lindesay J, Matthews RJ. Evaluating a mental health assessment for older people with depressive symptoms in general practice: a randomised controlled trial. Br J Gen Pract. 2002;52:202-207. [pmid: 12030662].
229 Desai MM, Rosenheck RA, Craig TJ. Case-finding for depression among medical outpatients in the Veterans Health Administration. Med Care. 2006;44:175-181. [pmid: 16434917].
230 Stagnitti MN. Antidepressant Use in the U.S. Civilian Noninstitutionalized Population, 2002. Agency for Healthcare Research and Quality Medical Expenditure Panel Survey, Statistical Brief #77. 2005:1-7.
231 Stafford RS, MacDonald EA, Finkelstein SN. National Patterns of Medication Treatment for Depression, 1987 to 2001. Prim Care Companion J Clin Psychiatry. 2001;3:232-235. [pmid: 15014590].
232 Olfson M, Marcus SC, Druss B, Elinson L, Tanielian T, Pincus HA. National trends in the outpatient treatment of depression. JAMA. 2002;287:203-209. [pmid: 11779262].
233 Joo JH, Solano FX, Mulsant BH, Reynolds CF, Lenze EJ. Predictors of adequacy of depression management in the primary care setting. Psychiatr Serv. 2005;56:1524-1528. [pmid: 16339613].
234 Solberg LI, Fischer LR, Rush WA, Wei F. When depression is the diagnosis, what happens to patients and are they satisfied?. Am J Manag Care. 2003;9:131-140. [pmid: 12597601].
235 The Cochrane Collaboration. The Cochrane Manual Issue 1, 2007. www.cochrance.org/admin/manual.htm. 11-15-2006. 12-28-2006.
236 Johnstone A, Goldberg D. Psychiatric screening in general practice. A controlled trial. Lancet. 1976;1:605-608. [pmid: 55891].
237 Zung WW, Magill M, Moore JT, George DT. Recognition and treatment of depression in a family medicine practice. J Clin Psychiatry. 1983;44:3-6. [pmid: 6822483].
238 Lewis G, Sharp D, Bartholomew J, Pelosi AJ. Computerized assessment of common mental disorders in primary care: effect on clinical outcome. Fam Pract. 1996;13:120-126. [pmid: 8732321].
239 Reifler DR, Kessler HS, Bernhard EJ, Leon AC, Martin GJ. Impact of screening for mental health concerns on health service utilization and functional status in primary care patients. Arch Intern Med. 1996;156:2593-2599. [pmid: 8951303].
240 Rubenstein LV, Jackson-Triche M, Unutzer J, et al. Evidence-based care for depression in managed primary care practices. Health Aff (Millwood). 1999;18:89-105. [pmid: 10495595].
241 Simon GE, Katon WJ, Lin EH, et al. Cost-effectiveness of systematic depression treatment among people with diabetes mellitus. Archives of General Psychiatry. 2007;64(1):65-72. [pmid: 17199056].