# Discussion

## Benefits and Harms of Primary Care Depression Screening

The direct evidence in support of widespread depression screening programs in primary care without further care supports beyond those focused on boosting the effectiveness of the primary care clinician’s treatment is weak. However, screening programs in which other staff provide some depression care can reduce depressive symptoms. Specifically, in this review, programs in which other staff provided assessment and monitoring in coordination with the primary care provider’s treatment, or that made extra efforts to enroll patients in specialty mental health treatment were likely to be effective.

We located one fair-quality RCT10 that comparing screened and unscreened primary care adult patients; screening increased the likelihood of complete remission at three months among those with major depression, but differences were not seen in the proportion of screened and unscreened participants meeting diagnostic criteria for major depression. Methodological limitations to the analyses of interest to this review included very short follow-up, no information on the baseline comparability between the treatment and control groups in the subset of participants selected for follow-up, and no information on the comparability of the subgroup selected for follow-up with the full sample. Since only one trial directly evaluated a screening program, we also considered trials of screen-detected depressed patients, where the intervention included feedback of screening test results to clinicians (usually with provision of depression diagnostic and care management supports) compared with “usual care” where screening results were not given to the providers. The only RCT that evaluated clinician feedback of depression screening test results without further care supports (most closely mimicking a trial of screened versus unscreened patients) was a small, underpowered study that found no benefit.113

Feedback of screening results combined with the participation of other staff in the treatment of the patient’s depression did improve depressive symptomatology,109,110,114,116 particularly for adult patients with newly detected depression. The most intensive programs109,110 involved extensive training of clinician and office support staff, patient materials, mental health or support staff participation in ongoing depression care, and multiple follow-up contacts. Even with a fairly intensive program, one of these trials109 improved depression symptomatology only in patients with newly identified depression. Two less intensive programs114,116 were also effective in reducing depressive symptomatology, when additional staff were involved in the care of the patient’s depression. However, one116 of these resulted in only a one-point difference in improvement on a 30-point depression scale, which may not reflect a clinically important difference. Participants in these two less intensive programs that improved depressive symptomatology were highly selected and not broadly representative of general primary care populations.

Comparisons with other reviews of depression screening. In contrast to the 2002 systematic review,71 on which the USPSTF based it depression screening recommendation, a 2005 Cochrane review that excluded all studies including “complex quality improvement/care management” strategies, concluded that screening programs were not effective in improving health outcomes. Our findings both confirm and extend these two previous reviews. Consistent with both the USPSTF and Cochrane reviews, the limited evidence we found on screening and feedback without further care supports suggested this approach is unlikely to have an impact. We concur with the previous USPSTF review that depression care support programs including screening can improve depression symptomatology and remission in adult populations, and we are clearer about the types of effective support. Any apparent differences in the conclusions between these three reviews can largely be explained by the differences in the trials each included, as detailed in Appendix E Table 1.

Why screening programs alone may not be effective. It is puzzling, at first glance, why screening and feedback of results alone would not clearly improve depression outcomes, since it is fairly well-established that they do increase recognition of depression.108 Critics of widespread depression screening suggest that the differences between clinically-detected and screen-detected cases could partially explain this discrepancy.156,157 Patients whose depression is undetected in primary care (and would therefore only be identified through screening) tend to be less impaired and have milder levels of depression than those who are identified without screening.9,47,49,158 Treatments such as antidepressants may have only a small effect in patients with mild depression.159 Given this, treatment may not be initiated for patients screening positive for mild depression, as was the case in a study that used the PRIME-MD screening tool in VA outpatient medical clinics, where clinical nurse specialists disagreed with the screening diagnosis in 40 percent of the positive screening cases and therefore did not initiate antidepressant treatment.160 Studies have also found that the patients whose depression was missed by providers had negative attitudes about antidepressants161 and were more likely to consider their depressed mood to be due to normal fluctuations or physical causes.162 Thus, the patients whose depression is undetected may be less likely to accept the treatment that the provider would most likely offer. Given these considerations, NICE guidelines suggest avoiding antidepressants and psychological therapies as an initial treatment in mild depression, offering strategies such as watchful waiting, advice on sleep and anxiety management, exercise, or guided self-help programs57 as initial steps.

Another reason that screening programs alone may not be effective is that many depression cases identified will already be known to the clinician. In the trials we reviewed, about 40 to 80 percent of non-older adults screening positive were already being treated (i.e., at the time of screening or very recently).113,114,163 Similarly, in the Seattle, WA site of an international, naturalistic study of depression treatment in primary care, 34 percent of patients screened positive on the CES-D, and 44 percent of these had been treated for depression during the previous 3 months.164 Similarly, 51 percent of those identified using the PRIME-MD screening tool in a 1995 study were already on antidepressants.165 The identification of such a large proportion of already identified, but untreated or under-treated, depression patients in screening programs may be one reason why ongoing depression care management and treatment options— such as counseling and mental health referrals—appear necessary to gain health benefits in screening unselected adult populations. In essence, these screening programs are providing the additional monitoring and needed supports to effectively treat depression patients in primary care.

Comparison with reviews of depression care management interventions. Since most of the screening studies we reviewed involved additional depression care supports, we also examined recent systematic reviews on the effectiveness of depression care management interventions for improving depression in primary care settings. Four meta-analyses looked at the effectiveness of disease management or collaborative care programs and found them generally effective,166–169 and cost-effective.170 Additional publications have attempted to determine particular components of effective programs.101,171–173 All of these authors identified several care components as effective: 1) care management by a nonphysician working with the primary care physician (sometimes referred to as case management); and 2) collaborative care between physicians and mental health clinicians.101,171–173 Solberg enumerated two additional effective components: 1) education and support of patients for self-management, and 2) attention to patient preferences.171 These program components are generally consistent with the depression care supports we found to be part of successful screening programs in this review. Programs that did not have an effect on depression remission tended to be less intensive initiatives that did not include additional staff directly supporting patient care.101

Although none of these reviewers of depression care management programs identified screening as a necessary or important component, it still bears examination. A 2006 editorial identified 10 trials of depression management programs published since 1995^173^ and identified common components of the programs, such as whether they employed case management, whether they identified patients through screening, and the level of involvement of specialty mental health providers in the care of the patients. We used this model, expanding the table to include two other dimensions of potential importance identified in this review: whether the trial focused on newly-identified cases of depression and whether the trial targeted older adults. We expanded the table to include additional studies that were identified in any of the reviews described above,101,166–169 or included in the current review which addressed outpatient depression management components beyond clinician information or education and were without obvious quality concerns (Table 11). Effective trials, shown on the top half of the table, are those in which a significant treatment effect was seen at some time point for at least one of the main depression outcomes of interest. The ineffective trials are listed in the bottom section of the table and did not show significant treatment effects.

Table 11 Elements of depression management interventions166,168,169,173,193

Trial | Evidence- based guideline? | Patients identified through screening? | Enhanced patient education? | Employed case mgmt? | Level of mental health specialist involvement | Newly-ID’d depression episode?^†^ | Older Adult Focus?
Effective Programs
Oslin 2003^194^ | Yes | Yes | Yes | Yes | High | Unclear | No
Datto 2003^195^ (pilot for Oslin) | Yes | No | Yes | Yes | High | Mix | No
Katon 2004^196^ (Diabetes + Depression) | Yes | Yes | Yes | Yes | Medium | Mix | No
Bruce 2004^183^ | Yes | Yes | Yes | Yes | High | Mix | Yes
Alexopoulis 2005^177^ | Yes | Yes | Yes | Yes | Medium | Mix | Yes
Fortney 2006^197^ | Yes | Yes | Yes | Yes | Medium | Mix | No
Wang 2007^198^ | Yes | Yes | Yes | Yes | High | Mix | No
Rubenstein 2007^116^ | Unclear | Yes | Unclear | Yes | Unknown | Mix | Yes
Unutzer 2002^199^ | Yes | Yes | Yes | Yes | Medium | Mix | Yes
Dietrich 2004^200^ | Yes | No | No | Yes | Medium | Mix | No
Hedrick 2003^201^ | Yes | Yes | Yes | Yes | High | Mix | No
Rost 2001:^109, 191^ newly identified | Yes | Yes | Yes | Yes | Medium | Yes | No
Katzelnick 2000^202^ | Yes | Yes | Yes | Yes | Medium | No | No
Hunkeler 2000 176,203 (IMPACT) | Yes | No | Yes | Yes | Low | Yes | No
Wells 2000^110^ | Yes | Yes | Yes | Yes | Varied | Mix | No
Simon 2000^204^ | Yes | No | Yes | Yes | Low | Yes | No
Peveler 1999: Nurse counseling205 | No | No | Yes | Yes | None | Yes | No
Banerjee 1996^206^ | Unclear | Yes | No | Yes | High | Yes | Yes
Schulberg 1996:^207^ IPT | No | Yes | Yes | No | High | Yes | No
Schulberg 1996:^207^ Nortriptyline | Yes | Yes | Yes | Yes, by other physician | Low | Yes | No
Katon 1995, 1996^208,209^ | Yes | No | Yes | Yes | High | Mix | No
Katon 1999^210^ | Yes | No | Yes | Yes | High | No | No
Blanchard 1995^211^ | No | Yes | No | Yes | Medium | Mix | Yes
Summary | 18/21= Yes (86%) | 16/23=Yes (70%) | 19/22=Yes (86%) | 22/23=Yes (96%) | 17/22=Med− High (77%) | 7/22=Yes (32%) | 6/23=Yes (26%)
Ineffective Programs
Ell, 2007^212^ (Home Health) | Yes | Yes | Yes | Yes | High | Mix | Yes
Finley 2003^213^ | Yes | No | Unclear | Yes | None | Yes | No
Swindle 2003^160^ | Yes | Yes | Yes | Yes | Low | Mix | No
Capoccia 2004^214^ | Unclear | No | Yes | Yes | None | Yes | No
Adler 2004^215^ | Yes | Yes | Yes | Yes | None | Mix | No
Dobscha 2006^216^ | Yes | No | Yes | No, “decision support team” | Low | Mix | No
Brook 2005^217^ | Unclear | No | Yes | No | None | Yes (new AD) | No
Rollman 2002^218^ | Yes | Yes | No | No | None | Mix | No
Rost 2001:^109^ previously detected | Yes | Yes | Yes | Yes | Medium | No | No
Simon 2000:^204^ Feedback only | Yes | No | Yes | No | None | Yes | No
Peveler 1999: Pt. Educ only205,219 | No | No | Yes | No | None | Yes | No
Callahan 1994^112^ | Yes | Yes | Yes | No | None | Mix | Yes
Dowrick 1995^220^ | Yes | Yes | No | No | None | Mix | No
Thompson 2000^221^ | Yes | No | No | No | None | Mix | No
Whooley 2000^111^ | Unclear | Yes | Yes | No | None | Mix | Yes
Brown 2000:^222^ Academic Detailing | Yes | No | No | No | None | Mix | No
Goldberg 1998:^223^ Academic Detailing | Yes | No | No | No | None | Mix | No
Mann1998:^224^ assessment + feeback | No | No | No | No | None | Mix | No
Mann 1998:^224^ above+ nurse follow-up care | No | No | No | Yes | None | Mix | No
Coleman 1999^225^ | No | No | Yes | Yes | None | No | Yes
Bashir 2000^226^ | Yes | No | Yes | No | None | Mix | No
Solberg 2001^227^ | Yes | No | Yes | Yes | None | Mix | No
Arthur 2002^228^ | No | Yes | No | No | Assessment only | No | Yes
Summary | 15/20= Yes (75%) | 9/23=Yes (39%) | 14/22=Yes (64%) | 9/23=Yes (39%) | 2/23=Med − High (9%) | 5/23=Yes (22%) | 5/23=Yes (22%)

† No=only previously treated, Mix=both

One of the most striking differences between the effective and ineffective programs was that 96 percent of the successful programs involved some kind of case or care management, compared to only 39 percent of the unsuccessful programs. One important benefit of case management is the ability to closely monitor symptoms and side effects, which in turn can help guide the depression management.53 Also, 77 percent of the successful programs had medium-to-high levels of mental health specialist involvement, compared to only 9 percent of the unsuccessful programs. Regarding screening, 70 percent of the successful programs involved systematic screening and 39 percent of the unsuccessful programs involved screening. The data are more sparse, but just as striking, for studies focusing on older adults. All six of the successful programs targeting older adults employed case management while only two of the five (40 percent) unsuccessful programs did. All five of the successful programs reporting on mental health specialty involvement also had medium to high levels of mental health specialty care involvement, while only one (20 percent) of the unsuccessful programs did. All of the successful, and all but one of the unsuccessful, programs employed systematic screening. So, while successful programs appear more likely to have a screening component than unsuccessful programs, other components showed more striking differences between the successful and unsuccessful programs. Thus, from this exploratory analysis, it appears that while screening may be useful to such programs, other components may be more critical to the success of depression management programs.

Harms of screening. No evidence was found that screening for depression is harmful. Theoretical harms include any stigma or distress associated with labeling, false positives, and identifying many more cases of mild, potentially transient depression. This could increase the risk of overuse of antidepressants and create unnecessary patient costs and potential side effects, as well as unnecessary societal or health system costs. Because effective screening would likely increase the number of depressed patients using antidepressants, the probability of serious adverse events associated with antidepressant use should also be weighed carefully against their potential benefits.

Cost-effectiveness. A cost-effectiveness study of a primary care depression care management intervention including a one-time screening component (which was included in our review)174 found that the intervention was cost-effective in patients who had not been previously identified as depressed. They estimated the incremental cost effectiveness ratio for enhanced care compared to usual care ranged from $9,592 to $14,306 per QALY over the course of two years.174 However, this intervention was not continued after the trial ended, despite its promising results, raising doubts about the feasibility of this program without other facilitating factors that were present when the studied was conducted.

## Effectiveness of Depression Treatment in Older Adults

Both antidepressants and psychotherapy appear to be effective in treating depression in older adults. Two good-quality meta-analyses120,121 published in 2000 and 2006 concluded that antidepressants are effective in treating depression in older adults, with estimated OR of 1.96 (CI: 1.39, 2.78) for SSRIs and 1.92 (CI: 1.07, 3.45) for other second generation antidepressants, compared with placebo controls. The Cochrane review published in 2000 reported 28 to 50 percent of older adults randomized to antidepressant treatment recover from depression compared with 10 to 25 percent in the placebo control groups. These recovery rates appear to be comparable to recovery rates in general adult samples: recent primary care treatment effectiveness data in adults suggests that roughly 25 to 30 percent are likely to achieve full remission and an additional 15 to 30 percent would show a response to treatment over the course of 3–6 months.53,79 Additionally, two good-quality meta-analyses120,122 concluded that psychotherapy is effective in treating depression in older adults. In these studies, depressed older adults were more than twice as likely to achieve remission than those who were not treated, with the ORs estimated at 2.47 (CI: 1.76, 3.47) and 2.63 (CI: 1.96, 3.53). Effect sizes estimates range from 0.72 to 1.09.

Although antidepressants and psychotherapy are effective in treating depression in older adults, most of these trials involved relatively healthy patients with mild-to-moderate levels of depressive symptomatology. Many older depressed patients may have significant challenges, including medical co-morbidities, that affect the generalizability of this research. The use of depression care management interventions, particularly psychosocial treatments, could be important to achieving real-world benefits in older and younger adults.175 Primary care-based collaborative care approaches such as those tested by the PROSPECT and IMPACT trials, involving treatment teams including primary care clinician, depression care manager, and a mental health specialist, have improved depression outcomes and functioning in depressed older adults, with persistent benefits at up to 2 years.176,177 The IMPACT intervention was also found to be cost-effective.178 Considered as a whole, data on depression care management programs suggest a potential benefit for depressed patients of all ages and support calls for better links between process measures for quality care in depression, such as HEDIS, and health outcomes.179

## Treatment-Associated Harms in Adults and Older Adults

Controversy has existed about whether antidepressants aggravate suicide risk beginning with the use of tricyclic antidepressants (TCAs) and continuing through the introduction of second-generation antidepressants, particularly SSRIs. The proposed mechanism of action is reduction of psychomotor retardation before affect improvement and perhaps inducement of akathisia, which has been associated with increased suicidality, and which has been reported in up to 25 percent of SSRIs users early in SSRI treatment.180 Treatment effects can be hard to determine, however, since suicidal ideation itself is a common feature of depressive disorders, occurring in 50 to 60 percent of those with MDD.57

We found no definitive evidence from seven separate exhaustive meta-analyses of short-term, placebo-controlled trials that second-generation antidepressants (primarily SSRIs) increase the risk of completed suicide in adults. While reassuring, these results are not conclusive, given the power limitations to detect such a rare event. Others have noted elsewhere that, given these rare event rates, 300,000 persons would need to be studied to have the power to detect a two-fold difference in suicide deaths.129 When we calculated absolute risk differences for suicide in MDD patients treated with SSRIs or placebos, the risk differences were modest (1.12 and 1.8 per 10,000 persons treated), with 95 percent confidence intervals that crossed zero (Table 9). Thus, these results are most accurately considered consistent with some increase in short-term risk, a mild protective effect, or no increased risk for suicide in patients with MDD treated with SSRIs. Longer-term observational studies did not suggest markedly different rates of suicide over six or more months after antidepressant treatment initiation than most meta-analyses of shorter term trials, and one observational study suggested a similar rate of suicide-related deaths across the first six months of treatment;129 both of these findings provide some reassurance that the shorter-term clinical trials are not providing drastic underestimates of suicide-related risk due to patient selection or other factors.

Meta-analyses also suggested no increase in non-fatal suicide attempts or serious self-harm behaviors, except in three analyses of adults treated with SSRIs or other second-generation antidepressants. In a careful meta-analysis conducted by the manufacturer that utilized independent, adverse event assignment by experts, definitive suicidal behavior (all events consisting of suicide attempts with no completed events or preparatory acts) was increased (OR 6.7; CI: 1.10, 149.40) in 3455 adults with MDD on paroxetine compared with 1978 on placebo-treatment. The absolute risk difference was 26.8 non-fatal suicide attempts or serious self-harm behaviors per 10,000 person treated with paroxetine (Table 9). The estimated NNT-H is 373 (CI: 208, 1818). Although this analysis included all adults with MDD, the risk was driven by young adults (18 to 30 years) in which eight of 11 events occurred. At the time these data were released, the manufacturer stated that the company “believes that young adults, particularly those with MDD, may be at increased risk for suicidal behavior during treatment with paroxetine” and recommended that labeling amendments should be undertaken.131 In two other meta-analyses, odds of suicidal behaviors were doubled (OR 2.70, CI: 1.22, 6.97) in a meta-analysis of 10,557 adults being treated for all indications on SSRIs compared with 7856 adults on placebo130 and in a 2006 FDA analysis restricted to young adults (18 to 24 years) being treated with second-generation antidepressants, including SSRIs, for any psychiatric indication (OR 2.31; CI: 1.02, 5.64, treatment vs. placebo-control).125

Any risks of self-harm that may be associated with second-generation antidepressant use are strongly age-related. In older adults (ages 65 and older), antidepressant use was protective for all suicide-related events in the FDA 2006 meta-analysis looking across the lifespan. Other studies outside the scope of this review (since absolute risks could not be assessed and/or the focus was a high-risk group) generally confirm a beneficial impact of antidepressants on suicides in older adults. Juurlink and colleagues conducted a nested case-control study using linked population-based coroners’ records, patient-level prescription data, physician billing claims, and hospitalization data on 1,264,686 Ontario residents 66 years of age and older from 1992 to 2000.^181^ While there was a small increased risk of suicide only during the first month of SSRI therapy compared with other antidepressants (after propensity-score adjustment for measured confounders), the absolute risk for suicide among treated patients was very low and the majority (68 percent) of older persons committing suicide had received no antidepressant therapy during the six months prior to death. In 101 Israeli older adults with MDD hospitalized for suicide attempts, fewer (42 percent) were exposed to antidepressants prior to their suicide attempt than matched controls of patients with MDD admitted to the hospital who had not attempted suicide (52 percent on antidepressants, p=0.02).182 Some recent observational studies reviewed by others that did not meet our inclusion criteria (by reporting only relative as opposed to absolute suicide-related risks in a comparative effectiveness study) confirm findings about timing of the greatest suicide-related risks. A matched case-control study of patients treated with antidepressants in UK general practices from 1993–999 suggests that odds of suicidal behaviors are increased during the first month (particularly the first 1 to 9 days) after a new antidepressant prescription.148 These findings coincide with those from a large prospective cohort study in the US reviewed here.129

We did not generally emphasize findings for suicidal ideation combined with behaviors, as attempts and ideation appear to be distinctly affected. Nor did we include evaluations focused on individual drugs nor comparisons between drugs since most of these involve indirect comparisons (i.e., comparisons using different populations from different RCTs to supply treatment and comparison). However, we made an exception by reporting findings from the paroxetine RCTs separately due to the quality of the recent GSK analysis using blinded, expert event classification which indicated increased risk of suicide attempts in young adults, particularly those with MDD, and due to a consistent pattern of increased risk (significant or not) with paroxetine in drug-specific analyses in the most recent FDA review.125 While small numbers of events make actual estimates of increased risk unstable, these findings are certainly worthy of current clinical attention and future research.

A puzzling finding was the discrepancies between the 2006 FDA report compared with findings from multiple other reviews, including an earlier FDA report. A more detailed consideration of these issues is included in Appendix G Table 4 “Quality concerns/Comments” column and Appendix G Table 9.

The support for care and close monitoring suggested for effective depression screening and management program in this report may also reduce potential harms. In older adults, the PROSPECT (Prevention of Suicide in Primary Care Elderly) trial found that suicidal ideation and depression severity were more effectively reduced and remission achieved more commonly in patients receiving treatment management using practice-based depression care managers than in those receiving usual care.183 While careful monitoring of patients, particularly younger patients, during early treatment with antidepressants seems prudent, screening for suicidality would be a more direct means of detecting those at risk of suicide and has been addressed in a separate report for the USPSTF.184 Among clinically depressed primary care patients in need of treatment, a small proportion 0.5 percent are at high risk of suicide, while about 10 percent have active thoughts but no clear plans.185 This supports the idea that there may be high-risk groups, which could be an important area for future review by the USPSTF.

In looking for increased medical risks associated with antidepressant use in older adults, we found evidence that risks of UGI bleeding may be increased about two-to-three fold in adults currently using SSRIs, particularly older adults, those with a history of GI bleeding, and those on SSRIs with higher degrees of serotonin reuptake inhibition. Concurrent use of NSAIDs, and to a lesser extent low-dose aspirin and other anticoagulants, appeared to further increase bleeding risks. These findings may have implications for all adults, but particularly for vulnerable older adults or those with a history of GI bleeding, given the prevalence of use of analgesic medications (over-the-counter as well as prescription) for therapeutic and preventive reasons. Recent reports of a small but significant two-fold increase in falls and fractures with SSRI use in adults 50 years and older155 suggest that clinicians should remain aware of new research about the risk-benefit ratio for different medication classes as they consider appropriate antidepressant treatment choices, particularly in older adults.

Relatively large numbers of patients discontinued therapy (16 to 29 percent) with longer-term discontinuation in community-based trials similar to population-based studies. The high rates of discontinuation in clinical trials would be reduced in actual primary care using medication counseling (not just handouts)106 or care management interventions, which include frequent contacts to titrate medications, monitor symptoms, and address adverse effects.75 Discontinuation due to adverse events (5 to 12 percent) might be somewhat amenable to these approaches.

## Limitations of the Review and the Literature

We limited questions of harms of treatment to existing systematic reviews, meta-analyses, and large prospective observational studies examine harms of antidepressants. We examined a limited set of pre-specified rare but serious adverse effects and also examined discontinuations (total and due to adverse events) to represent less severe, more common adverse events for all adults. For older adults, we considered a broader range of serious adverse events (serious medical events such as GI bleeding). We took this approach given the overall purpose of the report which was to provide data to estimate overall benefits and harms from screening (and subsequent treatments) for depression. Also, this approach was necessary given the very large body of international evidence on second-generation antidepressants and on depression in general. Our approach, however, omitted information from trials of more recently approved medications (e.g., duloxetine) and would not have captured rare or emerging serious medical effects that are not already well summarized in the literature or studied in large observational studies. None of the abstracts and individual papers reviewed for inclusion in this review suggested that our approach led to significant omissions.

Given that commonly available antidepressants have comparable efficacy in the majority of patients seen in primary care,57,92 clinicians may select medications based on the consequences of specific adverse effects for individual patients (for example, dizziness in an older adult with poor balance or nausea in a patient with dyspepsia).75 Detailed considerations of potential side effect differences were beyond the scope of this report but are considered elsewhere.57,92

Much of the evidence for serious suicide-related harms derives from short-term RCTs conducted for drug development and submitted to regulatory agencies. This evidence may not be generalizable to primary care due to exclusion of the most severe (or suicidal) patients, high dropout rates (which can be due to a host of factors, including withdrawal by a concerned clinician),57 recruitment strategies outside of health care settings that tend to get motivated patients, sponsorship by the drug industry (which have been shown to be more likely to demonstrate positive effects than independent studies).142 Also, high placebo effects are seen in some trials, and may be due to a host of factors, including the trend towards less severely depressed patients in more recent clinical trials and the ameliorating effect on depression of the support from being in a trial.180 The very large body of evidence from hundreds of small studies makes quality review, including careful checking for completeness and systematic inclusion across reviews impossible, and undoubtedly resulted in data from some trials being included more than once, particularly across reviews. We did not attempt to summarize data between meta-analyses due to the potential for duplication as well as difference in methods.

Many reports attempt to determine the comparative harm of medications, particularly related to suicide events. Limitations of this literature are lack of a true control in a condition with increased suicide risk on its own, use of indirect comparisons, and serious concerns from confounding by indication in non-randomized comparisons, which makes it difficult to interpret results reporting either differences or similarities between medications. Jick et al, for example, found that medication differences in suicidal events were largely due to confounding by indication in a case-control analysis of 143 suicide cases and 1000 randomly selected antidepressant users from the large UK General Practice Research Database. Differences in suicide risk were no longer present after controlling for history of suicidality and number of previous antidepressant treatment episodes.127 Others have also demonstrated confounding by indication in observational studies of suicidality and antidepressant use.150

We did not consider ecologic data on suicidality, as many other reviewers have, since it does not meet minimum USPSTF criteria for study designs that indicate causality. However, US data indicating a decrease in the suicide rate signal from 1988 to 2002 (after being stable from 1960–988), during the same time fluoxetine prescriptions increased 15-fold, are consistent with no increased risk due to second generation antidepressants, an increased risk of suicidal behaviors (such as attempts) but not suicide, or increased suicide risk only with specific antidepressants or in specific subgroups (such as younger age).186

Our review did not include questions examining a high-risk approach to screening (e.g., screening or treatment results focused specifically on high-risk groups, such as those with a history of depression, coronary artery disease, or other medical conditions). NICE has recommended screening for depression in primary care and general hospital settings only for those in high-risk groups, but these recommendations were based on consensus rather than on evidence.57 The presence of medical and psychiatric co-morbidities may affect depression outcomes, but we did not examine this question.

Little data were available to specifically examine the impact of race/ethnicity in depression screening or treatment. However, a pooled analysis of 104 paroxetine trials in 14,875 adults with all indications was undertaken to specifically examine response and tolerability in minority populations (Hispanic, Asians, African Americans). This study reported no treatment by minority group interaction for depressed patients, and a similar speed or response and adverse effects across groups.187 Authors note very low power to detect differences due to the low number of minorities recruited as subjects in these studies, and suggest much greater effort to ensure minority representation in future clinical trials.

Another limitation of our review is the narrow scope of the question of efficacy of depression treatment in older adults (KQ3), for treatments we judged to be widely available to primary care providers, and in samples that are similarly to general primary care populations. Most of these data were limited to short-term treatment efficacy trials, and therefore the long-term treatment effectiveness is unknown, as is the effectiveness of these treatments in general primary care populations, as generally delivered in primary care.

For the purposes of this review, we sought to answer the focused question of whether commonly available treatments can improve depression in older adults. Therefore, we did not review trials examining the best way to deliver treatment to older adults, such as trials examining collaborative care approaches. We also excluded trials that compared different treatment agents with each other, as these did not address the focused question of whether there are efficacious treatment agents for this group of adults. We also excluded trials of physical treatments, such as ECT and TMS, as we felt these may not be widely available for referral from primary care. Finally, we also excluded trials that were limited to older adults with specific medical conditions, such as those who had recently suffered a stroke or myocardial infarction because these samples were not broadly representative of primary care the population.

Studies addressing maintenance and relapse prevention were beyond the scope of this review, but are an important area of research for clinicians.

## Future Research

Large-scale, randomized controlled trials, or at least well-controlled clinical trials of depression screening programs with an unscreened control group and health outcome ascertainment (including response, remission, and health risks), would be very useful in answering the role of depression screening in improving overall depression care management.

Better understanding of the necessary and sufficient components of depression care management programs (screening; frequency of monitoring; type of monitoring; training of monitors; role of physicians and non-physician providers, etc) that are directly relevant to improving depression outcomes in primary care would help clarify the key parts of such program.

Updated information on the frequency that depression cases are missed in current primary care, and their level of severity (e.g., major depressive disorder, dysthymia, minor depression) would help determine the current need for active case finding approaches. Consideration of how such under-diagnosis varies between different primary care settings would be key.

Better understanding of other high-risk groups for suicidal behavior and self-harm beyond young age and disease severity (MDD) would be very beneficial. Other work, for example, suggests that treatment failure may be related to underlying bipolar disorder.188

Better understanding of suicide and self-harm risks in various subgroups according to medication response and adverse effects (e.g., nonresponders vs. responders) could help target suicide prevention efforts. The FDA’s report found results for suicidal behavior that were consistent with the increased risk occurring primarily in those who do not show a clinical response to treatment.124,125

Pharmacogenetic studies, such as information on metabolizer genotypes (e.g., CYP2D6), and the impact of genetic variability and of medication interactions on antidepressant efficacy, tolerability, and safety could help in targeting depression treatments to increase benefits and reduce adverse effects.57,151

Better understanding of the impact of depression care management programs on adverse effects and harms would help determine net benefit of these approaches.

Further understanding of risks associated with long-term antidepressant use, particularly among older adults and those taking other medications, is greatly needed.

## Conclusions

Good evidence supports the health benefits of programs combining depression screening and feedback with the support of additional staff to provide some depression care in adults visiting primary care. However, it is unclear that screening itself is a necessary part of such a program, and available evidence does not support screening alone in the absence of additional staff providing case management or mental health treatment functions. Variability among primary care settings in the rates of under-detection may further confuse one’s understanding of the role of screening. The most comprehensive programs included clinician training and treatment protocols provided at the point of care, patient educational materials, office staff training and participation in providing post-visit follow-up, and available mental health referral; the mechanisms by which these interventions produce benefits are likely multiple, but could include enhanced treatment adherence through closer monitoring of treatment tolerability and response, treatment adjustments, and psychosocial support. Closer monitoring may also be important for reducing uncommon, but potentially serious, adverse events. Depression screening and feedback without additional staff to provide some of the depression care are unlikely to offer additional benefits above usual care.

Older adults benefit from antidepressants and/or psychotherapy comparable to (or almost as well as) younger adults. Older depressed adults have a reduced risk of suicide-related adverse events (ideation or behaviors) during antidepressant treatment, in contrast with younger patients. However, risks for upper gastrointestinal (UGI) bleeding, a serious medical side-effect, may be elevated at least two-to-three-fold in older patients on SSRI antidepressants, particularly in those with a history of UGI bleeding or concurrent use of NSAIDs. Antidepressants with more potent serotonin-uptake inhibition may further increase risk. These findings may have relevance for all adults, particularly older adults, given the prevalence of SSRI, NSAID, and low-dose aspirin use.

Concerns about rare, but very serious suicide-related antidepressant treatment harms with the potential for significant public health harm due to widespread antidepressant use, have prompted repeated meta-analyses. The most current evidence on completed suicide does not demonstrate an effect of second-generation antidepressants compared with placebo, but is also consistent with mild protection or some increased risk. Although results for suicidal behavior and ideation are similar for the most part, several meta-analyses suggest a true short-term increase in suicidal behavior in young adults (aged 18–9 years) on antidepressants, particularly those with major depressive disorder and those taking paroxetine. Thus careful monitoring during early treatment, particularly in younger adults, seems prudent.