# Results

## Key Question 1: Is there direct evidence that screening for depression among adults and older adults in primary care reduces morbidity and/or mortality?

Summary of findings. One fair-quality randomized controlled trial of primary care patients identified by the previous systematic review108 compared screening’s impact with a non-screened usual care group (Table 3).10 Nine hundred sixty-nine patients were randomized, 863 of whom completed a post-visit interview. A subset of the randomized patients from one of the two sites, over-sampling those with depressive symptomatology at baseline, were re-assessed after 3-months.

Table 3 Summary of results for key question 1: study examining health outcomes of a screening program in a primary care setting10

| Screened (N=587) | Unscreened (N=276) | Significance
Percent female | 71% | 71% | NS
Mean age | 59 | 56 | NS
Percent Hispanic | 60% | 58% | NS
Annual income ≥ $16,800 | 24% | 24% | NS
Baseline depression diagnosis^*^ | 13.1% | 13.8% | NS
3-mo depression diagnosis^*,†^ | 37% (N=153) | 46% (N=65) | p=0.19
3-mo ≤ 1 depression symptom, among baseline depressed^†^ | 48% (N=67) | 27% (N=30) | p<0.05
Mean symptom count reduction from baseline, controlling for baseline depression severity^†^ | 1.6 (N=153) ‡ | 1.5 (N=65) ‡ | p=0.21

NS-not significant or no p-value given

* Included major depressive disorder, dysthymia, or minor depression

† Follow-up attempted on 230 only: all 101 patients with baseline depression diagnosis and random sample of 129 patients without depression, all from Texas site.

‡ Ns not reported directly but inferred from those provided for 3-mo depression diagnosis

At follow-up, screened patients who were depressed at baseline were more likely to be in complete remission than unscreened depressed patients (≤1 symptom of depression in 48 percent of those screened compared to 27 percent of those not screened, p<0.05). However, when the entire follow-up sample was considered (not merely those who were depressed at baseline), screened and unscreened samples did not differ in the proportion of patients meeting DSM-III-R criteria for a depressive disorder nor in the average change in number of depression symptoms at follow-up. The study’s follow-up procedures may have limited their power to detect group differences and introduced bias. This study was also at risk for intervention contamination because providers saw patients in both study conditions. (See Appendix F Table 1 for key elements of the trial and Appendix G Table 1 for detailed information)

Study details. Table 4 lists brief information regarding depression screening and interview instruments described in this and subsequent sections. Williams and colleagues10 conducted the only study that compared a screened sample to a non-screened sample, which is the optimal comparison for looking at the effects of mass screening. Participants were recruited at two sites: a VA general internal medicine clinic in San Antonio, Texas and a university-affiliated general internal medicine clinic in Washington, DC. Patients were randomized either to usual care, to complete a brief (one item) depression screener, or to complete the Center for Epidemiologic Studies-Depression Scale (CESD) before a scheduled appointment. In both screening groups, the results were placed in the patient’s chart on a bright orange form, regardless of whether the screening test was positive or negative. Providers saw both intervention and control participants and therefore contamination is possible. All providers were given a guide for managing depression in primary care and a continuing education session on diagnosing depression. No other depression care support was provided.

Table 4 Depression symptom rating scales and diagnostic interview tools

Instrument | Abbreviation | Number of items | Scoring range | Typical Cut-point
Symptom Rating Scales
Beck Depression Inventory | BDI | 21 | 0–63 | 11 mild 17 borderline clinical 21 moderate 31 severe
Center for Epidemiological Studies Depression Screen | CESD | 20 | 0–16 | 16
Geriatric Depression Scale | GDS GDS-15 | 30 15 | 0–30 0–15 | 14 5
Hamilton Depression Rating Scale (Clinician rating tool) | HAMD | 21
Montgomery-Asberg Depression Rating Scale (Clinician rating tool) | MADRS | 10 | 0–60 | None found
PRIME-MD Patient Health Questionnaire Brief | PHQ-9 | 9 | 0–27 | 5 mild 10 moderate 15 moderately severe 20 severe
Primary Care Evaluation of Mental Disorders, Mood Module screening items | PRIME-MD brief screen | 2 | 0–2 | 2
Composite International Diagnostic Interview, two “stem” items for depression section. | CIDI 2-item | 2 | 0–2 | 2
Diagnostic Interview Tools
Composite International Diagnostic Interview | CIDI | (varies, depending on responses) | Diagnostic code | NA
Primary Care Evaluation of Mental Disorders, Mood Module | PRIME-MD | (varies, depending on responses) | Diagnostic code | NA

NA-not applicable

After the baseline visit with the provider, research staff attempted to interview all randomized (n=969) participants by phone to determine whether they met DSM-III-R criteria for depression; 863 (89.1 percent) completed the post-visit interview. Three months after the index visit, they attempted to contact 230 participants (26.7 percent, 230/863), which included all patients at one study site who met DSM-III-R criteria for a depressive disorder at the post-visit phone interview (n=101), and a random sample at the same site (n=129) who did not meet criteria for depression, over-sampling those who had depressive symptoms without meeting DSM-III-R criteria for MDD, Dysthymia, or Minor Depression. The completion rate for the 3-month follow-up was 94 percent. Because only a subgroup of the non-depressed patients was followed from only one study site, the health outcomes for this study cannot be considered randomized comparisons. Data were not presented on the baseline comparability between the follow-up sample and the original sample, or between the intervention and control groups among those in the follow-up sample, so we can not be as certain that follow-up group differences represent the intervention’s effect.

According to the table of baseline characteristics, participants were primarily middle-aged females of Hispanic background and were largely low-income, with only 24 percent of the sample reporting annual incomes of ≥$16,800 at that time (late 1990s). They also had high rates of positive screening tests (41 percent on the single-item screener and 33 percent on the CESD) and confirmed DSM-III-R depression diagnoses (13 percent).

This study found mixed results. Among patients who were depressed at baseline, patients in the two screening groups were more likely to have fully recovered from depression (i.e., reported ≤ one depression symptom) at 3-month follow-up than those who were not screened (48 vs. 27 percent, p<0.05). Among the entire follow-up sample, however, the proportion meeting DSM-III-R criteria for depression was similar in the combined screening groups (37 percent) and in the usual care group (46 percent) at three month follow-up (p=0.19), though they lacked adequate power to detect a population-level impact (n=218). Also, after controlling for baseline severity of depression (which differed between the screened and usual care groups in the full randomized sample), the mean reduction in DSM-III-R symptom counts was similar for the two groups (1.6 in screened vs. 1.5 in unscreened after controlling for baseline severity, p=0.21). While screening improved health outcomes in depressed patients, the effect was not large enough to create group differences at the level of the full follow-up sample. Since the follow-up sample included a considerably larger proportion of people who were depressed or symptomatic than the full sample, the effect would be even weaker in a full sample of primary care patients.

## Key Question 1a: What is the impact of clinician feedback of screening test results (with or without additional care management support) on depression response and remission in screen-detected depressed patients receiving primary care?

Summary of findings. Two good-quality109,110 and six fair-quality111–116 randomized controlled trials reported providing the impact of giving depression screening results to clinicians on health outcomes in screened populations (Table 5). Four of these studies involved general adult populations (N=1,908)109,110,113,114 and four focused on older adults (N=1,443).111,112,115,116 Four of these were also included in the previous review. 109–112 All studies randomized and/or enrolled patients who screened positive on at least one depression screening instrument which was often administered in the clinic waiting room. Although all patients were screened, feedback of screening test results was only given to providers of patients who screened positive (Appendix G Table 1).

Table 5 Summary of results for key question 1a: studies examining health outcomes of screening results feedback among screen-identified depressed patients in primary care.

Study setting | Approach to intervention beyond screening results feedback | Sample characteristics (N, gender, proportion of sample currently or recently treated for depression) | Length of follow-up | % depressed at follow-up *p<0.05** p<0.01 | | | Scale score decrease from baseline *p<0.05** p<0.01
| | | | IV | UC | † | IV | UC | ‡
General adult populations
Bergus et al, 2005^113^ Rural | None | N=59 Female: 67% (calc) Age: 41 (calc) 38% on meds for depression or anxiety | 10-wk 6-mo | 46% 48% (all NS) | 63% 62% | a a | 5.8 5.7 (all NS) | 5.8 5.0 | h
Jarjoura et al, 2004^114^ Urban, indigent | Improve quality of PCP care; Logistical support for PCP; Other staff provide some dep. care | N=61 Female: 69% (calc) Age: 45 (calc) 0% currently treated | 6-mo 12-mo | — — | — — | | 7.6* 6.5* | 0* 0* | i
Wells et al, 2000^110^ Wells et al 2004^118^ Sherbourne et al189 Multi-site, urban, rural | Improve quality of PCP care; Logistical support for PCP; Other staff provide some dep. care | N=1,356 Female: 71% Age: 44 % treated NR | 6-mo 12-mo 57-mo 24-mo | 40%**\|\| 42%** 38%IG1* 36%IG2 39%IG1 31%IG2 | 50%** 51%** 44%* 44% 34% 34% | b b b b c c | — — — — | — — — —
Rost et al, 2001^109^ Rost et al, 2000^190^ Multi-site, urban, rural Prev. known cases | Improve quality of PCP care; Logistical support for PCP; Other staff provide some dep. care | N=243 Female: 84%^§^ Age: 43^§^ 100% recently treated | 6-mo | — | — | | 14.5 (NS) | 11.0 | j
Rost et al, 2001^109^ Rost et al, 2000^190^ Rost et al, 2002^191^ Newly identified cases | Improve quality of PCP care; Logistical support for PCP; Other staff provide some dep. care | N=189 Female: 84%^§^ Age: 43^§^ 0% recently treated | 6-mo 24-mo | — 26%* | — 59% | — d | 21.7* — | 13.5* — | j
Older Adult Population
Bosmans et al, 2006^115^ Urban, the Netherlands | Improve quality of PCP care | N=145 Female: 60% Age: 65 (calc) 0% currently treated, 83% history of depression | 12-mo | 57% (NS) | 52% | e | 7.8 (NS) | 7.2 | k
Whooley et al, 2000^111^ Urban | Improve quality of PCP care; Other staff provide some dep. care(minimally implemented) | N=331 Female: 61% Age: 76 (calc) 20% on antidepressant past 12 months | 24-mo | 42% (NS) | 50% | f | 1.8 (NS) | 2.2 | l
Callahan et al, 1994^112^ Urban | Improve quality of PCP care; Logistical support for PCP | N=175 Female: 76% Age: 65 11.4% on antidepressant | 6-mo 9-mo | 87% — (all NS) | 88% — | g — | — — (all NS) ¶ | — — | j j
Rubenstein et al, 2007^116^ Urban VA | Logistical support for PCP; Other staff provide some dep. care | N=792 (n=206 screening positive for depression) Female: 3.2% Age: 74 % treated NR | 12-mo⫧ | | — | — | 3.7* | 2.7* | l

calc-calculated; NS-not significant; IG-intervention group; NR-not reported; IG1=Psychotherapy, IG2=Medication Support

† Diagnostic Methods: a: PHQ ≥ 6; b: CIDI 2-item; c=CIDI full interview; d=CESD ≥ 15; e=PRIME-MD; f=GDS≥ 6; g=HAM-D≥ 16

‡ Scale Score Instrument: h=PHQ-9; i= BDI, standardized on control group change; j= CESD; k= MADRS; l= GDS

§ These statistics refer to the entire study sample. Total sample=479, data presented on the 432 shown in this table.

|| Results for the two intervention groups were reported combined at 6- and 12-month follow-ups, and reported separately at 24- and 57-month follow-ups.

¶ Reported that groups did not differ at 6 or 9 months but did not provide exact scores

⫧ Results only for subgroup that screened positive for depression

In general adult populations, four trials screened a total of 38,843 primary care patients to detect 1,908 depressed adult patients (Table 5). Bergus and colleagues conducted a small, fair-quality RCT in a rural setting which did not support the effectiveness of screening programs with no depression care supports beyond simple feedback of screening results.113 Another small, fair-quality RCT improved depressive symptomatology, but had a highly selected participant sample because they only enrolled screened adults with newly-detected depression (i.e., patients already known to be depressed were excluded from the trial, as were those who were actively seeking treatment for depression).114 In this trial clinicians were given a detailed depression treatment protocol during the visit that included a recommended follow-up schedule and educational materials for the patient, and also received logistical support from other staff for scheduling follow-up visits and facilitating referrals. Two trials with considerably higher intensity interventions involving depression care by other staff were effective in improving depression outcomes,109,110 particularly for adults with newly detected depression. These trials included such elements as intensive clinician and office support staff training, support staff or specialty mental health provider participation in ongoing depression care, and multiple follow-up contacts. See Table 6 for a summary of intervention elements included in each study. It was impossible to determine the degree to which the screening components contributed to the positive effects in the studies that also included additional depression care supports beyond simple screening and related interventions targeting the primary care provider.

Table 6 Summary of depression care support elements provided in programs of depression screening with feedback of results to providers.

| | General Populations | | | | Older Adult Populations
| | Bergus et al113 | Jarjoura et al114 | Wells^*^ et al110,118 | Rost et al109,190,191 | Bosmans et al115 | Whooley et al111 | Callahan et al112 | Rubenstein et al116
| Screening results given to provider for review | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Improve Quality of PCP Care | Provider prompted or trained in further assessment | | Yes | | Yes | Yes | Yes
Improve Quality of PCP Care | Provider given generic treatment protocol and/or depression management training | | Yes | Yes | Yes | Yes | Yes | Yes
Improve Quality of PCP Care | Provider given patient-specific treatment recommendations | | | | | | | Yes
Logistical Support to PCP Provider | Support or study staff provided proactive logistical help, e.g. with follow-up appointments, referrals | | Yes | Yes | Yes | | | Yes | Yes
Other Staff Provide Some or Most of Depression Care | Psychoeducational Classes | | | | | | Yes^**^
Other Staff Provide Some or Most of Depression Care | Support or study staff provided monitoring and/or case management | | | Yes | Yes | | | | Yes
Other Staff Provide Some or Most of Depression Care | Routine referral to behavioral counseling | | Yes
Other Staff Provide Some or Most of Depression Care | Study, mental health, or other specialty staff provided depression care or medication management | | Partial | Yes | | | | | Partial
Other | Financial commitment by provider’s institution | | | Yes

Trials with statistically significant group differences shown in bold.

* Group differences were significant only for the subgroup or participants with newly identified depression

** This program offered a group psychoeducational class that only 12 percent of the intervention participants attended

In screening focused on older adults, four fairly large-scale trials screened 12,432 primary care patients to identify a total of 1,443 depressed older adults to test the impact of screening feedback with some care supports on remission and symptom reduction. The only trial with a significant treatment effect was also the only trial that expanded the role of other staff to provide depression management functions (in this case, assessment and regular follow-up). None of the trials in older adult patients limited enrollment to patients with newly identified depression. Intervention and usual care groups all showed some improvement from baseline, but only one of the four interventions in these trials improved depression remission rates or symptoms beyond usual care. The trial conducted in the Netherlands,115 provided no extra care support beyond clinician training and provision of a treatment protocol consistent with Dutch depression care guidelines.117 Although this trial did find an increase in the proportion of patients treated with antidepressants, no differences were found in depression remission or symptom severity at 12 months. Another trial offered a psychoeducational group to patients in addition to screening and provider feedback,111 but patient participation in the psychoeducational group was minimal. The intervention group in this trial showed similar rates of depression remission and improvement to those who were simply screened without further intervention. The intervention in a third trial112 included individually-tailored treatment recommendations, educational materials, and three scheduled follow-up visits with the provider. Adherence with follow-up visits was not reported. These supports were ineffective in a medically indigent, largely black, older adult population with multiple medical and psychiatric co-morbidities.112

Finally, the one trial116 that did report an improvement in depression symptomatology among older patients who screened positive for depression involved the assistance of a case manager, who conducted an in-depth assessment and then referred the patient to primary or specialty care or to a multidisciplinary geriatric assessment team for further assessment. The case manager also provided patient education and follow-up. These results were reported in the subgroup of older adults screening positive for depression who were enrolled in a trial that attempted to identify patients with any of five high risk conditions. Therefore, this was not a randomized comparison, and the patient population was limited to patients who scored in a “high risk” range for a number of conditions. It was unclear if patients screening positive for depression only (i.e., none of the other four conditions screened for) could have been eligible for study inclusion. Thus, the generalizability of this trial to general primary care screening for depression in older adults may be limited.

Study details. All eight studies were conducted in outpatient primary care settings, seven in the United States and one in the Netherlands. Study settings included urban, rural, and indigent clinics, and two of the studies involved multiple geographic sites across of the US.109,110 Four of the studies111,112,115,116 focused on screening older adults and will be discussed separately from the others. In all studies, the usual care participants were screened as well as those in the intervention groups, often in the waiting room prior to a scheduled visit, but results of the screening tests were not systematically given to the providers of usual care patients or used in their care. The primary outcomes of two studies involved subgroup analyses,109,116 which were therefore non-randomized (though controlled) comparisons. We included these analyses in our review because they were conducted in the context of a well-designed and implemented randomized controlled trials and were likely planned a priori.109

Studies focusing on general adult patients. Four studies focused on general adult populations. In a recent small (n=59) study in a rural setting,113 providers at two private health clinics were educated about the PHQ-9. Researchers subsequently screened consecutive clinic patients. Patients with a positive score on the PHQ-9 were randomized either to have their PHQ-9 results given to their providers or not. Providers of intervention participants were asked to review the completed PHQ-9. No other depression care support was provided. Providers saw both intervention and control participants and therefore contamination is possible.

After 6 months there were no statistically significant group differences in either the proportion of participants in remission or in change in PHQ-9 score. This was a small study, however, with only 59 randomized participants. Even with their fairly good follow-up rate of 86 percent, there was minimal power to detect even large differences. For example, they found that 52 percent of the intervention group achieved remission from depression at 6-month follow-up, compared with 38 percent of the control group. The power for this comparison was approximately 10 percent, given their sample size. In order to achieve statistical significance with 80 percent power with their sample size, approximately 80 percent of the intervention participants would have to be in remission, compared with 38 percent of the control group. Thus, this study was not adequately powered to detect differences that would likely be clinically significant. They also reported differences in PHQ-9 score change, which is likely to have more power than the binomial comparison, but they did not report the standard deviations that would have allowed us to analyze the power for this analysis. This study also included a fairly large proportion of participants who were already taking medications for depression or anxiety (38 percent), though they do not specify the proportion taking antidepressants.

In another small (n=61) study with a largely indigent population,114 Jarjoura and colleagues recruited patients from an internal medicine residency clinic who were either enrolled in Medicare or who were without private health insurance and had low income. Patients were excluded from this study if they were currently receiving treatment for any mental health problem (including depression), were seeking help for mental health problems, or reported suicidal ideation on the screening test. While there was a high background level of depression in the population, with positive screening test results for 45 percent of screened patients, only 9 percent of the screened patients were eligible for the study (i.e., had a positive screening test and were not already being treated for depression).

In the intervention condition, a screening nurse advised resident physicians of the positive screening results and provided a protocol outline asking the physician to: 1) explore symptoms with the patient and affirm screening results; 2) attempt to rule out physical conditions, medications, or other primary psychiatric diagnoses; 3) provide information, treatment, and follow-up at specified intervals; and 4) facilitate refer to behavioral treatment. Control participants who screened positive were informed they might have a problem with depression and that effective treatments were available. Participants were contacted at 6- and 12-months after the baseline visit and 90 percent completed at least one follow-up interview.

Researchers reported that intervention status predicted change in Beck Depression Inventory (BDI) in a mixed model linear regression. At six-month follow-up, average BDI score for the treatment group had improved by 7.6 points more than that of the control group (p<0.05, BDI range 0–63). Intervention effects were maintained at 12 months, with BDI score improvement in the intervention group 6.5 points greater than in the control group (p=0.03). As with the Bergus et al113 study, this was a small study that randomized individuals rather than providers (and was therefore vulnerable to contamination). This study, however, used an analysis technique likely to have more power than the Bergus et al analyses.

This study limited the sample to those who were not being treated for depression at baseline, thus eliminating patients who were diagnosed with depression but were untreated, under-treated, or resistant to treatment. The intervention in the Jarjoura et al114 study did provide elements beyond simple feedback to a provider, including a protocol and positive screening test results, but the program was not extremely extensive and involved a level of treatment that is feasible for many or most primary care settings. A total of 70 percent of the patients in the intervention condition were given depression care (24 percent received mental health specialty care, with or without antidepressants, and an additional 45 percent received antidepressants without specialty care), compared with only 15 percent in the usual care condition, none of whom received specialty mental health care. Thus, the combination of limiting the program to newly detected depression and moderate levels of support appeared to be sufficient to improve patients’ depression.

Two large-scale studies109,110 included extensive interventions beyond screening. Both included study sites in many regions of the US and both used a two-step screening approach adapted from the Composite International Diagnostic Interview (CIDI), where depressive symptoms are only explored if the patient is positive on a two-item initial screener. One of the studies110 found significant group differences in depressive symptomatology and remission, while the other found a benefit only among the subgroup of newly detected patients with depression.109

The study by Wells110 and colleagues randomized clinics to usual care or one of two extensive quality-improvement interventions for depression care. One intervention condition (QI-Meds, referred to as IG1 in Table 5) included screening; institutional monetary commitment; staff and clinician training (1- or 2-day workshops); clinician manuals; monthly training lectures; academic detailing; numerous materials for clinicians, staff, and patients; initial visit with nurse specialist for assessment, education, and discussion of patients preferences and goals; and trained nurse specialists for follow-up assessment and on-going support for medication adherence for those prescribed antidepressant medications. The other intervention condition (QI-Therapy, referred to as IG2 in Table 5) included all of the same QI elements as the QI-Meds condition except that it included trained therapists to provide manualized CBT and reduced co-pay for those referred for psychotherapy, rather than nurse specialists to support medication adherence. Providers in both intervention groups were expected to provide the treatment they deemed most appropriate for each patient, so patients in both groups could have received antidepressants or mental health specialty care. For example, referrals to mental health specialists ranged from 63 percent to 89 percent in the QI-therapy clinics and between 17 and 45 percent in the QI-Meds clinics. Structured follow-up sessions with a nurse medication specialist on the phone or in person averaged 1.8 sessions for patients in the QI-Therapy and 5.1 for QI-Meds patients.

Medical directors of the usual care clinics were mailed the AHRQ depression practice guidelines with quick reference guides for distribution to clinicians. Patients in control clinics were screened and patients were told that while they could inform their providers of the screening test results, the study staff would not send the results to their providers. Patients who screened positive on the CIDI were enrolled in the interventions and followed up.

At follow-up, the proportion of participants in either treatment arm who were still positive on the CIDI 2-item screener was 40 percent at 6 months and 42 percent at 12 months, while 50 percent of usual care participants still scored positive on the CIDI at 6 months and 51 percent at 12 months (p=0.001 for group differences at 6 months, p=0.005 at 12 months). At 5-year follow-up, program benefits were sustained for the QI-therapy group, which had positive CIDI screening scores of 36 percent of the intervention participants compared with 44 percent of the usual care participants (p=0.05). The difference between the control and QI-meds group was not significant at 5-year follow-up (38 vs. 44 percent positive, p=0.08).118 These results provide good evidence for the effectiveness of their program. It is impossible to determine, however, what role, if any, the screening component played in the success of their program, which included so many elements. Further, while this intervention was proven feasible for primary care settings, it involved significant institutional commitment and may not reflect the care that would be found currently in most settings.

The Rost et al study109 was designed for practices without ready access to mental health specialty care and also contained extensive care support elements beyond screening. Researchers cluster-randomized clinics to usual care or an intervention in which office staff recruited, screened, and enrolled participants who screened positive prior to a clinic visit. If the physician confirmed the depression diagnosis, the participant was scheduled for a return visit with the physician and to meet with the nurse specialist in one week. The nurse specialist reassessed the patient’s level of depression, discussed treatment options and preferences, and asked the participant to complete a homework assignment. Participants completed up to eight additional sessions following the same pattern, either by phone or a face-to-face visit. Nurse documentation logs indicated that the nurses intervened in 92.5 percent of the patients in the intervention condition, contacting these patients an average of 5.2 times. Physicians and nurses in the intervention clinics were also trained in depression assessment and treatment and had access to free 24-hour consultation for patient-specific questions.

Although there was a significant overall treatment effect,119 outcome data were only presented in two strata: patients who were not already being treated for depression (“newly identified”), and patients who were already or had recently been treated for depression (“recently treated”). Among the newly identified, CESD scores dropped an average of 21.7 points in the intervention group and only 13.5 points in the control group (p<0.05). In the recently treated, CESD scores dropped in both groups and did not differ between groups. At 2-year follow-up, significantly fewer of the newly identified patients in the intervention group met CESD screening criteria for depression (26 percent), compared with the control group (59 percent) (p<0.05). As with the Wells study, the effect of the screening component cannot be isolated.

Studies focusing on older adult patients. Four fair-quality, cluster-randomized RCTs focused on older adults.111,112,115 A 2006 study conducted in the Netherlands randomized 34 general practices (GP) to intervention or usual care conditions.115 Providers in the intervention practices attended a 4-hour training session on diagnosis and treatment of late-life depression, with a treatment protocol based on Dutch treatment guidelines.117 In all practices, patients aged 55 or older were screened for depression with the Geriatric Depression Scale (GDS), and those scoring five or greater underwent a diagnostic evaluation using the Primary Care Evaluation of Mental Disorders (PRIME-MD). Usual care providers were not informed of screening test or PRIME-MD results. The intervention providers were informed of screening results and conducted the PRIME-MD interview themselves to determine MDD diagnosis. Patients with MDD diagnoses who were not currently using antidepressants were invited to participate in the study.

Fifteen percent of the 3,937 patients screened scored five or greater on the GDS, and 53 percent of the 339 consenting to the diagnostic interview were diagnosed with MDD and enrolled in the study. At 12-month follow-up, the groups did not differ on either proportion depressed or on symptom severity scores. Fifty-seven percent of the intervention group participants and 52 percent of the usual care participants still met criteria for depression at the 12-month follow-up.

Whooley and colleagues111 randomized HMO primary care clinics to either an intervention or control condition. The intervention condition involved screening, feedback, treatment guidelines, and training for providers and group psycho-educational classes offered to patients and families. The control condition also involved screening and the clinics received the same one-hour training session. Patients were screened with the Geriatric Depression Scale (GDS) and 14 percent of the participants screened positive for depression and were enrolled in the study, with 20 percent receiving antidepressants during the previous year. Although this study included group classes, only 12 percent of the patients attended them. Follow-up after 2 years revealed improvements in both groups with no differences between the intervention and control groups.

Callahan and colleagues112 randomized clinical practices to usual care or to a program screening for depression, dementia, and alcoholism. Providers in the intervention group received a letter for each of their study patients screening positive on two separate depression instruments. These letters contained the results of the second screening test, a list of medications that may cause depressive symptoms, and treatment recommendations. This letter was placed in the patient’s chart, along with handouts for the patient. The provider was encouraged to schedule three appointments with the patient over the course of the next three months. Completion rates for visits were not reported. Providers in the control group were given no information or screening results, and additional appointments were left to the discretion of the provider. Providers in both groups were given an educational session on late-life depression and completed surveys after baseline visits of study patients. Sixteen percent of the patients in this study screened positive on the first screener, the Center of Epidemiologic Studies Depression Scale (CESD), and of these, 28.6 percent completed and were positive on the Hamilton Depression Rating Scale (HAMD). No group differences were found at 6 or 9 months follow-up, with very few patients in either group (12 to 13 percent) achieving remission. The patient population was an indigent, urban, largely Black group of seniors with co-morbid medical and psychiatric illnesses and significant functional disability at baseline.

Rubenstein and colleagues116 conducted a non-randomized controlled trial in which patients in two VA clinical practices aged 65 or older were screened via a postal survey for five different common geriatric conditions (depression, falls/balance problems, urinary incontinence, memory loss, and functional impairment). Those scoring in the “high risk” range (indicating impairment on four or more of the ten items on the screening instrument) were invited to enroll in the trial. Participants at the clinical practice assigned to the control group received usual care, though if a serious condition was identified then the patient’s primary care provider was notified. Participants in the clinical practice assigned to the intervention group were contacted by a case manager, who performed a more thorough assessment over the telephone. After completing the assessment, the case manager provided referrals to primary or specialty care providers, as needed, or for further evaluation by a multidisciplinary geriatric assessment team. The case manager also provided patient education, a written summary of recommendations, scheduled appointments, and conducted follow-up calls (one-month post-assessment and then quarterly). Overall, 42 percent of those returning questionnaires scored as “high-risk”, 79 percent (n=792) of these enrolled in the study, and 41 percent of the enrolled scored in the depressed range on the GDS (45.8 percent of those completing the GDS).

Among the entire enrolled population, including those who were not depressed at baseline, no differences were seen in change in depressive symptomatology over time. Among the 206 participants who were above the cut-off for likely depression on the GDS at baseline and completed the 12-month assessment, those in the intervention group showed a greater decline in depression severity after one year. GDS scores of participants in the intervention group dropped by an average of 3.7 points, compared with an average decline of 2.7 points among control participants (p=0.05). However, only 72.5 percent of the sample completed the GDS at one-year, so despite the high follow-up rate for the study overall, the follow-up rate for this instrument was considerably lower. Also, we do not know if the intervention and control participants in the subgroup of participants meeting depression criteria at baseline were similar to each other, nor do we know what the follow-up rate was among these baseline depressed.

All studies of older adults were well-designed, fairly large-scale studies with apparently similar rates of background depression in their populations. Two studies focused additional supports on the treating provider in the form of education, screening, and feedback, with other elements such as repeat visits with the provider (Callahan) or outside psycho-educational classes for patients.111 One utilized case managers rather than focusing on improving the care provided by the primary care clinician.

## Key Question 2: What are the harms of screening for depressive disorders in adults and older adults?

We did not find any studies that included adverse events of screening.

## Key Question 3: Is antidepressant and/or psychotherapy treatment of older depressed adults effective in improving health outcomes?

Summary of findings. We found three good-quality systematic reviews in older adults120–122 that each included meta-analyses (Table 7). One examined the efficacy of antidepressants,121 one examined the efficacy of psychotherapy,122 and one examined both types of treatments.120 Two of these reviews120,121 found that antidepressants were effective in treating depressed older adults, and approximately doubled the odds of remission compared with placebo controls, with OR of 2.03 (CI: 1.67, 2.46) for patients with major and minor depression; 2.13 (CI: 1.61, 2.86) for the community-dwelling subset; and 2.27 (CI: 1.72, 2.94) in the subset with MDD. Two good-quality meta-analyses120,123 of psychotherapy effectiveness concluded that psychotherapy is effective in treating depression in older adults. Depressed older adults treated with psychotherapy were roughly two-and-a-half times more likely to achieve remission than those who were not treated with psychotherapy, with the ORs estimated at 2.47 (CI: 1.76, 3.47) and 2.63 (CI: 1.96, 3.53). Effect sizes estimates range from 0.72 to 1.09.

Table 7 Summary of the evidence for KQ3: treatment efficacy in older adults

Reference | No. trials in meta- analysis (number of participants) | Years covered | Age range | Results Remission: Odds Ratio (95% CI) Symptom Report: Effect Size (d) (95% CI)
Antidepressants
Pinquart et al, 2006^120^ Antidepressant vs. placebo in depressed older adults Major and minor depressive disorders considered | 62 trials (N=3,951) Subset focused on MDD: 31 trials (N=NR) | Through 2004 | Mean or median age ≥60 yrs | Remission 2.03 (1.67, 2.46)
Pinquart et al, 2006^120^ Antidepressant vs. placebo in depressed older adults Major and minor depressive disorders considered | 62 trials (N=3,951) Subset focused on MDD: 31 trials (N=NR) | Through 2004 | Mean or median age ≥60 yrs | Clinician Symptom Report, Total 0.69 (0.57, 0.81) MDD-only 0.79 (0.64, 0.95) SSRI 0.48 (0.30, 0.66) Atyp 0.72 (0.48, 0.95) TCA 0.93 (0.65, 1.21) MAOI 0.79 (0.51, 1.07) | Self-Report of Symptoms , Total: 0.62 (0.45, 0.79) SSRIs 0.22 (0.10, 0.35) Atyp 0.67 (0.37, 0.97) TCA 0.83 (0.46, 1.20) MAOI 0.80 (0.40, 1.19)
Wilson et al, 2000^121^ Antidepressant vs. placebo in older adults Major and minor depressive conditions considered | 17 trials (N=1,524)^*^ Subset focused on MDD: 8 trials (N=1,120)^*^ Subset focused on community dwellers: 7 trials (N=1,070)^*^ | Through 1999 | ≥ 55 yrs or described as “elderly” | Remission rates SSRI vs. Placebo: 28% vs. 17%^*^ 1.96 (1.39, 2.78)^†^ Atypical vs. placebo 42% vs. 27%^*^ 1.92 (1.07, 3.45)^†^ TCA vs. Placebo: 49% vs. 25%^*^ 3.12 (2.13, 4.76)^†^ | MAOI vs. Placebo: 41% vs. 10%^*^ 5.88 (2.56, 14.28)^†^ Community-dwelling subset only: 36% vs. 21%^*^ 2.13 (1.61, 2.86)^†^ MDD subset only: 36% vs. 20%^*^ 2.27 (1.72, 2.94) (all p<0.05)
Psychotherapy
Pinquart et al, 2006^120^ | 32 trials (N=1,407) 9 trials exclusively MDD(n=NR) | Through 2004 | Mean or median age ≥ 60 yrs | Remission: 2.47 (1.76, 3.47) Clinician Report Total: 1.09 (0.91, 1.26) MDD-only: 0.96 (0.69, 1.23) | Self-Report Total: 0.83 (0.69, 0.98)
Cuijpers et al, 2006^122^ | 21 trials (N=1,937) | NR | Mean or median ag ≥ 55 yrs e | Remission: 2.63 (1.96, 3.53) Symptom Report (Clinician- or Self-Report) Total: 0.72 (0.59, 0.85)

* Calculated from Ns presented in text or summary tables.

† Odds ratio (95% confidence interval) computed by taking the reciprocal of the odds ratio of proportion not in remission reported in Wilson 2000. 121

MDD-major depressive disorder; ES-Effect Size (d); OR-Odds Ratio; NR-Not Reported; SSRI-Selective Serotonin Reuptake Inhibitor; Atyp-atypical; TCA-Tricyclic Antidepressant; MAOI-Monoamine Oxidase Inhibitor; BDI-Beck Depression Inventory; GDS-Geriatric Depression Scale; HRSD-Hamilton Rating Scale for Depression

Study details - antidepressants. Numerous systematic reviews examining antidepressant efficacy in older adults have been published since the end of the previous USPSTF report’s search window. We limited our inclusion to the two most recent good-quality systematic reviews that also included meta-analyses — a Cochrane review published in 2000^121^ and another review published in 2006.^120^ There was considerable overlap among the two included reviews, though they had somewhat different inclusion criteria and search windows and therefore different sets of included trials. Another good-quality review of newer antidepressant efficacy in adults was also published in 2000^75^ and discussed efficacy in older adults separately. This study, however, overlapped substantially with the Cochrane review, and since the Cochrane review provided more detail, we excluded this other 2000 review.

The most recently published meta-analysis120 examined 62 pharmacotherapy studies, 32 psychotherapy studies, and five studies examining both interventions in depressed older adults. This good-quality review included studies involving the full range of depressive disorders, including minor depression, dysthymia, and MDD. These authors included non-randomized comparative studies, although 89 percent of the included studies were randomized trials. All studies included a control condition and no restrictions were set with regard to setting (e.g., inpatient, outpatient, residential). In addition to providing overall results for all depressive disorders, they also reported the results of trials focusing exclusively on MDD separately. The authors combined all agents to determine overall effectiveness of antidepressants and combined all therapeutic modalities to determine overall effectiveness of psychotherapy. Of the 77 comparisons of clinician-reported outcomes, the specific agents examined included roughly the same number of reports for SSRIs (21/77) and TCAs (22/77), and over one third of the drugs were categorized as “other,” many of which were non-SSRI second generation medications.

This review found an overall effect size of antidepressants of 0.69 (CI 0.57, 0.81, k=77 comparisons) for clinician-rated depression (most commonly the HAM-D) and 0.62 (CI 0.45, 0.79 k=28 comparisons) for self-rated depression. Although they do not report the absolute proportion of patients in the treatment and control groups whose depression remitted, the authors do report that treated participants were approximately twice as likely as control participants to go into remission (OR 2.03, CI: 1.67, 2.46). For studies focusing exclusively on MDD, clinician-rated depression had an effect size of 0.79 (CI: 0.64, 0.95, k=39 comparisons).

This review reported effect sizes separately for different classes of antidepressant agents, though they did not limit this analysis to studies focused on MDD. The authors report effect sizes ranging from 0.48 (SSRIs) to 0.93 (TCAs) for clinician-rated improvement, and report effect sizes ranging from 0.22 (SSRIs) to 0.83 (TCAs) for self-rated improvement.

The 2000 Cochrane Review121 included randomized, placebo-controlled trials using antidepressants in the treatment of depression in older adults. The authors included studies of major and minor depression recruited from outpatient, community, institutional, and inpatient sources. They included 23 placebo-controlled, double-blind RCTs involving SSRIs, other second generation antidepressants, TCAs, and MAOIs, 17 of which were included in the meta-analysis. Eleven of the trials included in the meta-analysis were TCAs, and three of the trials involved second generation medications (fluoxetine and mirtazapine). Separate analyses were conducted for each of the medication categories, and separate analyses were conducted to determine the percent recovered at the end of the trial, continuous HAM-D scores, other observer rating scales, and discontinuation rates. For this review we limited our focus to recovery rates and HAM-D scores. Most of these studies measured treatment outcome at 3 to 8 weeks. This Cochrane review reported the number, proportion, and odds ratios of participants who were not recovered from depression at trial’s end. We converted these numbers to report those who recovered from depression for ease of interpretation and comparison with other meta-analyses.

The most commonly reported outcome was the proportion of patients still depressed at the end of the study, which we converted to percent no longer depressed. Pooled fixed effects odds ratios were estimated for each medication type. A total of 365 patients treated with SSRIs were compared with 372 placebo controls in two trials with estimated OR of 1.96 (CI: 1.39, 2.78). One of these trials also reported differences in HAM-D change scores of 1.7 points in favor of the treatment group (CI:0.54, 2.60). Trials of other second generation antidepressants examined mirtazepine and two other medications not approved for use in the U.S. (minaprine, and medifoxamine), estimating an overall OR of 1.92 (CI: 1.07, 3.45) in 102 patients treated with active agents and 96 placebo controls in two trials. No HAM-D results were reported for either of these trials. For TCAs, 245 patients treated with TCAs were compared with 223 placebo controls in ten trials and had an estimated OR of 3.12 (CI: 2.13, 4.76). One trial reported that treatment participants improved on the HAM-D by 9.6 points (CI: 9.4, 13.8) more than the control participants. Analyses of MAOIs included a total of 58 patients treated with MAOIs and 63 with placebo in two trials, and found an OR of 5.88 (CI: 2.56, 14.28). No HAM-D results were reported for MAOIs. In terms of recovery rates, these studies found 28 to 49 percent of patients recovering from depression among antidepressant users and only 10 to 25 percent recovering in the placebo control groups.

In addition to overall results by medication type, they report meta-analysis results separately for outpatient/community recruitment, which are of greatest relevance to this review. Antidepressants were more effective than placebo, with 36 percent of antidepressant users recovered at the end of the study compared with 21 percent of the placebo patients, estimated OR of 2.13 (CI: 1.61, 2.86).

Although they did include some studies of hospitalized and institutionalized patients, most of these trials excluded a large proportion of those screened for inclusion due to comorbid physical illness or high levels of depression severity. Thus, the results of these analyses are best generalized to relatively healthy elders with mild- to moderate- depression severity, and only to very short-term outcomes.

Study details- psychotherapy. As with antidepressant therapy, several systematic reviews have been published examining psychotherapy efficacy in older adults since the end of the previous USPSTF report’s search window. We limited our inclusion to the two most comprehensive recent good-quality systematic reviews of psychotherapy for depression in older adults, one by Pinquart and colleagues120 and the other by Cuijpers and colleages122, both published in 2006. While there was substantial overlap between the two reviews, their inclusion and exclusion criteria led to somewhat different bodies of evidence and we therefore included both reviews.

The Pinquart review did not report search dates, but appeared to have covered the literature through 2004. It included studies in which participants had a median age of 60 or greater, required a placebo or no-treatment control group, and included non-randomized comparisons, for a total of 32 trials. They report results separately for clinician-rated and self-report outcomes. The Cuijpers review searched an additional year (through 2005), included trials of participants aged 50 or greater, included trials that compared two active treatments as well as those that included control groups, and only included randomized comparisons, for a total of 25 trials. Pinquart and colleagues specifically reported including non-English language studies. No mention of language restriction was reported in the Cuijpers report, and no non-English language studies were among the list of included trials. Most of the 13 studies included in Pinquart but not in Cuijpers appeared to be non-randomized controlled trials and non-English language trials. Most of the 12 trials included in Cuijpers but not in Pinquart were either comparative effectiveness trials (i.e., they did not include a no-treatment control group) or were published after 2004.

The systematic review and meta-analysis by Pinquart and colleagues120 found an overall effect size of 1.09 (CI: 0.91, 1.26, k=35 comparisons) for clinician-rated depression severity (usually using the HAM-D) and 0.83 (CI: 0.69, 0.98, k=52 comparisons) for self-rated depression. Twenty-six of the comparisons of clinician-rated depression involved some form of cognitive behavioral therapy. The other comparisons involved problem-solving, reminiscence, interpersonal, rapid eye movement, or life review therapy. Likewise, more then three-fourths of the comparisons involving self-reported outcomes used cognitive behavioral therapy. While they do not report the absolute proportion of patients in the treatment and control groups whose depression remitted, they do report that treated participants were more than twice as likely to go into remission (OR 2.47, CI: 1.76, 3.47). For studies focusing exclusively on MDD (excluding dysthymia and minor depression), clinician-rated depression had an effect size of 0.96 (CI: 0.69, 1.23, k=16 comparisons).

The review by Cuijpers and colleagues122 reported an effects size of 0.72 (CI: 0.59, 0.85) for psychological treatment of depression in older adults, among trials that included a control condition (k=21 comparisons). This is within the 95 percent confidence interval of the Pinquart study for self-reported depression. This review did not report clinician- and self-reported symptomatology separately, but instead averaged these two measures if a trial reported both types of outcomes, and combined both types of outcomes in a single meta-analysis. Thus, this effect size reflects a blend of clinician report (which tends to show larger effects) and self-report (which tends to show smaller effects). Half of the comparisons in this review involved cognitive behavioral therapy, and the remaining involved behavior therapy alone, reminiscence or life-review, interpersonal, problem solving, or “other” therapies. Eleven studies in the Cuijpers review included remission rates, usually based on falling below a pre-specified cut-off on a continuous depression measure. They calculated an overall OR of 2.63 (CI: 1.96, 3.53), which is well within the 95 percent confidence interval for remission in the Pinquart review. Thus, these two reviews reported very consistent results for remission, but the average degree symptom improvement was somewhat smaller in the Cuijpers review than the Pinquart review, and this may in part be due to the method of analyzing the outcomes. It is also possible that randomized trials result in smaller group differences than non-randomized controlled trials, though the data were not presented that would allow us to verify this hypothesis.

## Key Question 4: What are the adverse effects of antidepressant treatment (particularly SSRIs and other second-generation drugs) for depression in adults and older adults?

Summary of findings. We examined serious adverse effects associated with antidepressant treatment including: suicide-related events (completed suicide, serious self-harm or attempted suicide, suicidal ideation) and serious psychiatric events, including hospitalization. Since adverse effects—typically nausea, dizziness, diarrhea, headache, sexual dysfunction, or insomnia—occur in 61 percent of patients during clinical trials of antidepressant medications,57,92 we examined rates of early discontinuation, particularly discontinuations due to adverse effects. For older adults, we also considered evidence of serious medical events (e.g., upper gastrointestinal bleeding) associated with SSRIs and other second-generation antidepressant use.

Suicide-related event rates were most commonly reported per person receiving treatment, without consideration of exposure time. Event rates per 10,000 persons for three suicide-related outcomes are reported in Table 8: for completed suicide, for suicidal behaviors (usually defined to include suicide attempts, preparatory acts, or nonfatal, serious self-harm), and for suicidal behaviors and ideation combined. Table 9 reports risk differences in these outcomes for patients with MDD.

Table 8 Summary of rate of suicide and related behavior or ideation.

| | Completed Suicide | | | Suicidal Behaviors | | | Suicidal Behavior or Ideation
Study, Subgroup | Treatment Condition | N (events/persons) | Rate per 10,000 | OR, (95% CI) | N (events/persons) | Rate per 10,000 | OR, 95% CI | N (events/persons) | Rate per 10,000 | OR, 95% CI
Systematic Reviews of Trials
Levenson, 2006 125 Stone, 2006 124 Through 9/2006
MDD only 162 RCTs | 2^nd^ GenAD Placebo | 4/22,379 1/14,873 | 1.79 0.67 | 2.66^*^ (0.26, 130.9) | - | - | - | 163/22,309 123/14,728 | 73.1 83.5 | 0.86 (0.67, 1.10)
All psychiatric indications 295 RCTs | 2^nd^ GenAD Placebo | 5/39,799 2/27,309 | 1.3 0.73 | 1.72^*^ (0.28, 18.01) | 79/39,729 49/27,164 | 19.9 18.0 | 1.11 (0.77, 1.61) | 248/39,729 196/27,164 | 62.4 72.2 | 0.84 (0.69, 1.02)
All psychiatric indications, Ages 18–24 years 272 RCTs | 2^nd^ GenAD Placebo | - | - | - | 23/3,810 8/2,604 | 60.4 30.7 | 2.31 (1.02, 5.64) | 47/3,810 21/2,604 | 123.4 80.6 | 1.55 (0.91, 2.70)
All psychiatric indications, Ages 25–30 years 295 RCTs | 2^nd^ GenAD Placebo | - | - | - | - | - | [underlined: 25–64 yrs] 1.03 (0.68, 1.58)^**^ | 41/5,558 27/3,772 | 73.8 71.6 | [underlined: 25–64 yrs] 0.79 (0.64, 0.98)^**^
All psychiatric indications, Ages 31–64 years 29 RCTs | 2^nd^ GenAD Placebo | - | - | - | - | - | [underlined: 25–64 yrs] 1.03 (0.68, 1.58)^**^ | 147/27,086 124/18,354 | 54.3 67.6 | [underlined: 25–64 yrs] 0.79 (0.64, 0.98)^**^
All psychiatric indications, Ages ≥65 years 233 RCTs | 2^nd^ GenAD Placebo | - | - | - | - | - | 0.06 (0.01, 0.58)^**^ | 12/3,227 24/2,397 | 37.1 100.1 | 0.39 (0.18, 0.78)
Hammad 2006 137 Through 2000
MDD only 207 RCTs | SSRIs only SSRI/other Placebo | 6/14,675 15/25,604 2/8,868 | 4.1 5.9 2.3 | SSRI vs Placebo: 1.81^*^ (0.32,18.37) SSRI+Other vs Placebo: 2.60^*^ (0.60, 23.4) | - | - | - | - | - | -
Khan 2003 126 January 1985 – January 2000
Indications not stated Number of RCTs not reported | SSRIs Placebo | 38/26,109 5/4,895 | 14.6 10.2 | 1.43^*^ (0.56, 4.64) | - | - | - | - | - | -
Indications not stated Number of RCTs not reported | SSRIs Active controls | 38/26,109 34/17,273 | 14.6 19.7 | 0.74^*^ (0.45, 1.21) | - | - | - | - | - | -
Gunnell 2005 138 , Saperia 2006} 139 MHRA 2004 105 Through 2003
All indications 439 RCTs | SSRIs Placebo | 9/23,804 7/17,022 | 3.8 4.1 | 0.85 (0.20, 3.40) | 128^†^/30,814 75^†^/21,689 | 41.5 34.6 | 1.21 (0.87, 1.83) | 97^‡^/26,882 80^‡^/18,822 | 36.1 42.5 | OR: 0.80 (0.49, 1.30)
GSK 2006 131 Through December 2004
MDD cases 19 RCTs | Paroxetine Placebo | - | - | - | 11/3,455 1/1,978 | 31.8 5.1 | 6.7 (1.10, 149.4) | 31/3,455 11/1,978 | 89.7 55.6 | 1.3 (0.7, 2.8)
MDD cases, Ages 18–30 years. Number of RCTs not reported | Paroxetine Placebo | - | - | - | 8/612 0/339 | 130.7 0 | (cannot calculate)
Fergusson 2005 130 1967 through June, 2003
All indications 411 RCTs | SSRIs Placebo | 4/10,557 3/7,856 | 3.8 4.0 | 0.95 (0.24, 3.78) | 23/10,557 6/7,856¶ | 21.8 7.6 | 2.70 (1.22, 6.97) | - | - | -
Storosum 2001 140 1983 through 1997
Likely MDD cases, 77 Short-term RCTs | SSRIs Placebo | 7/7,944 4/4,302 | 8.8 9.3 | 0.95^*^ (0.24, 4.42) | 29/7,944 17/4,302 | 36.5 39.5 | 0.92^*^ (0.49, 1.79) | - | - | -

| | Completed Suicide | | Suicidal Behaviors
Study, Subgroup | Treatment Condition | N (events/persons) | Rate per 10,000 (95% CI) | N (events/persons) | Rate per 10,000 (95% CI)
Cohort Studies (includes 95% CI around event rate if no comparison)
Simon 2006^129^ MDD only in pre-paid group practice | Second generation and TCAs | 31/65,103 | 4.8 (*3.3, 6.8) | 76/65,103 | 11.7 (*9.3, 14.6)
Martinez 2005^128^ Age <90 with new antidepressant prescription | Any anti-depressant (Primarily 1^st^ generation) | 69/146,095 | 4.7 (*3.7, 6.0) | 1968^†^/146,095 | 134.7 (*128.9, 140.8)
Martinez 2005^128^ 19–30 year-olds with new antidepressant prescription | Any anti-depressant (Primarily 1^st^ generation) | 19/34,792 | 5.5 (*3.5, 8.6) | 747/34,792 | 214.7 (*199.8, 230.7)
Jick 1995^127^ Pharmaceutical event monitoring data, All indications | Any anti-depressant (Primarily 1^st^ generation) | 143/172,598 | 8.3 (*7.0, 9.8) | - | -

Bolded: p < 0.05

* calculated

** Cited in Stone 2006

† Non-fatal harms, plus includes fluoxetine-related suicides for Gunnell.

‡ Ideation only

MDD-major depressive disorder; TCA- tricyclic antidepressant; SSRI- selective serotonin reuptake inhibitor

Table 9 Risk differences (per 10,000) for suicide and suicidality among patients with major depressive disorder.

Study, Outcome, Comparison | Absolute Risk per 10,000, Drug | Absolute Risk, per 10,000 Placebo | Risk Difference | 95% CI
FDA 2006^124,125^ Suicide, SSRI vs. Placebo | 1.79 (4/22379) | 0.67 (1/14873) | 1.12 | −1.1, 3.3
Hammad 2006^137^ Suicide, SSRI vs. Placebo | 4.1 (6/14675) | 2.3 (2/8868) | 1.8 | −2.7, 6.3
GSK Report 2006^131^ Suicidal Behavior, Paroxetine vs. Placebo | 31.8 (11/3455) | 5.1 (1/1978) | 26.8 | 5.5, 48.0
GSK Report 2006^131^ Suicidal Behavior or Ideation, Paroxetine | 89.7 (31/3455) | 55.6 (11/1978) | 34.1 | −11.3, 79.5

For completed suicide, none of the seven meta-analyses of short-term trials in adults being treated either for MDD or for any psychiatric indications supplied clear evidence that use of second-generation antidepressants—or of SSRIs in particular—significantly increased rates of completed suicide for those on antidepressant treatment compared with placebo. However, despite the large sample sizes, there were very few suicides (7 to 43 total suicides among treated and control patients per review) which limited power to detect these rare events; using reported or calculated OR, these results are compatible with no increase in short-term risk, some protective effect, or some increased risk. Most meta-analyses estimated suicide rates ranging from 3.8 to 8.8 per 10,000 antidepressant-treated adults, compared with 2.3 to 9.3 per 10,000 placebo-treated patients. Two studies’ data represented outliers. One FDA report estimated 1.8 completed suicides per 10,000 antidepressant-treated MDD patients (compared with 0.67 per 10,000 placebo-treated MDD patients);124,125 this estimate is markedly lower than other studies and may reflect methodological differences (e.g., in how suicides and related events were categorized, among other differences). And, the much higher estimates of suicide rates in both antidepressant and placebo-treated patients in another review126 could reflect the suicide risk among more severely depressed patients (since the majority of studies in this review employed active controls rather than placebos) as well as quality concerns with this review.

Three fair or good quality large observational studies reported on suicide with antidepressant treatment in a total of 383,796 patients from a large US HMO and from GP practices in the UK.127–129 Among the two highest quality studies reporting a 6–8 month follow-up duration, crude suicide rates were 4.7 and 4.8 per 10,000 persons treated primarily with second-generation antidepressants, with slightly higher rates reported among children and adults under 30 years. These studies also indicate higher risk for suicide death among men compared with women. Although these observational studies do not give us comparative information for people who were not taking antidepressants, they give credence to the estimate of approximately 4/10,000 suicide cases among antidepressant users found most consistently in the meta-analyses of short-term trial data.

For suicidal behaviors (defined differently across studies, but usually including suicide attempts, preparatory acts, or serious self-harm), results from five meta-analyses did not show significant differences in the odds of suicidal behaviors in adults treated with antidepressants compared with placebo, with several exceptions. One fair quality systematic review indicated an increased odds of suicidal behaviors in adults of all ages being treated with SSRIs for any indication (OR 2.70; CI: 1.22, 6.97);130 this report was limited to published studies only and did not have clear adverse event ascertainment for the majority of patients. In an FDA review of regulatory data of placebo-controlled trials, odds of suicidal behavior were approximately doubled in adults under age 25 taking second-generation antidepressants for all psychiatric disorders (OR 2.31; CI: 1.02, 5.64);125 in contrast, the odds of suicidal behaviors was not changed among middle-aged adults, and was greatly reduced in older adults on second-generation antidepressants (OR 0.06, CI: 0.01, 0.58).124

The highest odds of non-fatal suicidal behavior was reported in adults of all ages being treated for MDD with paroxetine compared to placebo (OR 6.70; CI: 1.1, 149.4), with most events (8/11) occurring in those aged 18–29 years.131 The NNT-harm for this estimate is 373 (CI: 208, 1818).

Two good quality observational studies suggest that, in contrast to a higher risk of suicide deaths in men, there were no sex differences in risks of self-harm, but there were age-related differences.128,129 Suicide attempts were significantly greater in younger persons (under aged 18 years),129 with a higher rate of self-harm in those aged 19–30.^128^ The highest risk for suicidal behaviors occurred in the month prior to treatment initiation and the first month of treatment.129 Rate of suicidal behaviors in real-world practice situations was similar to trial rates for one study129 but was substantially higher in the other;128 this higher rate could reflect real differences or perhaps represents study differences in definitions (and perhaps ascertainment).

For suicidal ideation, three meta-analyses used a combined endpoint (suicidal ideation or behavior) and found no differences between antidepressant and placebo-treated patients, except for a reduction in older adults treated with second-generation antidepressants for all psychiatric conditions (OR 0.39;CI: 0.18, 0.78).125

For serious psychiatric events, we did not find any existing systematic reviews and found very limited reliable primary evidence to estimate mania precipitation or to distinguish other uncommon but important psychiatric side-effects from suicide-related behaviors.

For tolerability, we found eight systematic reviews that reported overall discontinuation rates and discontinuation due to adverse effects as measures of the impact of adverse effects associated with antidepressants,72,75,90–95 and two large cohort or uncontrolled treatment trials.46,96 Early treatment discontinuation ranged from 16 to 29 percent in meta-analyses of antidepressant trials in primary care patients with depression, with a best estimate of 20 to 23 percent in “real-world” trials of primary care. Early discontinuations due to adverse effects were lower (5 to 12 percent). Patients aged 55 and older had higher discontinuation rates overall (27 to 36 percent) and for adverse effects (17 to 22 percent). With longer follow-up, adverse event discontinuation rates increased, particularly in those who switched or augmented medications due to lack of efficacy or intolerable side-effects.

As reported above, older adults were at lower risk for suicide-related harms during antidepressant treatment. For those over 65 years, antidepressant treatment was protective for both suicidal behaviors (OR 0.06; CI: 0.01, 0.58) and combined suicidal behaviors and ideation (OR 0.37; CI: 0.18, 0.76). For serious medical events in older adults, we found a fair-quality systematic review of six large observational studies from Denmark, Canada, the UK, and Holland examining bleeding risk in these SSRI’s.132 Among 26,005 Danish patients aged 16 years and older (almost half aged 60 or more years) risk for hospitalization for upper gastrointestinal (UGI) bleeding was increased compared with non-users during periods of current SSRI use only, with an excess risk of 3.1 per 1000 treatment years. In 317,824 Canadian patients 65 years and older on antidepressants, risk of hospitalization for UGI bleeding increased greatly with age, from 4.1 hospitalizations per 1000 person-years of SSRI treatment in those aged 65 to 70 years to 12.3 hospitalizations per 1000 person-years in octogenarians. Excess hospitalizations for UGI bleeding were increased five-fold (33.2 per 1,000 treatment years) in persons with prior UGI bleeding. In some, 133–135 but not all,136 studies, odds of UGI bleeding among SSRI users were further increased at least two-to-three fold when SSRI users were also taking NSAIDs, with a lesser risk associated with co-use of aspirin or other anticoagulant medications.

### Study details

#### Suicide and related-events, systematic reviews and meta-analyses of short-term trials

For suicide-related events, we included two recent related reviews reported by the U.S. Food and Drug Administration (FDA),124,125 an earlier FDA review,137 and two reviews sponsored or in response to the Medicines and Healthcare Products Regulatory Agency (MHRA) in the United Kingdom,105,131 along with a related review 138 and a related letter to the editor providing additional data.139 Two additional reviews evaluated clinical trials submitted to regulatory agencies for drug approval by the U.S. FDA126 or by the Medicines Evaluation Board of Netherlands.140 One systematic review evaluated published clinical trials only.130 We included all regulatory agency or related reviews, as well as systematic reviews, reporting on suicide-related events with antidepressant usage, unless the review was clearly updated by a more current review. These ten publications group together into seven main sets of data as shown in Table 8.

These reviews were generally large, reviewing 57 to 702 RCTs (with an average of 326 RCTs) and summarizing the experience of 5433 to 99,839 patients (41,379 patients on average). Most trials were less than 6 to 8 weeks and trial dropout rates were rarely considered but, where reported, exceeded 25 percent drop-out in about half of the trials. The limited reporting of methods to ensure systematic study retrieval and minimal information about individual study details in regulatory and related reviews, made it unclear where there was duplication. Lack of detailed reporting of methods and lack of criteria for quality rating regulatory (as opposed to systematic) reviews also impaired our effort to quality rate these reviews. Thus we provide no quality rating of regulatory and related reviews, but comment on possible concerns related to review methods and reporting. All reviews examined RCTs comparing SSRIs and other second-generation antidepressants with placebo (some trials also with active controls), but varied in whether they included both published and unpublished studies. We found it important to consider reviews including both published and unpublished trials to address potential bias found in previous reviews of only published trials of antidepressants.141 Inclusion of unpublished data also helps minimize a potential non-reporting bias associated with trial sponsorship by the manufacturer.142 We supplemented harms information available from meta-analyses of short-term efficacy trials conducted for drug approval with seven large observational studies.127–129,143–146 These studies reported on risks in those with antidepressant use with a minimum of six months of follow-up conducted in the United States, UK or Denmark. Some of these also provided information on suicide rates in patients who were not taking antidepressant medications. Three studies which were rated fair or good quality are summarized in the text and Table 8,127–129 with details on the fair to poor studies in Appendix G Table 8.^144–147^

2006 FDA Report:124,125 This report conducted for the FDA provided the most current data and compared the risk of either suicidal behavior (e.g., suicide, suicide attempts, or preparatory acts) or suicidality (ideation or suicidal behavior) in a series of meta-analyses of 372 randomized placebo-controlled trials of 11 second-generation antidepressants (buproprion, citalopram, duloxetine, escitalopram, fluvoxamine, fluoxetine, nefazodone, paroxetine, sertraline, mirtazapine, and venlafaxine). Meta-analyses were based on individual and on trial-level data. Most adult patients (63 percent) were enrolled in SSRI trials. Sponsors (manufacturers) created datasets from all relevant trials by protocol and coded adverse events hierarchically with the most specific and serious suicide-related event that occurred for each subject superseding all others (e.g., completed suicide superseded suicide attempt which superseded preparatory acts which superseded ideation). However, in some cases this meant that suicidal ideation superseded self-injurious behaviors (intent unknown) and fatal or non-fatal events with insufficient information. Data were not provided to determine in how many cases suicidal ideation (a cognitive act) was coded instead of actual injurious behaviors or fatal or non-fatal events. Sponsors classified all events and prepared, but were not required to submit, narrative summaries for all “possibly suicide-related events.” Events were limited to those occurring during the double-blind phase of treatment or within one day of stopping randomized treatment.

The FDA review included 99,839 adult patients being treated for major depressive disorder (MDD) and other psychiatric and behavioral disorders, with 15,505 person-years of observation for all participants. MDD was the most common indication (46 percent), followed by other psychiatric disorders (28 percent), other behavioral disorders (14 percent), other indications (9 percent), and non-MDD depression (4 percent). There were a total of eight suicides, 134 attempted suicides, 10 individuals with preparatory actions but no attempts, and 378 individuals with ideation only. Numbers of patients and event-rates were not reported for the other types of fatal and non-fatal possibly suicide-related events that were superseded by suicidal ideation.

Rates of suicide and suicide-related events were relatively more common in those with MDD. Patients with MDD (n= 37,252) accounted for most of the suicides (five of eight suicides), resulting in higher crude suicide rates (1.79 per 10,000 MDD patients treated with any of the 11 antidepressants over an average of 7.5 weeks) compared with patients being treated for other psychiatric disorders (0.66 suicides per 10,000 persons treated) or MDD patients on placebo (0.67 per 10,000 treated).124 Similarly, other suicide-related events (suicidal attempts, preparatory behaviors, or ideation) were relatively more common in those with MDD than other psychiatric disorders (Appendix G Table 3). Thus, event rates and risk differences are reduced in analyses that combine the two groups (MDD with other psychiatric disorders in the category “all psychiatric indications”), but relative measures should not be distorted since the relative impact on all suicide-related events across treatment groups were similar in the two groups of patients.

Of greater importance, the primary outcome used in most meta-analyses, which was likely selected to improve power, was a combined outcome of the impact of medication on ideation and the impact on behaviors (suicidality, reflecting suicidal behaviors OR ideation). However, the direction of the impact of treatment compared with placebo was in opposite directions depending on whether the outcome was suicidal behaviors or suicidal ideation (Appendix G Table 3). For suicide-related behaviors, event rates tended to either be similar in those on active drug and placebo or to be reduced in the placebo groups. In contrast, for suicidal ideation, event rates tended to be higher in placebo than in the drug treatment groups. Because suicidal ideation occurred much more frequently than suicidal behavior, however, the results for the primary outcome are primarily influenced by the medications’ impact on suicidal ideation rather than behaviors. Thus, this combined primary outcome can neither clearly differentiate the impact of antidepressant medications on ideation vs. behaviors, nor provide a clear a picture about the more critical impact of antidepressant medications on suicidal behaviors.

Therefore, to the extent possible, we focus on analyses from this report that reported on the outcome of suicidal behaviors (suicides, attempts, or preparation) in MDD (the highest risk group and most appropriate for absolute rates relevant to this report) and on patients with all psychiatric indications (higher power for relative measures of effect) (Tables 8 and 9).

Compared with placebo, patients with MDD taking active drug had no difference in the odds of suicide (OR 2.66, CI: 0.26, 130.9) or in the odds of suicidality (including ideation and behaviors) (OR 0.86; CI 0.67, 1.10) Similarly, there were no differences in completed suicides, suicidal behaviors or suicidality in active treatment vs. placebo among those with psychiatric indications. There were no differences in suicidal behaviors between drug classes (e.g., SSRIs, SNRIs, other modern antidepressants) in adults with psychiatric indications. However, there was heterogeneity of treatment risk within SSRIs: compared with placebo, suicidal behavior was more likely for those treated with paroxetine (OR 2.76; CI:1.16, 6.6) and less likely for those treated with sertraline (OR 0.25; CI: 0.07, 0.90) Cautions are advised in interpreting these numbers, due to multiple comparisons and since comparisons between medications are indirect comparisons which may also reflect differences across trials.124 When examined by age, adults with psychiatric disorders under age 25 who were treated with second-generation antidepressants had the highest rates of suicidal behavior (60.4 per 10,000 persons) and significantly increased odds of suicidal behavior (OR 2.31; CI:1.02, 5.64), but not suicidality (ideation or behavior) (OR 1.55; CI: 0.91, 2.70), compared with those randomized to placebo. In adults aged 25–64, suicidality (ideation or behavior) was significantly reduced in those on second-generation antidepressants (OR 0.79; CI: 0.64, 0.98), but there was no impact on suicidal behavior alone (OR 1.03; CI: 0.68, 1.58). In contrast, older adults (ages 65 years or older) on these medications had a reduction in both suicidal behavior (OR 0.06; CI: 0.01, 0.58) and broader suicidality (OR 0.39; CI 0.18, 0.78). For all types of suicide-related events (suicide, attempts, preparatory acts, and ideation), differences between treatment groups were greatest in the 18–24 years and the 65 years and older age groups. In the older age group, rates for all events were lower in the antidepressant treated group than in placebo.

Hammad 2006:^137^ In another FDA regulatory analysis of earlier data, the risk of completed suicide during short-term (6–17 week) treatment was examined using 2 placebo-controlled trials conducted as part of the drug development programs for five SSRIs (citalopram, fluoxetine, fluvoxamine, paroxetine, sertraline) and four other second-generation antidepressants (buproprion, mirtazapine, nefazodone, venlafaxine). Events were ascertained during active treatment only. Among adults with MDD (n=40,028 in 207 trials) or with anxiety disorders (n=10,972 in 44 trials), there were 21 and two completed suicides, respectively, with a mean exposure time of 1.4 patient-months. Rates of suicide in adults with MDD taking any second-generation antidepressant were 5.9 per 10,000 persons and 4.1 per 10,000 persons for those taking SSRIS, which did not differ significantly from suicide rates in placebo-treated patients with MDD. It is not clear why suicide rates were two to three times higher for both antidepressant- and placebo-treated patients with MDD in this review using drug development trial data, compared with the 2006 FDA report based on similar data. Several differences between the two reports are: 1) the time frame for data; 2) the inclusion of active controlled trials without a placebo arm in this review, but not 2006 FDA report (and the higher suicide rates in active control trials, perhaps due to patient severity); 3) a difference in included medications (duloxetine and escitalopram were not included in this report). In general, however, suicide rates in this report are consistent with the other systematic reviews and regulatory reviews.

Khan 2003:^126^ This review of regulatory data obtained summary reports used as the basis of FDA approval for five SSRIs (citalopram, fluvoxamine, fluoxetine, paroxetine, and sertraline) to determine suicide risk in SSRI users; these reports summarized an unreported number of clinical trials submitted for regulatory approval from January 1985 to January 2000. Information on trial setting or included patients is lacking except that patients did not have psychotic features and had never had hypomania or mania. Suicides were assigned to the drug the person was taking at the time of the event, even if the trial primarily addressed another medication. It was not clear how those who discontinued treatment were classified. Suicide rates were 14.6 per 10,000 persons among SSRI users and 10.2 per 10,000 users among placebo, which were not significantly different. These suicide rates are much higher than those reported in other reviews, particularly considering that patients with all indications may have been included. However, the relative predominance of active controls, compared with placebo controls, among these trials suggests that these were more severely ill patients (as more severely ill patients would be less likely to be enrolled in trials with placebo treatment).

MHRA Regulatory 105,131 and Other Related Reviews:138,139 The Medicines and Healthcare products Regulatory Agency (MHRA) and the Committee on the Safety of Medicine in the United Kingdom requested analytic work on suicides, non-fatal self-harm, and suicidal thoughts with use of SSRIs which has been reported in peer-reviewed publications138,139 and technical reports.105,131 This work examines 439 placebo-controlled trials submitted for regulatory approval providing data on six SSRIs (citalopram, escitalopram, fluoxetine, fluvoxamine, paroxetine, sertraline) in a total of 52,503 patients treated for all indications for a mean of 8–10 weeks (with patient numbers varying by analysis). A total of sixteen suicides, 203 episodes of non-fatal self-harm, and 177 reports of suicidal thoughts occurred.

Results among all adults suggested no impact of SSRI treatment on completed suicides (OR 0.85; 95 percent credible interval 0.20, 3.40), on non-fatal self-harm (OR 1.21; CI: 0.87, 1.83), or on suicidal thoughts (OR 0.80; CI: 0.49, 1.30). Due to data limitations, this study included suicides from fluoxetine trials in the self-harm category rather than the suicide category. The suicide rate in patients taking SSRIs (except fluoxetine) was 3.8/10,000 persons, compared with 4.1/10,000 persons in those on placebo. Although not significantly different, the direction of the main effect of treatment compared with placebo in suicide-related behaviors (increased), was opposite the main effect in suicidal ideation (decreased), which is consistent with the FDA reports described above. Meta-analyses were not conducted at the patient level and thus weren’t stratified by trial type or adjusted for issues such as disease severity, age, or suicidal history. The proportion of patients with MDD vs. other indications could not be determined. This study did not include studies other than those submitted to the MHRA by the manufacturers, which could exclude trials conducted for non-regulatory reasons with less favorable adverse effects findings. However, given the large sample sizes needed for these rare outcomes, it is unlikely that there are independent investigators conducting large trials considering suicide or related events, and none were located during our systematic searches.

Looking specifically at paroxetine, data from 57 placebo-controlled RCTs of paroxetine treatment in 5433 adults with MDD were made available by the manufacturer.131 Definitive suicidal behavior (without any fatalities) was increased in those on paroxetine relative to placebo (OR 6.7; CI: 1.1, 149.4), and eight of 11 events of suicidal behavior occurred in young adults (18–29 years). The risk difference for suicidal behavior was 26.8 per 10,000 (CI: 5.5, 48.0), with a NNT-H of 373 (CI: 208, 1818). When suicidal behavior and ideation were considered together, there was no significant difference between those on paroxetine and those on placebo (OR 1.3; CI: 0.7, 2.80).

Fergusson:130 This fair quality systematic review of 411 published, randomized, placebo-controlled trials of five SSRIs (citalopram, fluoxetine, fluvoxamine, paroxetine, sertraline) in 18,413 adults treated for all indications for a mean of 10.8 weeks complements the MHRA review of regulatory data from the same time period (1967 through 2003). This review included the same SSRIs as the MHRA review, except for escitalopram, which was only included in the MHRA review. The number of patients and events were much smaller in this review of short-term trials that were published only: a total of seven suicides and 29 attempts in 18,413 patients. Rates of suicides (3.8 per 10,000 persons) were almost identical in this review and the MHRA review, but lack of similarity between the categorization of other suicide-related events prevents comparisons between these two meta-analyses. Rates of suicide did not differ between those on SSRI treatment and placebo (OR 0.95; CI: 0.24, 3.78). Combined fatal and non-fatal suicide attempts were increased in those on SSRIs, compared with placebo, (OR 2.28; CI: 1.14, 4.55), driven by the difference in non-fatal attempts (OR 2.70; CI: 1.22, 6.97). Adverse events may have been underreported given the reliance on published data only and since adverse event reporting was not available from the majority of trials. Also, almost half (46 percent) of trials had dropout rates of over 25 percent, which means adverse events were likely to have been missed, especially given that longer duration trials (7 weeks or longer) had an increased risk of fatal and non-fatal events. Even though this review included published trials only and half of patients in this review were in trials funded by the pharmaceutical industry, industry-funded trials reported an increased risk of fatal and non-fatal events with treatment compared with placebo while those funded by other sources did not.

Storosum 2001:^140^ This review considered 85 short-term and longer-term clinical trials submitted to the Medicines Evaluation Board of the Netherlands from 1983–1997 for approval for use in major depression and another 14 placebo-controlled trials of antidepressant medications in those with MDD published from 1990–1999. Antidepressant drugs were not specified, but could have included nine second-generation antidepressants (bupropion, citalopram, fluoxetine, fluvoxamine, mirtazapine, nefazodone, paroxetine, sertraline, venlafaxine), if the Netherlands approval dates coincide with those in the US.125 Rates of suicide in 77 short-term studies of patients with MDD were 8.8 per 10,000 persons treated with active drug, compared with 9.3 per 10,000 persons treated with placebo. Similarly, suicide attempts were not increased in those taking active drug compared with placebo. For all of these meta-analyses, the results are compromised by the type of trials available for review. The majority of trials were short-term efficacy designs that tend to screen out higher risk patients, including those at risk for suicide. None of these trials were designed to measure adverse effects, which is especially problematic for rare events such as suicide and events that may not be spontaneously reported such as suicide-related behaviors and ideation. As such, these analyses are plagued by issues related to power and measurement bias, particularly given the large dropout rates after which adverse events may not have been captured. Differences in event definition for analyses across meta-analyses complicates comparisons. Generalizability of this evidence is questionable due to very short time periods and that fact that participants differ from those seen in clinical practice in important ways: volunteers for studies generally have more mild to moderate depression; exclusion of those that are suicidal or at high risk upon entry to trial; and exclusion of those with comorbid psychiatric or medical illnesses. Therefore, we sought large observational studies and uncontrolled treatment studies in community settings as supplements.

#### Suicide and related-events, cohort studies

We found seven large observational studies128,129,143–146,148 from five separate practice or prescription data sources which reported adverse suicide-related events in a total of 1,064,603 patients receiving antidepressant prescriptions over 6 months to 5 years, plus 59,432 depressed patients who did not receive antidepressants. And, although many observational studies focused on comparative effectiveness, we were interested in absolute adverse event rates to determine the applicability of adverse event rates from the short-term clinical trials to primary care practice. Observational studies that could not supply absolute adverse event rates were not included. In observational pharmacoepidemiological studies, confounding by indication (e.g., the tendency of clinicians to prescribe drugs differentially based on disease severity, to give drugs that are less toxic in overdose, such as SSRIs, to their suicidal or more severe patients, or the tendency for clinicians to try newly available medications in treatment-resistant cases) is a major threat to validity for non-randomized drug-drug comparisons.149 Data from several recent studies on antidepressant use in the community demonstrate that adjustment for potential confounders is not sufficient to remove all residual confounding by indication.150,151 Given these quality concerns, we focus on the results from the three fair or good quality reports here,127–129 with the remainder covered in Appendix G Table 8.^144–147^

Simon 2006:^129^ In a good-quality cohort study in a large, prepaid, group practice from 1992–2003, suicides and attempts requiring hospitalization were assessed in 65,103 patients aged five to 105 years with diagnosed MDD, dysthymia, or depression NOS after their first dispense (for at least the prior 6 months) of any antidepressant. Patients could contribute more than one episode of “new” treatment. In the entire covered population, the suicide rate was 1.7 per 10,000 persons during this time period. There were 31 suicides and 76 suicide attempts requiring hospitalization during the 6 months after beginning “new” antidepressant treatments or 4.8 suicides per 10,000 persons treated and 11.7 suicide attempts per 10,000 treated. Men had higher odds of suicide death than women (OR 6.6; CI: 2.9, 14.7), with no variation across age nor across time from beginning treatment. Suicide attempts were greatly increased in those under age 18 (3.14 per 10,000 CI: 16, 46.8;) compared to those 18 years and over (7.8 per 10,000 persons, CI: 5.8, 9.8). There were almost as many serious suicide attempts during the six months preceding a “new” antidepressant as in the succeeding six months (76 and 73, respectively). Rates of suicide attempts remained the highest during the month preceding “new” treatment for adults and adolescents after excluding those with prior antidepressant treatments or suicidal attempts. Rates of suicide attempts were also increased in the month after starting “new” treatment compared with the subsequent five months (OR 2.4; CI: 1.6, 3.8), during which suicide attempts declined.

UK General Practice Research Database: Two studies utilized primary care records from the UK General Practice Research Database to examine harms associated with first dispense (for at least the prior 12 months) of antidepressants.127,128 The more recent report using records from 1995–2001, which more fully represents the time period of use for second-generation antidepressants, was a good-quality cohort study evaluating suicides and self-harm events among 146,905 youth and adults aged 10 to 90 years (18 percent over 60 years) with diagnosed depression, dysthymia, or bipolar disorder after their first dispense of any of 26 first and second-generation antidepressants.128 The median duration of follow-up was 0.66 years with an interquartile range of 0.57 to 1.03 and a total of 62,224 person-years for the whole cohort. In that time, 69 suicides occurred (56 in men and 13 in women; 19 in those aged 19 to 30 years) and 1,968 self-harm events. The self-harm events were primarily drug overdoses (81 percent). Thirty-six of the 69 patients who committed suicide (52 percent) were taking antidepressants at the time of their death. Outcomes were ascertained using death certificates along with diagnoses and reviewing free text notes from medical records. In those taking any antidepressant, the rate of suicide was 4.7 per 10,000 persons of all ages and 5.5 per 10,000 persons aged 19–30. The rate of self-harm was 134.7 per 10,000 persons of all ages and 214.7 in those aged 19–30 years. The standardized incidence rate for suicide (standardized to the age and sex of the UK population) was 6.2 (CI: 4.0, 8.5) per 10,000 person years, which was significantly higher in men (11.7 per 10,000 person-years) than women (0.9 per 10,000 person-years). In contrast, there was no sex difference in the standardized incidence rate for self-harm. Compared with those not exposed to antidepressants, unadjusted odds of suicide were increased three-fold or more in those with a history of self-harm, with referral to a mental health professional (possibly a proxy for more severe disease), with antipsychotic use, and with use of more than one antidepressant. Similarly, unadjusted odds of self-harm were increased three-fold or more in those with history of self-harm, with a mental health referral, with a comorbid alcohol misuse, and with use of more than one antidepressant. A fair-quality older study using similar methods and primary care records from 1988–1993, researchers examined suicide events for six months after dispenses of nine antidepressants (all first generation except for fluoxetine) for all indications.127 There were 143 suicides among 172,598 persons taking antidepressants during 167,819 person-years of observation; the overall suicide rate was 8.5 (95 percent CI, 7.2, 10.0) per 10,000 person-years. Of the 143 individuals who committed suicide, 67 had a history of attempts (47 percent) and most (78 percent) had documented depressive illness.

Serious psychiatric effects (hospitalization, mania precipitation). Very few studies were found. In a large good quality open-label effectiveness study of 2,876 screen detected outpatients with previously established non-psychotic major depressive disorder (in 18 primary care and 23 psychiatric community settings) treated with an SSRI (citalopram) under a protocolized treatment approach, 2 percent of patients experienced a serious psychiatric event (defined as suicidal ideation or hospitalization for worsening depression, substance abuse, suicidality, and other).53 These data did not distinguish suicide-related harms from other serious psychiatric events. In another large fair-to-poor quality post-marketing study of primary care patients treated with one of six second-generation antidepressants, after exclusion of those with pre-existing mania, there were 1.2 reports of mania per 1000 patient-months of treatment within the first three months of treatment with no indication of the severity of the mania.147

Tolerability. Although measurement methods are not very robust, a recent systematic review of comparative effectiveness of second-generation antidepressants reported that, on average, 61 percent of patients in efficacy trials of SSRIs and other second-generation antidepressants experience at least one adverse effect (e.g., nausea, headache, diarrhea, fatigue, dizziness, sexual dysfunction, tremor, dry mouth, or weight gain).92 In a large fair to poor quality prescription event monitoring study of primary care patients,147 nausea and vomiting, malaise, headache, dizziness, and drowsiness were reported in at least one-quarter of patients on one of six second-generation antidepressants during the first month of treatment. Since adverse event profiles appear to vary somewhat among medications that are equivalent in efficacy, clinicians may aim to minimize potential side-effects when choosing among first-line antidepressants.92,129

Early medication discontinuation is common, particularly in antidepressants, and can compromise expected benefits from treatment initiation. Since early discontinuation can result from several factors (e.g., lack of efficacy, intolerable side-effects, due to achieving complete treatment response), discontinuation due to adverse effects is a more accurate proxy for tolerability. Studies examining discontinuation due to adverse effects are detailed in Appendix G Table 6.

We located three at least fair quality systematic reviews or meta-analyses (in four publications) of mostly short-term (6–8 week) randomized controlled trials that compared SSRIs and/or other second generation antidepressant with placebo that reported overall discontinuation rates and discontinuation due to adverse effects for antidepressants and for placebo.72,75,91,95 We included four additional, at least fair quality, comparative effectiveness reviews of short-term, head-to-head trials that reported on total and adverse effect-related discontinuation rates for second generation antidepressants.90,92–94 Two fair-quality uncontrolled treatment trials46,96 provided longer term (up to 10 months) discontinuation data. Five of the nine studies provided antidepressant discontinuation rates in primary care patients,72,75,93,95,96 with one of these clearly conducted in community-based primary care.96 Two reported data for older and younger patients separately.90,94

In trials of primary care patients with depression, short-term early discontinuation (within the first 2–3 months) for SSRIs for any reason ranged from 16 to 29 percent.75,93,96 Short-term SSRI discontinuations from non-primary care populations fell within this range,46,90–92 except for potentially higher total discontinuation rates in patients on higher doses (38 percent)91 and in patients aged 55 years and older (27 to 36 percent).90,94 These are unadjusted rates and most are based on relatively small numbers of patients, so any apparent age- or dose-related differences may not be statistically significant. Considering the data we found from “real-world” trials in primary care as best evidence, a reasonable best-case estimate of short-term overall SSRI discontinuation rate in primary care adults is 20 to 23 percent. As expected, with longer follow-up, total discontinuation for SSRIs increased to around 33 percent after 6 months.96 Discontinuation after this time, however, could be due to remission (which is common after about 20 weeks) in both new and recurrent152 patients, particularly in older studies in which treatment continuation beyond remission was not emphasized to clinicians.57

Discontinuation due to adverse events in primary care patients taking SSRIs and other second generation antidepressants ranged from 5 to 12 percent during the first 3 months.72,93,95 Short-term antidepressant discontinuations from non-primary care populations fell with in the same range90–92 or were higher in some studies of specific SSRIs or doses (14 to 16 percent)46,91 and in patients aged 55 years and older (17 to 22 percent).90,94 People who switched or augmented medications after lack of efficacy or intolerable side-effects in initial treatment had increased rates of discontinuation through each successive treatment regimen (up to 30 percent in 8 to 10 weeks), possibly indicating more severe or treatment resistant disease.46 In community-based primary care, 26 percent of SSRI users discontinued use at 9 months due to adverse events.96 These are unadjusted rates and most are based on relatively small numbers of patients, so any apparent differences may not be statistically significant.

##### Older adults

Adverse events: We found no admissible evidence focused solely on older adults for suicidality, serious psychiatric effects, and discontinuation in older adults. Adverse events considered for general adults apply to older adults to the extent that trials and studies include older participants. For most meta-analyses, however, participant-level descriptive data were not available; one FDA review124,125 reported age-related results. For cohort studies, patients over 65 years were in the included age ranges, but data were not reported separately for this age group. Below we summarize available subgroup analyses from the trials and studies discussed above and summarize. One systematic review reporting on serious medical issues (upper gastrointestinal bleeding) in adults and older adults with antidepressant use.

Suicidality: Older patients (ages 65 years or older) on antidepressant medications showed a reduction in suicidal behaviors (OR 0.06; CI: 0.01, 0.58) and in suicidality (suicide deaths, suicidal behaviors and suicidal ideation) (OR 0.39; CI: 0.18, 0.78), compared with placebo.124,125 For all types of suicide-related events (suicide, attempts, preparatory acts, and ideation), crude rates were lower in the antidepressant-treated group than in placebo. Cohort studies did not provide more specific information on this population subgroup.

Serious medical issues: We found a fair-quality systematic review of six observational studies examining the risk of bleeding in antidepressant users (particularly those on SSRIs or with greater inhibition of serotonin reuptake) which reported on patients at increased risk of UGI (upper gastrointestinal) bleeding (e.g. older persons) and also examined synergistic effects with other medications that are known causes of UGI bleeding.132 The quality of this review was limited by searching only in MEDLINE, by inadequate reporting of search results and inclusion/exclusion activities, and by lack of quality assessment of included studies. This review included four large population-based database studies evaluating UGI bleeding and two studies evaluating any abnormal bleeding. For UGI bleeding, the four studies included a total of 14,128 cases of UGI bleeding in 419,897 persons from the UK General Practice Research database (1993–1997), province-wide health records for older adult patients in Ontario, Canada (1992–1998), population-data from Denmark (1991–1995), and the Health Improvement Network from GPs in England and Wales (1990–2003). After excluding those with previous GI bleeding (and other risk factors for GI bleeding) from Danish cases and controls, 26,005 patients aged 16 to 104 (48 percent aged 60 years or older) using antidepressants were at increased risk of hospitalizations for UGI bleeding.135 During periods of active SSRI use, hospitalizations for UGI bleeding were 4.3 per 1000 person-years of treatment compared with never-users, with an excess risk of 3.1 per 1000 person-years. Rates were further increased in those using SSRIs and NSAIDs only (17.7 per 1000 person-years), SSRIs and low-dose aspirin (13.0 per 1000 person-years), and SSRIs with other drugs (17.0 per 1000 person-years). Risks with SSRI use were removed after termination of treatment. To a lesser extent, rates of hospitalization for UGI bleeding were also increased in adults on older (first generation) non-SSRI antidepressants both during and after treatment. The comparison cohort was not age-or sex-matched, and there could have been differences in risk of GI bleeding between users and non-users of anti-depressants that explain different rates of bleeding between the two groups. However, demonstration of no significantly increased risk during periods when antidepressant users were not taking SSRIs (specificity of effect) increases confidence in these findings.

In 317,824 older Canadian patients (all over aged 65 years) prescribed SSRIs or other antidepressants, risk of hospitalization for UGI bleeding greatly increased with age.134 For those aged 65–70 years, rates were comparable to the Danish study (4.1 per 1000 person-years) but increased to 7.2 per 1000 person-years in those 70–75 years, 8.8 per 1000 person-years in those 75–80 years, and 12.3 per 1000 person-years in those over 80 years of age. For older patients with a history of previous GI bleeding, hospitalizations for UGI bleeding ranged from 28.6 per 1000 person-years to 40.3 per 1000 person-years (overall 33.2 per 1000 person-years), depending on how strongly the SSRI caused serotonin inhibition. The relative risks of UGI bleeding among older persons taking SSRI antidepressants were also increased in those on non-steroidal anti-inflammatory drugs (NSAIDs) (RR 2.8; CI: 2.4, 3.3), anti-coagulants (RR 2.2; CI: 1.7, 2.8), peptic ulcer treatment (RR 2.1; CI: 1.8, 2.4) and to a lesser extent, aspirin (RR 1.7; CI: 1.4, 2.0). In the UK GPRD database, only 3.1 percent of 1651 patients aged 40–79 years with UGI bleeding were current users of SSRIs, but the odds of SSRI use or of NSAID drug use were significantly increased (2–3 fold) in persons with UGI bleeding compared with age-and-sex matched controls.133 In this report, there was a strong interaction between these two, such that the odds were increased markedly (OR 15.6; CI: 6.6, 36.6) for NSAIDS and SSRIs combined. However another general practice-based report (The Health Improvement Network) from England and Wales found no clear increase in risk of UGI bleeding in 11,261 adult cases of UGI bleeding compared with 53,156 controls for SSRIs plus NSAIDs compared with SSRIs alone.136 Two other studies listed in the review report on risk of any abnormal bleeding. One study from the Drug Safety Research Unit in the UK using prescription event monitoring data supplied by GPs found weak evidence to support more bleeding events in the first six months among 50,150 new users of SSRIs compared to users of other psychiatric drugs or non-psychiatric drugs.153 As with many of these prescription event monitoring studies, adverse event ascertainment was limited due to a 51 percent response rate from surveyed GPs. In a nested case-control study from the Netherlands, rates of hospitalization from 1992–2000 for a primary diagnosis of any type of abnormal bleeding were 4.9 per 1000 person-years in 64,000 new users of second-generation antidepressants aged 18 and older, with higher risks linearly associated with greater degrees of inhibition of serotonin intake in antidepressants.154

We found one good-quality large prospective population-based community cohort study that evaluated the effect of daily SSRI use on the risk of clinical fragility fracture, bone mineral density, and falls over 5 years among 5008 subjects (137 daily SSRI users) aged 50 years and older.155 After adjustment for potential confounders including age, total hip BMD, modified Charlson index, prevalent vertebral deformity, prevalent fragility fractures at baseline, and cumulative lifetime estrogen use in women, daily SSRI use was associated with a two-fold increased risk of radiographically-confirmed fragility fractures (HR 2.1, CI: 1.3, 3.4) and a reduction in bone mineral density at the total hip. In those with daily use compared with non-users, after adjustment for history of falls, there was a two-fold increased risk of falls (HR 2.2, CI: 1.4, 3.5). Fracture rates did not appear to be moderated completely by the impact of daily SSRIs on falls or on BMD, as they remained elevated after adjustments for these risk factors. The duration of use among daily SSRI users could not be confirmed.

Tolerability: Crude rates of early discontinuation for any reason, and for adverse effects, appeared higher in older adult patients than in younger patients. In two comparative effectiveness meta-analyses, about one-third (32 to 36 percent) of patients 55 years and older discontinued antidepressants within 3 months.90,94 Discontinuation due to adverse effects occurred in 17 to 22 percent of seniors in clinical trials. These are unadjusted rates and are based on relatively small numbers of patients, so absolute rates should be taken as an approximation and any apparent differences may not be statistically significant.

## Summary of Evidence Quality

Table 10 summarizes the overall quality of evidence according to USPSTF criteria and other considerations about the body of evidence for each of the key questions addressed in this review.

Table 10 Summary of Evidence

No. of studies | Design | Limitations | Consistency | Applicability | Overall Quality | Summary of Findings
KQ1. Depression outcomes in screened vs. unscreened patients
1^10^ | Controlled comparison (Subgroup analysis of larger RCT) | Single study; follow-up limited to one of two sites and to depressed patients plus random sample with depressive symptoms; not a truly randomized comparison; contamination possible. | Not applicable | Fair; representative primary care sample, but results do not represent population-level results from a screening program. | Fair | Increased likelihood of remission at 3 months among those with depression diagnosis at baseline interview (48% remission in screened vs. 27% in unscreened), but overall proportion with depression diagnoses at follow up did not differ between screened and unscreened groups (37% in screened vs. 46% in unscreened).
KQ1a. Depression outcomes in trials of screening + feedback (+ other supports allowed) vs. screening without feedback
8^109–116^ | RCTs, two randomized at the patient level; six at the clinic or practice session level; three of those using clinic-level randomization trials used cluster randomization | No non-screened control groups; considerable variability in intensity and type of additional care supports provided. | Fair; some studies found a positive effect and some did not; considerable variability on several dimensions (e.g. type of care supports, population characteristics) which may explain inconsistencies | Fair; all involved screen-detected primary care samples, although 2 limited enrollment to only those with newly detected depression and an additional trial included only patients screening positive for multiple conditions, one of which was depression, thus limiting generalizability to general primary care populations. | Fair to good; most studies fair quality, but also had two good quality large-scale trials. | Four trials of screening and feedback alone or with extra components to improve the effectiveness of the primary care provider’s treatment did not improve depression at 6–12 month follow-up compared with screening without feedback in usual care. Four programs with additional staff providing depression treatment or case management to depressed patients reduced depression, though only among patients with newly-identified depression in two cases (on trial limited participants to newly-identified patients, on reported results separately for newly-identified patients). We cannot determine the degree to which screening and feedback was necessary to the programs’ successes. One of the four trials in older adults was effective in improving depression, which was the only trial in older adults that included substantial involvement of staff other than primary care provider.
KQ2. Harms of screening
No evidence
KQ3. Treatment in older adults
3^120–122^ | Meta-analyses | Included trials outside the scope of our review, e.g., patients in residential or inpatient settings and studies involving minor depression. | Good | Fair; most trials very short term and not done in primary care settings; many trials only included patients with mild-moderate depression and limited comorbidities; some trials conducted in residential or inpatient settings. | Good | Antidepressants and psychotherapy are effective in treating older adult patients. Patients taking antidepressants were roughly twice as likely to achieve remission than those taking placebo pills, and patients in psychotherapeutic treatment were more than twice as likely to achieve remission than those in control conditions, which included wait-list, attention placebo, or pill placebo.
KQ4. Harms of antidepressant treatment in adults and older adults
Suicide and Suicide related events
13^125–131,137,138,140,143,144,146^ | Individual and trial-level meta-analyses of placebo controlled drug efficacy RCTs in 6 regulatory reviews (and associated reports) and 1 systematic review 6 large cohort studies in US, UK, and Denmark following 1,064,603 pts for 6 months to 5 years after receiving antidepressant prescriptions | Most trials were short-term (6–8 week) efficacy trials for drug approval. Between-trial differences in outcome definitions, ascertainment time periods, and treated populations limit comparability of findings. Low event rates minimize power. | Findings across analyses are consistent for age-related differences in risks for suicide-related antidepressant treatment harms, for the timing of greatest risk for suicide-related events, and for highest risk of suicide-related events in patients with MDD and in males. Absolute event rates differ across meta-analyses more than can be explained. Cohort studies complement and extend findings from RCTs. | Fair due to RCTs including more highly selected, lower risk populations than primary care and due to short-term trial duration. Cohort studies provide additional follow-up in less selected patients treated with antidepressants through 10 months and are generally consistent with rates of suicide in clinical trials. | Fair-to-Good | Current evidence does not demonstrate an impact on suicides in those treated with second-generation antidepressants (mostly SSRIs) compared with placebo, although results are also consistent with a small protection or some increase in risk. Suicidal behaviors appear to be increased in young adults (aged 18–29), particularly those with major depressive disorder and those on paroxetine. The impact of antidepressant treatment on suicidal ideation appears to differ from the impact on suicidal behaviors, but many analyses combine these. In older adults, treatment with antidepressants confers a statistically significant protective effect on suicidal behavior and on suicidality. In cohort studies with 6–8 month follow-up duration, crude suicide rates were 4.7 to 4.8 per 10,000 persons treated, with higher rates reported among children and adults under 30. These rates are comparable to the findings in many of the short-term RCT meta-analyses in adult groups not restricted to major depressive disorder. Men had increased risks (at least 3 times greater) for suicide deaths compared with women. In contrast, there were no sex differences in self-harm risks, and rates varied substantially between studies due to definitional (and perhaps ascertainment) differences. These studies consistently indicate the highest risk for suicidal behaviors is in the month prior to and immediately after beginning antidepressant treatment.
KQ4. Harms of antidepressant treatment in adults and older adults (continued)
Tolerability
9^46,72,90,92–96,192^ | Meta-analyses of short-term placebo-controlled RCTs in 7 systematic reviews 2 uncontrolled primary-care and specialty community-based treatment trials | Tolerability is a non-specific measure of minor but common adverse effects | Fair—differences in measurement, study durations, and populations make ranges most accurate estimates. Short-term and long-term studies generally consistent. | Fair—3 systematic reviews focused on primary care patients. Data gathered under clinical trial situations may not reflect real-world treatment experience. | Fair-to-Good | In primary care patients with depression, early antidepressant discontinuation for any reason ranges from 16% to 29%, with a best estimate of 20% to 23%. Discontinuation due to adverse events in primary care patients ranges from 5% to 12% in the first 2–3 months to 26% at nine months. In some studies, higher doses of medication and older age were associated with increased rates of early discontinuation (overall and due to adverse effects).
Serious medical events (upper GI bleeding)
2^132,155^ | 1 qualitative systematic review of 4 large population-based studies of 419,897 adults taking antidepressants (14,128 cases of UGI bleeding) 1 large prospective cohort study | Only large observational studies were located; no trial evidence. We relied on the reviewers findings with some checking of the original articles. | Consistent findings between studies of bleeding. Specificity of effect supported by association between active SSRI use and UGI bleeds (compared with periods off drugs) and by increased risk in medications with greater serotonin reuptake inhibition. | Good | Fair-to-Good | Low-risk older patients on SSRIs had an excess risk of 3.1 UGI bleeds per 1000 treatment years during periods of active SSRI use compared with non-use and an excess of hospitalizations for UGIB of 4.1 per 1000 treatment years among older antidepressant users and 11.7 to 12.3 per 1000 treatment years in persons with prior UGI bleeding or those over 80 years of age. Increased UGI bleeds in adults 40–79 years currently taking SSRIs (adj. OR 3.0, 95% 2.1, 4.4) were much higher with concurrent use of NSAIDs (adj OR 12.2, 95% CI 7.1, 9.5) and to a lesser extent, low-dose aspirin (adj. OR 5.2, 95% CI 3.2, 8.0). To a lesser degree, UGI bleeds increased in current non-SSRI antidepressant users, (OR 1.4, 95% 1.1, 1.9) but with no interaction with NSAIDs or aspirin. UGI bleed risk associated with SSRIs showed greater increase in medications with a moderate to high degree of serotonin reuptake inhibition. Daily SSRI use was associated with a two-fold increased risk of fragility fractures and risk of falls.