# Methods

## Methods Synopsis

Using the USPSTF’s methods104 (Appendices B–D), we developed an analytic framework (Figure 1) and five key questions (KQ) that focused on the evidence the USPSTF required to update its recommendation. For all questions, disorders of interest were Major Depressive Disorder, Dysthymia, Depression Not Otherwise Specified (including Minor Depression), or “depression” with no further diagnostic specificity. However, we did not include evidence that focused exclusively on Dysthymia or Minor Depression. KQ1 examined direct evidence that screening programs for depression among adult and older adult primary care patients reduce morbidity and/or mortality. KQ1a examined the impact of clinician feedback of screening test results (with or without additional care management support) on depression response and remission in screen-detected depressed patients receiving primary care. KQ2 examined the adverse effects of screening for depressive disorders in adults and older adults. We did not re-examine screening test accuracy in adults or older primary care patients as that was adequately established in the prior review.71 KQ3 examined the effectiveness of antidepressant and/or psychotherapy treatment of older adult depressed patients for improving health outcomes, including depression response and remission. The goal of KQ3 was to answer the focused question of whether there are effective agents for treating depression in older adults, and not on identifying the best treatment or the optimal way to implement the treatment. Therefore, we did not include comparative-effectiveness trials or trials that aimed at improving delivery of known effective treatments. We did not update the effectiveness of depression treatment in adults as that was established in the last review.71 KQ4 assessed the major adverse effects of antidepressant treatments for depression in adults and older adults, with a focus on second-generation antidepressants (SSRIs in particular) due to the preponderance of use of these in the US.

Figure 1 Analytic Framework

1. Is there direct evidence that screening for depression among adults and the elderly in primary care reduces morbidity and/or mortality? a. What is the impact of clinician feedback of screening test results (with or without additional care management support) on depression response and remission in screen-detected depressed patients receiving usual care?

2. What are the adverse effects of screening for depressive disorders in adults and in elderly patients in primary care?

3. Is antidepressant and/or psychotherapy treatment of elderly depressed patients effective in improving health outcomes?

4. What are the adverse effects of antidepressant treatment (particularly SSRIs and other second-generation drugs) for depression in adults and the elderly?

This figure depicts the analytic framework for screening for depression in adults. The diagram starts on the left with two lines of text which read “Adults 18 to 64 years” and “Adults 65 years and older.” An arrow then leads to the right; above the arrow appears “Screening.” The arrow then forks in three directions. Arrow 1, which proceeds up and to the right, represents Key Question 1, which is: 1) “Is there direct evidence that screening for depression among adults and the elderly in primary care reduces morbidity and/or mortality?” and 1a) “What is the impact of clinician feedback of screening test results (with or without additional care management support) on depression response and remission in screen-detected depressed patients receiving usual care?” Arrow 1 goes directly to the end of the diagram on the far right. Arrow 2 represents Key Question 2, which is “What are the adverse effects of screening for depressive disorders in adults and in elderly patients in primary care?” Arrow 2 curves down and ends at an oval reading “Adverse effects.” The third fork proceeds to the right, to a box labeled “Patients identified with depression.” From there, the arrow forks in two directions. Arrow 3 represents Key Question 3, which is “Is antidepressant and/or psychotherapy treatment of elderly depressed patients effective in improving health outcomes?” Arrow 3 leads to the right, to the last box of the diagram. This box contains six bullets: Bullet 1: Diagnosis of a depressive illness; Bullet 2: Depressive symptomatology; Bullet 3: Quality of life ratings; Bullet 4: Assessments of functioning; Bullet 5: Suicidality (attempts or ideation); Bullet 6: Change in health status (e.g., death, improvement in comorbid disorders, reduction in physical complaints). Arrow 4 curves down from the midpoint and ends at an oval reading “Adverse effects.”

For all key questions, we searched for systematic reviews, meta-analyses, and evidence-based guidelines on depression screening, treatment, or associated harms in adults and older adults in the Database of Abstracts of Reviews (DARE), MEDLINE, and PsycINFO from 1998 through December 2007, and the Cochrane Database of Systematic Reviews (CDSR) from 1998 through October 2006 (with updates through December 2007). Once we identified relevant reviews in the CDSR, we hand-checked for updates periodically through December, 2007. We also conducted a series of searches corresponding to the key questions and reviewed each search for applicability to the other key questions.

For KQ1 and KQ1a, we searched for RCTs/CCTs of depression screening in primary care to cover the time period since the previous USPSTF review (1998 through December, 2007) in MEDLINE, PsycINFO, and Cochrane Collaboration Registry of Clinical Trials (CCRCT). We further searched Science Citation Index, Social Science Citation Index, Science Direct, high Wire Press, and Google Scholar from 2000 to March 2006 for articles referencing the single screening trial from the previous USPSTF review that included a non-screened comparison group.10 In addition to our searches, we considered all screening-related trials identified from the previous USPSTF review,71 from a 2005 Cochrane review on depression screening,100 and from a review on educational and organizational interventions for depression101 for inclusion. Trials were eligible for KQ1 if they compared screened and unscreened patients. For KQ1a, patients must have been screened for depression and the trial must have used the screening results in the care of the intervention participants and must not have used the screening results in the care of the control participants.

For KQ2, we searched MEDLINE and PsyccINFO from 1998 through December, 2007 for trials discussing harms of screening for depression in primary care settings or in populations generalizable to primary care, without restrictions on study designs. For KQ3 we searched MEDLINE, PsycINFO, and CCRCT for systematic evidence reviews, meta-analyses, and trials of psychotherapy and antidepressant treatment in older adults in two separate searches covering 1998 through December, 2007 for psychotherapy and 2003 through December, 2007 for antidepressants. Because we found good-quality recent meta-analyses, we limited our review to synthesized evidence. We did not restrict KQ3 and KQ4 to trials in primary care settings.

For KQ4, we examined all relevant meta-analyses, trials, and large observational studies from several current systematic reviews and evidence-based guidelines addressing treatment-associated harms.57,92,105 We focused our review of harms on already synthesized evidence supplemented by large observational studies located through searching MEDLINE from 1988 through December, 2007 for publications that included SSRI terms and terms related to either suicide or discontinuation without restrictions with regard to study design. Inclusion and exclusion criteria specific to each question are detailed in Appendix C and D. For screening program and treatment effectiveness, we focused on depression response, remission, and other health outcomes. For harms, we focused on suicide-related events, serious psychiatric events, serious medical events (for older adults), and discontinuation (overall and due to adverse events) as measures of tolerability.

Two investigators reviewed all abstracts. Articles were evaluated against a set of inclusion/exclusion criteria, including design-specific quality criteria based on the USPSTF methods (Appendix B), supplemented by NICE106 and Oxman107 criteria for systematic reviews. All studies excluded for quality reasons were critically appraised by two investigators. Data from included studies were abstracted into evidence tables by one investigator and checked by a second. Most data synthesis was qualitative since we judged that trials were not similar enough to allow quantitative syntheses for KQ1 (see Appendix F for between-study differences in potential confounders). For KQ2, we found no data, and we relied on already synthesized evidence for KQ3 and KQ4.

For KQ4, we abstracted data to calculate absolute event rates for suicide-related events from meta-analyses and systematic reviews, with 95 percent confidence interval (CI) calculated based on a Poisson distribution using the SAS version 8.2 GENMOD procedure with the offset option set at the log of the event rate. Risk differences with 95 percent CI for suicide-related events in patients with MDD (a relatively homogeneous risk group) on active medication were calculated using the RISKDIFF option of the FREQ procedure in SAS 8.2. This procedure uses a normal approximation to the binomial distribution to construct asymptotic confidence intervals. (SAS Version 8.2 for Windows, SAS Institute Inc., Cary, North Carolina)

## USPSTF Involvement

The authors worked with four USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions, resolve issues around scope and approach, and will work with them to finalize this draft report. Research was funded by the Agency for Healthcare Research and Quality (AHRQ) under a contract to support the work of the USPSTF and AHRQ staff provided oversight throughout the project.