# Appendixes

Appendix A Current practice details

Appendix B USPSTF Hierarchy of research design and quality rating criteria

Appendix C Inclusion and exclusion criteria for key questions

Appendix D Detailed methods

Appendix E Previous Adult Depression Reviews

Appendix F Meta-analysis decision factors

Appendix G Evidence Tables