# Evidence Tables

Appendix G Table 1 Evidence table of screening trials-KQ1 and KQ1a.

Study USPSTF Quality | Study design Unit of randomization Point of randomization Setting | Intervention and control conditions | Depressive disorders identified or targeted % Currently treated for depression | Location Population targeted | CONSORT numbers | Population characteristics Baseline depression scores | Inclusion and exclusion criteria | Screening instrument Mode of administration Who administered and scored How results sent to clinician Diagnostic work-up | Follow-up | Outcomes Depression outcomes Other health outcomes Adverse events | Group selected for analysis Similarity to all randomized Similarity at baseline | Analysis | Results P values NS=p>0.05, *p< 0.05, **p<0.01 | Comments
KQ1 trial
Williams et al 1999^10^ Fair | RCT Consecutive patients in study clinics recruited on designated days Patients randomized before screen to longer screen, brief screen, or no screen. Diagnostic phone interview after visit. Several different outpatient medical clinics | I1: Completed CES-D before scheduled appointment and results placed in chart on bright orange form(for everyone--not only positive screens) I2: Same as above but used 1-item depression screen C: Usual care (no screen) All providers received guide for managing depression in primary care and continuing education session on interpreting case-finding questionnaire and diagnosing depression All patients had post-visit diagnostic interview via phone | MDD, Dysthymia, Minor Depression % Currently treated: NR | San Antonio, TX and Washington, D.C. General outpatient primary care | 1,083 approached 1037 eligible 969 consented 969 screened 969 randomized I1= 323 I2= 330 C= 316 863 complete baseline data I1= 296 I2= 291 C= 276 | Mean Age: I= 59 I= 58 C= 56 Female: I1= 74% I2= 68% C: 71% Hispanic: I= 61% I2= 59% C= 58% Black: I1= 9% I2= 12% C= 10% Yrs educations: I1= 10 I2= 11 C= 11 % income <$7,200: I1=42%; I2=40%; C=36% % income ≥ $16,800 I1=24%; I2=25%; C=24% % any depression diagnosis: I1=12.4%; I2=13.8%; C=13.8% | Inclusion: scheduled appt at one of study clinics Exclusion: No telephone; no stable address | I1: CES-D; I2: “Have you felt depressed of sad much of the time in the past year?” Paper-and-pencil, in medical clinic before appointment Who administered/scored: NR Results placed in chart on bright orange sheet of paper Patient contacted by phone by the researcher after visit to complete diagnostic interview for DSM-IIIR diagnosis | 3-month, San Antonio clinics only. Only followed up patients with diagnosis confirmed by post-visit phone interview + random sample of non-depressed per phone interview | Depression: % depressed; % ≤1 DSM-IIIR depression symptoms Other: None AE: NR | Only those in follow-up group (see follow-up time frame) NR NR | Combined I1 & I2; Compared I vs. C on % depressed, % ≤1 DSM-R, # depressive symptoms. Specific test NR. | % Depressed @ 3-mo (of all followed-up): I=37% (56/153) C=46% (30/65) p=0.19 % Recovered (of those with depression diagnosis per post-visit phone interview)*: I=48% (32/67) C=27% (8/30) p<0.05 Mean symptom count reduction: I=1.6, C=1.5 p=0.21 Results similar when only analyzed those who had followup (not sure how missings handled above) | San Antonio clinics only. Only followed up patients with diagnosis confirmed by post-visit phone interview + random sample of non-depressed per phone interview
KQ1a trials
Bosmans et al 2006^115^ Fair | RCT, cluster randomized at clinic level Randomized before screen, enrolled if positive screen + diagnosis confirmed by PRIME-MD General practice | I: Screening; further evaluation by provider to determine if meet MDD criteria using PRIME-MD; providers attend 4-hr training session on screening, diagnosis, and treatment of late-life depression. Two treatment phases: every 2 wks for 2 months; monthly for 4 months. C: Screening, further evaluation by study staff to determine if meet MDD criteria using PRIME-MD. Practitioner remained blinded to results; no training. | MDD 0% currently using antidepressants | Amsterdam, The Netherlands Older (age 55+) general practice patients | 3,937 screened 579 pos screen 339 agree to diagnostic interview 178 MDD diagnosis 145 consent to rest of study I=70; C=75 I=18 clinics; C=16 clinics | Mean Age: I=66.4; C= 64.7 Female: I=66%; C=54% Race: NR SES: NR 100% not on antidepressants History of depression: I=85%; C=82% | Inclusion: age 55+; visit with general practitioner; GDS-15 score ≥5; PRIME-MD diagnosis of MDD; Exclusion: current use of antidepressants; current psychosis, bipolar, or drug abuse diagnosis; severe social dysfunction; inability to communicate in Dutch; impaired cognitive functioning | GDS, PRIME-MD GDS mode NR, PRIME-MD interview I: GP assistant admin and score GDS, GP admin/score PRIME-MD C: research assistant admin and score both GDS and PRIME-MD. Result given to GP, GP administer PRIME-MD if screened positive. Validation through GP or research assistant administration of PRIME-MD | 12-months | Depression: MDD diagnosis from PRIME-MD; depression severity from MADRS Other: Quality Adjusted Life Years from EuroQol (EQ-5D) AE: NR | Completing follow-up assessment (86% of enrolled) NR Enrolled group similar on age, sex, marital status, previous history of depression, and baseline depression severity | t-test for depression severity and QALYs, Chi-sq for percent recovered Intention to treat on all who completed all followup. | % recovered: I=43%; C=48%, p=0.60 Mean change in MADRS from baseline: I=−7.8; C=−7.2, p=0.70 Mean QALYs gained: I=0.65; C=0.70, p=0.20 Analysis on I=58; C=67
Bergus et al 2005^113^ Fair | RCT; randomized at patient levelRandomized using random number table after positive screen, all randomized screenedTwo private rural family practice clinics with 10 physicians | I: Provider asked to review PHQ-9 results, educated about PHQ-9C: Providers educated about PHQ-9, did not receive screen results | Accepted all positive screens, used screen cut-offs to categorize as Major and Minor depression for sub-analyses 38% on medications for depression or anxiety | Iowa; ruralGeneral outpatient family practice | 951 approached861 completed screen119 positive screen59 enrolledI=27; C=33 | Mean age: I=38.2; C=43.4 Female: I=62%;C=70% Caucasian: I=92%; C=96% Some college: I=58%, C=44% History of depression treatment: 60% Currently treated for depression: 38% PHQ: I=12.0; C=12.7 All baseline differences-NS | Inclusion: English-speaking; adult; patient at study clinicExclusion: dementia | PHQ-9Mode: NRAdmin/score: NR 1Provider asked to review completed PHQ-9Validation: provider review | 4-, 10-, 24-week | Depression: Change in PHQ-9 score; remission per PHQ-9Other: noneAE: NR | Completed ≥1 followup (inferred). Those unable to be contacted were dropped from the studyNRyes | t-tests; repeated measures ANOVA for continuous measuresChi-sq for % remissionPHQ9 scores carried forward for missing data | 10 week followupAll subjects: Change in PHQ: I= −5.8; C= −5.8 (p=0.45)% Remission: I=54%; C=37% (p=0.35) Patient with Major Depression: Change in PHQ: I= −7.3; C= −9.1 (NS)% Remission: I= 36%; C= 38% (NS) 24 week followup All subjects: Change in PHQ: I= −5.7; C= −5.0 (p=0.45)% Remission: I=52%; C=38% (p=0.35) Patient with Major Depression: Change in PHQ: I= −8.5; C= −8.2 (NS)% Remission: I= 54%; C= 31% (NS) | Small N, probable contamination, blinding NR
Jarjoura 2004^114^ Fair | RCT; randomized at patient level Randomized by permuted blocks of 40 using sealed envelopes after positive screen; all randomized screened Indigent primary care clinic | I: Screening nurse gave results + treatment protocol to provider. Protocol includes: explore symptoms to confirm diagnosis; rule out other explanations for positive screen; educate patient & give materials; offer appointment for behavioral counseling; prescribe antidepressant if acceptable to patient; schedule return visit in 4 weeks C: provider not informed of results; patient told may have problem with depression and that there are effective treatments | Not specified-just positive screen 0% currently being treated for depression | Ohio Internal medicine residency clinic | 1,095 screened 497 positive screen 101 not currently treated for depression 61 randomized* I=33; C=28 *24 of those not randomized were ineligible due to suicidal ideation | Mean Age: I=45; C=46 Female: I=76%; C=61% Race: NR SES: NR, but all were required to be below federal poverty level. 100% not current treatment for depression BDI: 28 (I) 23 (C) All characteristics-NS | Inclusion: age 18+; Medicaid or low-income & no private insurance; positive screen for major depression episode; not receiving treatment for depression; not seeking help for depression or other emotional problems; could read and respond to questionnaire Exclusion: suicidal ideation | PRIME-MD Presume mode paper-and-pencil, based on reading requirement Nurse administered/score Nurse gave results to clinician Provider asked to validate screen results | 6-, 12-month | Depression: BDI, PRIME-MD (1-yr only) Other: utilization of medical & behavioral services, costs of care, SF-36 AE: NR | Complete ≥1 followup (inferred) NR NR | Repeated measures mixed model. Adjusted for baseline | % showing ≥33% decline in BDI (averaging 6- and 12- mo data): 39% (I), 21% (C) (p NR) 6-mo: I-group BDI change 7.6 pts > C-group change (p NR) 12-mo: I-group BDI change 6.5 pts > C-group change (p=0.03) SF-36 QOL “Intervention effect”=3.6 (p=0.27) Health Care costs NS (p-value range 0.26–0.93) | Small N, probable contamination, control group told test results, possibly capitalizing on regression to mean since I-group 6 patients higher on BDI at baseline (though NS) Only newly-detected depression
Rost et al 2001^109^ Rost et al 2000^190^ Rost et al, 2006^119^ Rost et al, 2005^174^ Good | RCT, cluster randomized Randomized 12 matched primary care practices, 6 to each condition one control-group practice did not meet recruitment goals and so was replaced with another practice, participant enrolled after 2-step screen process, if patient positive on both screens | I: 2 physicians, 2 nurses, 1 administrative person trained; administrative staff recruited participant before index visit with physician; if physician confirm diagnosis, patient scheduled return visit in 1 week; re-assessed immediately before 1- week visit, patient educated about preferred treatment; ask patient to complete homework assignments; arranged further follow-up; up to 9 weekly visits with same pattern C: Administrative staff administered screening, but physicians were not informed which patients were participating and nurses did not meet with depressed patients. | Major Depression I: 48%; C: 40% recently (past 6 months) treated for depression | CO, MI, MN, NJ, NC, ND, OK, OR, VA, WI, urban and rural | 11,006 approached 9,555 completed 1st step screen 2,082 positive 1st step screen 653 positive 2nd step screen 479 patients enrolled I=239; C=240 Patients with 6-mo followup: Previously-known cases N=243, Newly-identified cases N=189 | Mean age: I=41.4; C=43.9 Female: I=84%; C=84% Caucasian: I=84%; C=84% High school: I=79%; C= 79% PHQ: I=12.0; C=12.7 all baseline differences NS | Inclusion: routine- length appt with participating provider; age 18+; sufficient English literacy/cog. function to complete questionnaire; no acute life-threatening physical condition; access to telephone; positive score on both screening instruments; Exclusion: pregnant, breastfeeding, or< 3 mos post-partum; bereavement; did not intend to receive on-going care in target clinic during next 12 months; lifetime history of mania; use of lithium; current alcohol dependence | (1) 2 WHO-CIDI items (2) 9-item Inventory to Diagnose Depression Mode: NR Office staff hand-scored Note placed in front of chart informing provider that the patient had screened positive for MDD and agreed to be in the study Provider asked to evaluate depression diagnosis and begin study protocol of agreed with diagnosis | 6-month on everyone; 12-month, 18-month, 24-month only on those with newly-identified depression episode | Depression: CES-D collected via phone interview Other: SF-36 AE: None | Completed the follow-up interview. Report separately those who had been treated for depression in past 6 months and those who had not. NR NR | Intention-to-treat hierarchical models stratified by whether patient had recently been treated for depression, controlling for all baseline differences that were p<0.20 | Decrease in CES-D baseline to 6-mo: Recently treated: I=14.5; C= 11.0 Newly identified depression: I=21.7; C=13.5* % Remission at 24 mos (CES-D≥15) in newly identified depression only: I=74%; C=41% | No overall results reported, only by subgroups of whether they had been in treatment for depression at baseline or not. Overall differences WERE significant, per personal communication (Rost, 2006)
Whooley et al 2000^111^ Fair | RCT, randomized at clinic level Randomized before screen, all randomized screened Primary care | I: provider notified of screening results + handout with score interpretation and general recommendations; group psycho-education classes offered to patients and family; 1-hour provider training on depression management C: screening & no feedback, 1-hour provider training on depression management | Not specified-just positive screen % on antidepressants in past 12 month: I=23%, C=17% | Oakland, CA Geriatric (65+) outpatient primary care | # approached NR 2,896 eligible for Screening 2,346 screened 2,346 randomized 331 positive screen I=162 C=169 | Mean age: I=75.7; C=75.9 Female: I=59%; C=62% African American: I=28%; C=37% Caucasian: I=49%; C=39% Completed High School: I=87%; C=76% (p=0.04) | Inclusion: age 65+, had medical appointment at one of study clinics Exclusion: NR | GDS Mode: NR Administered/scored: research assistant Results + explanatory hand-out put in chart Validation at discretion of provider | 2-year | Depression: GDS; % depressed Other: # visits; hospitalization AE: NR | Baseline GDS≥6: N=331 (I=162; C=169) 2-year GDS only avail for I=97, C=109 Those completing 2 yr followup were more likely to be divorced/separated and had fewer clinic visits in previous 12 mo. Similar on all variables reported except % completed high school (p=0.04, fewer in C group) and income category (p=0.002, C group lower income, fewer unknown income) | Mean change based on stepwise regression-include all baseline demographic/social/heal th variables, Keeping variables with p≤0.05 in model; Chi-sq of % improved; logistic of # improved, controlling for baseline differences; Compare differences in mean # clinic visits and hospitalizations | GDS: both groups significant change over time; no group differences % depressed: no group differences I=42% (41/97); C=50% (54/109) Adjusted mean decrease in GDS score from baseline: I=1.8; C=2.2 (p=0.41) Health care utilization: no group differences # clinic visits: I=1.8; C=1.6 # hospitalizations: I=1.1; C=1.0 | Only analyzed those who screened positive at baseline 12% attended group session.
Wells et al 2000^110^ Wells et al 2004^118^ Sherbourne et al 2001^189^ Rubenstein et al, 1999^240^ Good | RCT, cluster randomized Randomized managed care organization regions; regions in matched clusters of 3, each cluster had a region assigned to one of 3 conditions; individual provider consented to participate or not. Consecutive patients in study clinics screened, only positive screen enrolled Primary care | I1: (QI-Meds) Screening; institutional monetary commitment; staff and clinician training (1- or 2-day workshops); clinician manuals; monthly training lectures; academic detailing as needed; numerous materials for clinicians, staff, patients; trained nurse specialists for followup assessment and on-going adherence support (medication adherence, presumably) I2: (QI-Therapy) Screening; same QI elements as above except trained therapists to provide individual or group manualized CBT and reduced co-pay for therapy rather than nurse med specialists C: Screening; participant told they could inform their providers of screen results; medical directors mailed the AHRQ depression practice guidelines + quick reference guides for clinicians | MDD and Dysthymia-specific screener used % Currently treated: NR | 7 geographic regions-sites chosen to oversample Mexican Americans Outpatient primary care | 44,052 approached 37,452 consent to screening 27,332 screened* 3,918 positive screen 2,176 eligible for enrollment 1,356 patients enrolled (46 clinics randomized) I=913 (30 clinics); C=443 (16 clinics) *most of those not screened were ineligible because they were not patients of study providers | Mean age: I=44.5; C=42.2 Female: I=71.6%; C=69.0% Hispanic: I=29.1%; C=30.6% Caucasian: I=57.9%; C= 55.3% Completed college: I=22.2%; C=15.0% (p=0.001) % depressed per baseline CES-D: I=75.4; C= 75.7% | Inclusion: positive screen; intended to use clinic as source of care for next 12 months Exclusion: <18; acute medical emergency; did not speak English or Spanish; no insurance or public-pay arrangement that covered mental health care | CIDI-MDD and dysthymia sections (based on DSM) Mode: NR Administered/scored: study staff Intervention clinics provided lists of study participants. Control clinics not notified. | 6-month, 12-month, 18-month, 24-month, 57-month 6–24-month follow-up from mailed questionnaire with phone follow-up, 57-month followup by phone | Depression: CES-D; % probably MDD or dsythymia diagnosis per CIDI Other: SF-12 Mental health and physical summary scales AE: NR | Those completing follow-up qx 6-mo N=1,156 (85%), 12-mo N=1,126 (83%) 24-mo N=NR 57-mo N=924 (73%) NR I slightly older and more likely to be married than C | Patient-level intention-to-treat, using multiple imputation for missing data at item-level. Intraclass orrelations were lose to zero so analyses were not adjusted for cluster effects. Multivariate egression models | % depression per CES-D cut-off Baseline: I=75.4; C= 75.7 6-month: I=55.4; C=64.4** 12-month: I=54.5; C=61.4* Still positive on CIDI: 6-month: I=39.9%; C=49.9** 12-month: I=41.6%; C=51.2** 24-month: I=est 35%; C=34% 57-month: I=37.0%; C=43.6%* Mean mental health summary score: Baseline: I=35.6; C=36.1 6-month: I=41.6; C=39.8** 12-month: I=40.9; C=39.3* 57-month: I=44.8; C=42.6 Mean physical summary score Baseline: I=45.2; C=44.6 6-month: I=43.9; C=43.7 12-month: I=44.1; C=44.6 Depression diagnosis per CIDI interview (24-month) I1=39%; I2=31%; C=34% | Fairly extensive baseline data collection procedures for all participants, plus mailed followup questionnaire every 6 months
Callahan et al 1994^112^ Fair | RCT Clinical practice sessions randomized, patients scheduled during selected practice sessions and who screened positive in two separate interviews were enrolled. Primary care | I: 2-step screen; 3 appointments with primary provider over 3 months to address symptoms of depression; letter for provider including HAM-D results, medications associated with depression, and treatment recommendations placed in chart; educational materials for patient included in chart; post-visit questionnaire C: 2-step screen; no screening results given to provider; further appointments at discretion of provider; post-visit provider questionnaire for baseline interview visit Other: N=97 randomly selected for extensive psychiatric interview for other purposes, not included in these results All providers given talk on late-life treatment of depression; any patient positive for suicidal ideation at baseline interview referred for immediate psych evaluation | Not specified-just positive screen % on antidepressants: I=10.0%; C=13.5% (NS) | Indiana, multi-specialty ambulatory care clinic associated with urban county hospital Target age 60+ | 4,413 approached 3,767 screened during primary care visit for depression, alcohol, & dementia 612 positive CES-D 515 retained (randomly selected 97 for other purposes, not included in this study) 254 consented to 2nd interview 175 positive on HAM-D 175 enrolled I=100; C=75 | Mean age I=65.5; C=65.1 Female: I=76.0%; C=75.7% African American: I=50.0%; C=52.7% Years of education: I=8.6; C=9.1 Mean HAM-D: I=22.0; C=21.8 Mean SIP: I=33.0; C=29.9 No statistical differences | Inclusion: age 60+; regularly-scheduled primary care visit; score ≥16 on CES-D; score ≥15 on HAM-D Exclusion: prisoners; patients residing in nursing home; unable to speak English; hearing impaired | CES-D, HAM-D In-person interview; CES-D performed during regularly scheduled visit; HAM-D at special visit within 2 wks of first visit Research assistant | 1-month, 3-month, 6-month, 9-month | Depression: HAM-D, how assessed NR Other: SIP, how assessed NR AE: NR | Completers at 6 mo. NR Groups similar on sex, age, race, education, cognitive impairment, alcohol dependence, % depression diagnosis, % on medication associated with depression (e.g. narcotics), on antidepressants, mean # of diagnosis, HAM-D, SIP | Paired-comparison t-tests at 6 months | CES-D: all patients improved over 6 months**, no group differences in amount of improvement HAM-D: % Responded I=13%; C=12% (NS) SIP: All patients improved over 6 months (p-value NR), no group differences in amount of improvement
Rubenstein et al 2007^116^ Fair | Subgroup analysis of CCT Clinics assigned to treatment group, participants enrolled after screening positive for one of 5 conditions Primary Care | I: Structured phone assessment with case manager, then referrals as needed to (1) multidisciplinary geriatric assessment clinic; (2) home-based primary care program for homebound elders; (3) primary care provider; or (4) other specific services (e.g. mental health). Also health education and promotion, written summaries of recommendations, appointments, etc.. Called again after 1 month, then quarterly for 3 years. C: Usual Care | Not specified, just positive depression screen Curr tx: NR | Los Angeles, CA outpatient VA clinic Age 65+ at risk for one or more of five common geriatric conditions (falls/balance problems, urinary incontinence, depression, memory loss, and functional impairment) | 2,646 mail questionnaires 2,382 returned questionnaires 1001 met criteria as high risk 792 enrolled in study I=380 C=412 Among those with positive screen for depression: I=95 C=111 | Mean age I=74.6 C=74.3 Female: I=3.7% C=2.7% HS or beyond: I=75.3% C=76.5% No statistical differences | Inclusion: age 65+, 1+ clinic visits in past 18 mos; screen positive for one of five conditions Exclusion: live outside of 30 mile radius of clinic; already enrolled in geriatric services; living in a long-term care facility | GPSS Mail Case manager completed more extensive work-up, referred to primary provider, specialty care as needed | 1-yr, 2-yr, 3-yr (only 1-yr results reported on subgroup screening positive for depression) | Depression: GDS Other: None on subgroup screening positive for depression AE: NR | Those screening positive for depression at baseline NR NR | Repeated measures ANOVA | Mean GDS Score: Baseline: I=8.7; C=5.0 1-yr: I=8.8; C=6.1 (Time*treatment interaction p=0.05)

USPSTF=United States Preventive Services Task Force; AHRQ=Agency for Healthcare Research Quality; RCT=Randomized Control Trial; CES-D=Center for Epidemiologic Studies Depression Scale; I=Intervention; C=Control; MDD=Major Depressive Disorder; NR=Not Reported; AE=Adverse Events; PRIME-MD=Primary Care Evaluation of Mental Disorders; SES=Socio-Economic Status; GDS=Geriatric Depression Scale; GP=General Practitioner; GPSS=Geriatric Postal Screening Survey; PHQ-9=Patient Health Questionnaire; NS=Not Specified; BDI=Beck’s Depression Inventory; SF-36=Short Form; WHO-CIDI=World Health Organization Composite International Diagnostic Interview; QI=Quality Improvement; CBT=Cognitive Behavioral Therapy; HAM-D=Hamilton Rating Scale for Depression; SIP=Sickness Impact Profile; MADRS=Montgomery Asberg Depression Rating Scale

Appendix G Table 2 Evidence table for depression treatment of the elderly

Study reference | Treatments addressed | Comparison conditions allowed | Databases searched and years | Inclusion/exclusion criteria | Unpublished data? Non-English language studies? | Consort numbers | # included trials # directly relevant to current review (include control group, primary care setting, one of treatments in our scope) # participants total # participants in trials relevant to current review | Analyses used in this review | Qualitative results summary | Quantitative results summary | Quality rating
Wilson et al 2000^121^ | Antidepressants: TCAs, SSRI, MAOIs, and Atypical Antidepressants (Mirtazepine, Minaprine, Medifoxamine) | Placebo | CCDAN through 1999, includes: Medline: 1966–1999 PsycLIT: 1887–1999 EMBASE: 1982–1999 LILACS: 1982–1999 CINAHL: 1982–1999 SIGLE: through 1999 Psyndex (1977–1999) National Research Register(1999) Dissertation Abstracts International Biological Abstracts Cochrane Controlled Trials Register Cochrane Collaboration Depression Anxiety and Neurosis Controlled Trials Register Extensive hand-searching | Included: Placebo-controlled RCT; Depression by any criteria; described as elderly or all aged 55+ Excluded: Population of people with explicit diagnosis of other psychiatric disorder (dementia, alcoholism, bipolar); dose-response or testing combination; focus on maintenance treatment; literature review; trials reporting on electro convulsive therapy (ECT), prevalence studies, prescribing practice or risk factors. | Unpublished: dissertation abstracts Non-English: NR | CCDAN: 697 abstracts 108 articles reviewed 18 Included Hand-searches: 78 articles reviewed5 Included | Included trials: 23 trials total, 17(n=1524 calc) with sufficient data for meta-analysis Subset of MDD: 8 trials (n=1,120 calc) Subset of community-dwelling: 7 trials (n=1,070 calc) | Overall analysis, community- dwelling subgroup analysis Compare analysis of 4-week outcomes subgroup with overall results to see if overall results likely heavily influenced or different from longer follow-up studies. | TCAs, SSRIs, and MAOIs are effective in treatment of older community patients and inpatients. | Odds ratios for depression at outcome: TCA vs Placebo: 0.32 SSRIs vs Placebo: 0.51 MAOIs vs Placebo: 0.17 Atypicals vs Placebo: 0.52 Community-dwelling: 0.47 MDD subset: 0.44 (all p<0.05) Percent of depressed at follow-up: TCA vs. Placebo: 51% vs. 75% SSRI vs. Placebo: 72% vs. 83% MAOI vs. Placebo: 59% vs. 90% Community-dwelling: Drug 64% vs Placebo 79% MDD subset: Drug 64% vs Placebo 80% (all p<0.05) | Good
Cuijpers et al 2006^122^ | “Psychological” treatments, including CBT, psychodynamic, reminiscence, problem- solving, behavioral activation, interpersonal therapy | Untreated control group or other treatment (psychological or not) | Medline, PsycINFO, Cochrane Controlled Trials Register, Dissertation abstracts Years: 1966–2005 | Included: RCTs; subjects aged 50 years or older with cilinically relevant depressive symptoms Excluded: Studies in which the effects of the psychological treatment could not be distinguished from the total intervention | Unpublished: Yes Non-English: 0 | 2,355 abstracts reviewed 129 articles reviewed 25 trials included (in 34 articles) | Trials: 25 (n=1,937), 21 included in meta-analysis (N=NR) | Overall analysis; analysis limited to those with waiting list as control group. | Psychological interventions are effective in reducing depression in depressed elderly. | Odds ratio for remission: 2.63 (1.96, 3.47) Effect side for symptom report(average of clinican and self-report): 0.72 (0.59, 0.85 | Good
Pinquart et al, 2006^120^ | Pharmacological: TCAs, SSRI, MAOIs, other newer agents (e.g., venlafaxine, mirtazapine) Psychological: “rational”(e.g., cognitive and/or behavioral), “emotive”(e.g., supportive, dynamic, interpersonal) | Placebo, control without agent (attention active- placebo OK) | Medline, Cochrane Database, PsycINFO, PSYNDEX Years: through 2004 (personal communication) | Included: mean or median age≥60; MDD, dysthymia, minor depression; intervention group compared with control group; depression or psychological well- being outcomes; sufficient data to calculate effect size Excluded: studies of maintenance treatment, combination treatment, and collaborative care treatment | Unpublished: Yes Non-English: 8 | 120 potentially eligible trials Exclusions: non-depressed pts (15) duplicate datasets (6) age cut-off (3) maintenance treatment (3) inadequate control group (1) didn’t separate pharmacotherapy and psychotherapy results (2) only reported responders (1) | Trials: Total 89 trials (62 antidepressants, 32 psychotherapy (5 both)) Relevant trials: could not ascertain directly relevant Subset focus on MDD: 31 trials Participants: 5,328 participants Relevant participants: could not ascertain directly relevant MDD subset: NR | Overall MDD-only subgroup | Pharmacotherapy and psychotherapy are effective in reducing depression in depressed elderly; psychotherapy may be more effective in treating dysthymia and minor depression than pharmacotherapy, but they appear equally effective for MDD. | Pharmacotherapy: Self-reported depression d (effect size) = −0.62 p<0.001 Q (homogeneity) = 65.9 Clinician-rated depression d (effect size) = −0.69 p<0.001 Q (homogeneity) = 292.4 Psychotherapy: Self-reported depression d (effect size) = −0.83 p<0.001 Q (homogeneity) = 99.5 Clinician-rated depression d (effect size) = −1.09 p<0.001 Q (homogeneity) = 52.5 | Good

TCA-tricyclic antidepressant; SSRI-selective serotonin reuptake inhibitor; MAOI-monoamine oxidase inhibitor; RCT-randomized controlled trial; NR-not reported; CBT-cognitive behavioral therapy; calc-calculated; MDD-major depressive disorder.

Appendix G Table 3 Suicide Related Events in MDD and Other Psychiatric Indications124,125

Indication | | Event | Test Drug | Placebo
Major Depressive Disorder | Behaviors | Completed suicide Suicide attempt and preparatory acts Suicidal ideation | 4/22379 0.02% 48/22379 0.21% 111/22379 0.50% | 1/14873 0.01% 31/14873 0.21% 91/14873 0.61%
Other Psychiatric Disorders | Behaviors | Completed suicide Suicide attempt and preparatory acts Suicidal ideation | 1/15061 0.01% 24/15061 0.16% 52/15061 0.35% | 1/10573 0.01% 13/10573 0.12% 51/10573 0.48%
Combined All Psychiatric Indications (major depressive disorder, other depression disorders, other psychiatric disorders) | Behaviors | Completed suicide Suicide attempt and preparatory acts Suicidal ideation | 5/39799 0.01% 74/39799 0.19% 169/39799 0.42% | 2/27309 0.01% 47/27309 0.17% 148/27309 0.54%

Appendix G Table 4 Evidence table of systematic evidence reviews and meta-analyses of suicide risk related to SSRIs.

| Data Included | Drugs | Trial and participants | Duration | Outcomes | Outcome category definitions | Quality concerns/Comments
FDA 2006 Safety group meta-analysis124 Statistical group meta-analysis125 Center for Drug Evaluation and Research Regulatory review Not quality rated Funding: FDA | Data provided to FDA through data requests to drug sponsors. Obtained data 9/2005 through 9/2006 | Test drug vs. placebo SSRI: Citalopram Escitalopram Fluoxetine Fluvoxamine Paroxetine Sertraline Other: Duloxetine Venlafaxine Bupropion Mirtazapine Nefazodone 63% of patients were enrolled in trials of SSRIs SSRI 30,301 Active control 6,066 Placebo 26,042 | 372 RCTs (162 for MDD) Total Patients: 99,839 Test drug: 52,960 Placebo: 35,904 Active control: 10,975 Test drug w/MDD: 22,379 Placebo w/MDD: 14,873 Psychiatric indications [underlined: Mean Age (SD)] Drug: 41.8 (14.28) Placebo: 42.0 (14.48) 18–24 yrs: 9.6% ≥ 65 yrs: 8.8% [underlined: Female] Drug: 61.2% Placebo: 60.8% [underlined: Race] White Drug: 85.8% Placebo: 85.9% African-American Drug: 5.4% Placebo: 5.4% Asian Drug: 3.2% Placebo: 3.6% Hispanic Drug: 3.6% Placebo: 3.6% | 0–84 weeks MDD 0–16 weeks Mean: MDD 7.5 wks Other depression 26.5 wks | Results preferentially chosen from the statistical group report. [underlined: Suicide (Psychiatric indications)] Drug: 5/39,799 persons (1.3/10,000) Placebo: 2/27309 persons (0.73/10,000) OR (calculated): 1.72 (0.28, 18.01) [underlined: Suicides in] MDD Drug: 4/22,379 persons (1.79/10,000) Placebo: 1/14,873 persons (0.67/10,000) OR (calculated): 2.66 (0.26, 130.94) Risk difference (calculated): 1.12 (−1.1, 3.3) [underlined: Suicidal behavior (Psychiatric indications)*] Drug: 79/39,729 persons (19.9/10,000) Placebo: 49/27,164 persons (18.0/10,000) OR 1.11 (0.77, 1.61) [underlined: Suicidal behavior + Ideation(Psychiatric indications)*] Drug: 248/39,729 persons (62.4/10,000) Placebo: 196/27,164 persons (72.2/10,000) OR (95% CI) 0.84 (0.69, 1.02) [underlined: Suicidal behavior + Ideation (in] MDD[underlined: )*] Drug: 163/22,309 persons (73.1/10,000) Placebo: 123/14,728 persons (83.5/10,000) OR (95% CI) 0.86 (0.67, 1.10) *Numbers reported in figures are discrepant from tabular data. | Suicides: completed suicides Suicidal behaviors: suicides, attempts, acts toward imminent behavior Suicidality: suicidal behaviors, suicidal ideations | Meta-analyses are based on individual and trial level data. Suicide rates are strikingly lower than in all other reviews. Possible explanations relate to the way events were detected and categorized: 1) All potentially suicide related adverse events had to occur within the double-blind phase of the trials and were excluded if they occurred more than one day after discontinuation of drug or prior to randomization. Excluding events prior to randomization is desirable, particularly if events occurring during a placebo run-in are categorized as occurring during placebo treatment. However, given the high early discontinuation rates with these drugs, excluding events after discontinuation would involve undercounting which may have been differential since overall discontinuation rates are similar for drug and placebo, but reasons for discontinuation differ. 2) Manufacturers analyzed their own data to a pre-specified protocol and classified possibly-related suicidal events, without FDA independently checking the case-reports related to this classification. FDA report does not provide information on the number of events in the other 5categories used (i.e., fatal events with insufficient information; self-injurious behavior with unknown intent; self-injurious behavior, non-suicidal intent; non-fatal events with insufficient information; other: accidents, psychiatric or medical adverse events).
| | | | | BY AGE GROUP Young Adults 18–24 yrs [underlined: Suicidal behavior (All psychiatric disorders)] Drug: 23/3810 persons (60.4/10,000) Placebo: 8/2604 persons (30.7/10,000) OR (95%CI) 2.31 (1.02, 5.64) [underlined: Suicidal behavior + Ideation (All psychiatric disorders)] Drug: 47/3810 persons (123.4/10,000) Placebo: 21/2604 persons (80.6/10,000) OR (95%CI) 1.55 (0.91, 2.70) Adults 25–64 yrs [underlined: Suicidal behaviors (All psychiatric disorders)] OR 1.03 (0.68, 1.58) † [underlined: Suicidal behavior + Ideation (All psychiatric disorders)] OR 0.79 (0.64, 0.98) † Older Adults ≥ 65 yrs [underlined: Suicidal behavior (All psychiatric disorders)] OR 0.06 (0.01, 0.58) † [underlined: Suicidal behavior + Ideation (All psychiatric disorders)] Drug: 12/3227 persons (37.1/10,000) Placebo: 24/2397 persons (100.1/10,000) OR (95%CI) 0.39 (0.18, 0.78) †As reported in Stone 2006
Hammad 2006^137^ Center for Drug Evaluation and Research, FDA Review of regulatory data Not quality rated Funding: FDA | Data provided to the FDA from manufacturers. Includes parallel group RCTs from drug development programs that were performed through 2000. Patients had MDD and other anxiety disorders. | Drug vs. placebo SSRI: Citalopram Fluoxetine Fluvoxamine Paroxetine Sertraline Other-2nd generation: Bupropion Mirtazapine Nefazodone Venlafaxine TCAs: desipramine, amitriptyline, imipramine | 251 trials (207 for MDD) Total patients: 51,000 MDD trial: n =40,028 SSRIs:14,675 Other-2nd generation: 10,929 Placebo: 8,868 TCAs: 5,556 Anxiety trials n=10,972 (44 trials) Mean age: 36.6–38.7 yrs Female: 51–58% In/Outpatient settings: NR | 6–17 weeks | [underlined: Suicide-in MDD] SSRI: 6/14,675 persons (4.1/10,000) Other-2^nd^ generation: 9/10,929 persons (8.2/10,000) SSRI/Other-2nd generation: 15/25604 persons (5.9/10,000) TCAs: 4/5,286 persons (7.6/10,000) Placebo: 2/8,868 persons (2.3/10,000) OR SSRI vs. Placebo (calc): 1.81 (0.32, 18.37) OR SSRI/Other 2^nd^ generation vs. Placebo: (calc): 2.60 (0.60, 23.42) Risk difference SSRI vs Placebo (calculated): 1.8 (−2.7, 6.3) [underlined: Suicides-in MDD] SSRI/Other-2nd generation: 15/3707 person-yrs (calc) (48/10,000) Placebo: 2/1071 person-yrs (19/10,000) [underlined: Suicides-in Anxiety trials] SSRI: 1/1273 (7.9/10,000) Other-2^nd^ generation: 0/1273 (0/10,000) TCAs: 0/319 (0/10,000) Anxiolytics: 0/174 (0/10,000) Placebo: 1/4327 (2.3/10,000) OR SSRI vs Placebo (calculated): 3.40 (0.04, 267.02) | | Events attributed to randomized therapy if occurred during therapy or within one day of discontinuation- would not count suicides in anyone who was discontinued early due to adverse events or other issues. Excluded suicides prior to randomization. [underlined: 113 placebo-controlled trials (n=28,145)] 5 suicides/3335 person-years (15.0/10,000) [underlined: 94 active-only controlled trials (n=11,883)] 16 suicides/1443 person-years (110.9/10,000)
Gunnell 2005^138^ BMJ From MHRA report done for CSM Expert working group Update in BMJ June 2006^139^ Additional table provided by authors Report of the CSM expert working group December 2004^105^ Regulatory review Review of regulatory data Not Quality Rated Funding: None | Published and unpublished data provided to MHRA through 2003. Additional paroxetine data was provided in December 2004 | SSRIs vs placebo Citalopram (9 trials) Escitalopram (34 trials) Fluoxetine(135 trials) Fluvoxamine(48 trials) Paroxetine (57 trials) Sertraline (156 trials) | 477 RCTs Adults with all indications (MDD, plus others) Suicide data: 342 trials with 40,826 patients. Excluded fluoxetine. Non-fatal harms*: 52,503 patients 439 trials Suicidal ideation*: 45,704 patients 439 trials In-/Outpatient settings: NR Exclusion of suicidal patients: NR Patient characteristics NR *Updated numbers with those presented in BMJ update in 2006. | Follow-up duration not available for all trials. Mean: 8–10 weeks | [underlined: Suicide-excludes fluoxetine] SSRI: 9/23,804 persons (3.8/10,000) Placebo: 7/17,022 persons (4.1/10,000) OR (95% CI) 0.85 (0.20, 3.40) [underlined: Non-fatal harms*] (includes suicides for fluoxetine) SSRI: 128/30,814 persons (41.5/10,000) Placebo: 75/21,689 persons (34.6/10,000) OR (95% CI) 1.21 (0.87, 1.83) [underlined: Suicidal ideation*] SSRI: 97/26,882 persons (36.1/10,000) Placebo: 80/18,822 persons (42.5/10,000) OR (95% CI) 0.80 (0.49, 1.30) *Updated numbers with those presented in BMJ update in2006. Paroxetine trials in original report, n=95; in update, n=57. | Suicide: Any fatal self harm, including intentional overdose and other overdose (except accidental overdose) Self harm: any non-fatal self harm Suicidal thoughts: any reports of suicidal thoughts or ideas. | Did not look at individual patient data. Includes patients treated for conditions other than depression No descriptive characteristics of patients in included trials or of trial inclusion/exclusion criteria. Companies analyzed own data to a pre-specified protocol but also provide case reports to the MHRA for all reports of suicidal behavior. MHRA checked these for consistency and completeness, with further follow-up with the manufacturer as needed. In young adults with four disorders other than MDD, there were proportionally slightly more events of both outcomes.
Data from GSK Briefing document4/5/2006^131^ Not quality rated Drug company review of internal data | December1982 through May 2005 | Paroxetine only | Indications separated 57 RCTs-all indications 19 MDD trials In MDD trials N: Paroxetine: 3455 Placebo: 1978 Mean age: Paroxetine: 46 yrs Placebo: 46.5 yrs [underlined: %] Female: Paroxetine:59% Placebo: 60% | | [underlined: Definitive suicide behavior-]in MDD [underlined: (paroxetine only)] SSRI: 11/3455 persons (31.8/10,000) Placebo: 1/1978 persons (5.1/10,000) OR (95% CI) 6.7 (1.10, 149.40) Risk difference (calculated) 26.8 (5.5, 48.0) Number need to treat-to-harm 373 (208, 1818) [underlined: Definitive suicidal behavior or ideation-]in MDD[underlined: -paroxetine only] SSRI: 31/3455 persons (89.7/10,000) Placebo: 11/1978 persons (55.6/10,000) OR (95% CI) 1.3 (0.70, 2.80) Risk difference (calculated) 34.1 (−11.3, 79.5) Young adults 18–24 yrs [underlined: Suicidal behavior with or without ideation-]in MDD Paroxetine: 5/230 persons (217/10,000) Placebo: 0/104 persons (0/10.000) [underlined: Definitive suicidal behavior-]in MDD Paroxetine: 3/230 persons (130.4/10,000) Placebo: 0/104 persons (0/10.000) [underlined: Definitive suicidal behavior-all indications] Paroxetine: 16/786 persons (203.5/10,000) Placebo: 5/548 persons (91.2/10.000) OR (calculated): 2.26 (0.78, 7.92) Young adults ≤ 30 yrs [underlined: Definitive suicidal behavior] –in MDD Paroxetine: 8/612 persons (130.7/10,000) Placebo: 0/339 persons (0/10.000) [underlined: Definitive suicidal behavior -all indications] Paroxetine: 30/2037 persons (147.3/10,000) Placebo: 12/1422 persons (84.4/10.000) OR (calculated): 1.76 (0.87, 3.78) | Definitive suicidal behavior: completed suicide; suicide attempt and preparatory acts Events classified independently by Columbia University experts | Noted that increase in suicidality was driven by younger patients. When stratified by ages, no increased suicidal behavior was seen in 25–64 and ≥ 65 yrs. Eight of 11 events of suicidal behavior in MDD patients occurred in patients aged 18–30 years. All definitive suicidal behavior events in the paroxetine only dataset were attempts. In psychiatric disorders other than MDD, there was no evidence of increased risk of suicidal behavior or ideation or of suicidal behavior alone in patients with all other indications or in subgroups of those with “all other depression” or “all other non- depression.” Used exact method for OR and CI(not Mantel-Haenszel with continuity corrected as earlier analyses). Mantel-Haenszel method substantially underestimated risk due to small and disproportionate events and imbalanced randomization in some trials. 10 of 11 patients with suicidal behavior had experienced improvement and 9 of 11 experienced a social stressor at time of attempt.
Fergusson 2005^130^ BMJ Systematic review Fair quality Funding: Canadian Institutes of Health Research | Published only Searched: Medline 1967- June 2003; Cochrane Collaboration register of controlled trials November 2004; Pearled reference lists from 3 systematic reviews (2 Cochrane 2000; 1 UK evidence based guideline 1998) | SSRIs vs placebo or an active non-SSRI control including tricyclic antidepressant s. Search terms included: SSRI; Serotonin uptake inhibitors; Citalopram; Fluoxetine; Fluvoxamine; Paroxetine; Sertraline. | 702 RCTs reviewed 411 SSRI vs. Placebo 189 trials reporting fatal and non-fatal harms 10,557 SSRI patients 7856 Placebo All indications 59% of trials in patients with diagnosis other than MDD. 91% of trials include > 50% female. 91% of trials included patients with mean age < 60 yrs. | 93% ≤6 months Mean: 10.8 wks | SSRIs vs Placebo 7 suicides; 29 non-fatal attempts [underlined: Suicides (fatal attempts)] SSRI: 4/10,557 persons (3.8/10,000) Placebo: 3/7856 persons (4.0/10,000) OR (95% CI) 0.95 (0.24, 3.78) [underlined: Non-fatal attempts] SSRI: 23/10,557 persons (21.8/10,000) Placebo: 6/7856 persons (7.6/10,000) OR (95% CI) 2.70 (1.22, 6.97) [underlined: Suicides and non-fatal attempts] SSRI: 27/10,557 persons (25.6/10,000) Placebo: 9/7856 persons (11.5/10,000) OR (95% CI) 2.28 (1.14, 4.55) | Suicide attempts (primary): fatal and non-fatal acts of suicide Fatal suicide attempts: self inflicted acts resulting in death indicated by primary study. Non-fatal suicide attempts: overdose or suicide indicated by primary study. | Can’t separate out fatalities for those with MDD only. 7% of trials > 6 months. Adverse events may be limited by drop-outs from trials (46% of trials had drop-out rates > 25%). Adverse events available in 189/411 trials of SSRI vs placebo and thus NOT for most patients.
Khan 2003^126^ Am J Psych Review of regulatory data Not quality rated Funding: NR | Summary basis of approval reports obtained from the FDA for investigational SSRIs approved for use in the U.S. between January 1985 and January 2000. | SSRI (investigational at the time, subsequently FDA approved) vs other or placebo SSRI: Citalopram Fluvoxamine Fluoxetine Paroxetine Sertraline Active control: Nefazodone Mirtazapine Bupropion Maprotiline Trazolone Mianserin Dothiepin Imipramine Amitriptyline Venlafaxine | Unspecified number of RCTs conducted in order to get approval for an investigational drug. Total: 48,277 SSRI patients: 26,109 Placebo patients: 4895 Active controls: 17,273 Indications not stated. Patient characteristics: NR | Not reported | [underlined: Annual suicide rate (all patients)] 0.66% (6.6/1000) [underlined: Suicides] SSRI: 38/26,109 persons (14.6/10,000) % (95% CI) 0.15 (0.10, 0.20) Placebo: 5/4895 persons (10.2/10,000) % (95% CI) 0.10 (0.01, 0.19) Active control: 34/17,273 persons (19.7/10,000) % (95% CI) 0.20 (0.09, 0.27) OR SSRI vs Placebo (calculated): 1.43 (0.56, 4.64) OR SSRI vs Active Control (calculated): 0.74 (0.45, 1.21) [underlined: Suicides by exposure years] SSRI: 17/2864 person-yr (59.4/10,000) % (95% CI) 0.59 (0.31, 0.87) Placebo: 4/897 person-yr (44.6/10,000) % (95% CI) 0.45 (0.01, 0.89) Active control: 31/4094 person-yrs (75.7/10,000) % (95% CI) 0.76 (0.49, 1.03) | | Quality concern: Suicides assigned to the drug the person was on at time of event-even if trial was primarily of another medication. Not clear how classified event if discontinued medication. Information on trial setting or exclusion of high-risk subjects not given except that included patients lacked psychotic features and never had a hypomanic or manic episode. Other trial and participant information not given. Not clear if adults only. Active control combines second-generation investigational drugs with older, first-generation antidepressants. Likely included open-label and other longer time period studies (unlike 2006 FDA analyses). Counted placebo-run in phase as placebo treatment, therefore events prior to randomization are counted. Comments: Couldn't comparably ascertain suicide attempts. Rates based on exposure years not available for fluoxetine. Much higher rates than other studies-particularly for all indications-may be due to large number of active controls compared with placebos-indicates more severe patients.
Storosum 2001^140^ Am J Psych Review of regulatory data Not quality rated Funding: NR | Published and unpublished studies of SSRIs submitted to The Medicines Evaluation Board of the Netherlands for approval for use from 1983–1997. Also searched MEDLINE from 1990–1999 to locate additional long-term studies. | Double-blind, placebo-controlled trials. Drugs being evaluated were not specified. | 77 short-term studies, 8 long-term studies, and 14 long-term studies from MEDLINE for the indication of MDD. Studies of elderly patients and those with chronic depression excluded. Suicidal patients excluded in 64 trials; not reported in 10 studies. Short-term: 12,246 patients Long-term: 1946 Long-term MEDLINE: NR Shorter-term: 50 trials in outpatients; 10 in inpatients; 7 in and outpatient; 10 not reported. | Short-term studies: ≤8 wks (mean 5.8) Long-term studies: >8 wks (mean 38.3, placebo-controlled phase varied from 24–52 wks); were withdrawal or extension studies for sustained responders Long-term studies-MEDLINE: > 8 wks (placebo-controlled withdrawal phase ranged from 24 wks to 3 yrs); were withdrawal or extension studies for sustained responders | Short-term trials-likely MDD [underlined: Suicide completion*] Drug: 7/7944 (8.8/10,000) persons Placebo: 4/4302 (9.3/10,000) persons OR (calculated): 0.95 (0.24, 4.42) [underlined: Suicide attempts*] Drug: 29/7944 (36.5/10,000) persons Placebo: 17/4302 (39.5/10,000) persons OR (calculated): 0.92 (0.49, 1.79) Long-term trials-likely MDD [underlined: Suicide completion*] Drug: 2/1345 (14.9/10,000) persons Placebo: 0/604 (0/10,000) persons [underlined: Suicide attempts*] Drug: 9/1345 (66.9/10,000) persons Placebo: 4/604 (66.2/10,000) persons OR (calculated): 1.01 (0.28, 4.51) Long-term MEDLINE-in MDD [underlined: Suicide completion] Drug: 7/1440 (48.6/10,000) persons Placebo: 1/889 (11.3/10,000) persons OR (calculated): 4.34 (0.56, 195.72) [underlined: Suicide attempts] Drug: 9/1440 (62.5/10,000) persons Placebo: 0/889 (0/10,000) persons *Not significantly different | | Article states that most trials included patients who fulfilled DSM criteria for major depression, thus results are likely MDD patients in regulatory trials.

RCT-randomized controlled trial; MDD-major depressive disorder; SSRI-selective serotonin reuptake inhibitor; TCA-tricyclic antidepressant; NR-not reported; MHRA-Medicines and Healthcare Products Regulatory Agency; CSM-Committee on Safety of Medicines.

Appendix G Table 5 Evidence table of cohort studies of suicide risk with SSRIs.

Study USPSTF Quality | Data Included | Drugs | Conditions | Time Period | Outcomes | Quality Issues/Comments
Sondergard 2006^144^ Int Clin Psychopharmacol Funder: The Lundbeck Foundation Fair-Poor Quality | Nationwide Danish cohort 1995–1999 Registry of all prescribed antidepressants Registry of recorded suicides Taking antidepressant N: 438,625 Not taking an antidepressant N:1,073,862 (is approximately a 25% random sample of the population) | SSRIs: citalopram, fluoxetine, fluvoxamine, paroxetine, sertraline Other: mirtazapine, venlafaxine, negazodone, reboxetine Older: -TCAs (11) -MAOIs: isocarboxazid moclobemide Tetracyclics: maprotiline mianserin | Any indication: 438,625 Any antidepressant dispensed-no consideration of previous treatment. Excluded those who purchased lithium Age: median 56 yrs SSRI: N: 338,558 % Female: 64 Other: N: 58,596% Female: 64 Older: N: 153,540% Female: 68 | Followup: up to5 yrs | Sample not taking antidepressants: [underlined: Suicides:] 671 persons; (6.2/10,000) [underlined: Suicide rates:] Total: 12.6 per 100,000 py; (1.26/10,000) Men: 19.9 per 100,000 py; (1.99/10,000) Women: 5.5 per 100,000 py; (0.55/10,000) Sample taking antidepressants [underlined: Suicides]: 1474 persons; (33.6/10,000) [underlined: Range of suicide rates (by medication type)]: Total: 115.4–486.2 per 100,000 py (11.5–48.6 per 10,000 py) Men: 202.2–463.6 per 100,000 py (20.2–46.4 per 10,000 py) Women: 72.9–169.9 per 100,000 py (7.3–17.0 per 10,000 py) | Quality Issues: Comparison sample not matched to cases- were “random sample of everyone else approximately 25% Strong risk of confounding by indications in drug- specific rates due to not selecting new users only and treatment for all indications. Comments: Suicide rates 2–3 times higher in men than women- whether treated or untreated. 70% of suicides occurred during the 1^st^ month.
Simon 2006^129^ Simon 2007^241^ Am J Psych Funder: NIH Good Quality | Prepaid group practice in Washington and Idaho 1992–2003 Group Health Cooperative -Pharmacy records -Outpatient visits registration -Hospital discharge data -Mortality records from state and national death certificate data Additional analysis 70,368 patients from of 1996–2005 | SSRIs: citalopram, fluoxetine, fluvoxamine, paroxetine, sertraline escitalopram SNRI: venlafaxine Other: buproprion, mirtazapine, nefazodone, trazodone TCAs | 65,103 patients with MDD, dysthymia or depressive disorder not otherwise specified 82,285 episodes of antidepressant treatment 9,520 patients contributed 2 episodes 1,916 patients contributed >2 episodes Included if had not filled an antidepressant prescription in previous 180 days. Age: mean 44 yrs (5–105) % Female: 69.5 5107 episodes (6.2%) were in patients <18 yrs | 6 months for all persons after antidepressant use initiated. Gathered data for 10.5 yr period. | Suicides: N: 31 persons (4.8/10,000 4/10,000 treatment episodes <18 yrs. 5.9/10,000 treatment episodes ≥18 yrs 3.6/10,000 treatment episodes Male vs. Female: OR 6.6 95% CI (2.9, 14.7), but did not vary across age. Attempts: N: 76 persons (11.7/10,000): 9.3/10,000 treatment episodes Overall, 73 suicide attempts prior to prescription <18 yrs N: 314/100,000 persons 95% CI (160, 468) (31.4/10,000) ≥18 yrs N: 78/100,000 persons 95%CI (58–98) (7.8/10,000) No difference by sex Rate of entire covered population: 1.7/10,000 Relative odds (range) of suicide attempt from prescription date by sources of prescription >30 days prior Primary care: 0.47 (0.32, 0.69) Psychiatrist: 0.69 (0.33, 1.45) Psychotherapy: 0.40 (0.30, 0.54) 1–30 days prior Primary care: 1.90 (1.28, 2.81) Psychiatrist: 3.57 (1.70, 7.48) Psychotherapy: 3.35 (2.52, 4.45) >30 days after Primary care: 0.16 (0.08, 0.30) Psychiatrist: 0.56 (0.23, 1.37) Psychotherapy: 0.23 (0.15, 0.36) [underlined: Age > 25 yrs] >30 days prior Primary care: 0.56 (0.33, 0.94) Psychiatrist: 0.65 (0.21, 1.99) Psychotherapy: 0.42 (0.27, 0.65) 1–30 days prior Primary care: 1.85 (1.06, 3.23) Psychiatrist: 4.02 (1.34, 12.06) Psychotherapy: 3.19 (2.11, 4.81) >30 days after Primary care: 0.13 (0.05, 0.35) Psychiatrist: 0.87 (0.26, 2.99) Psychotherapy: 0.22 (0.11, 0.41) | 10% Medicare 7% Medicaid Overall mortality in Group Health population 1992–2002 17/100,000 Risk of suicide deaths was not higher in the 1^st^ month than subsequent months OR=1.2, 95%CI (0.5, 2.9). Deaths occur at about same rate over 6 months. Risk of attempt was higher in the first month than subsequent 5 months OR 2.4 95% CI (1.6, 3.8). However, highest risk was in the month preceding treatment.
Martinez 2005^128^ BMJ Funder: Medicines and Healthcare products Regulatory Agency Good Quality | UK General Practice Research Database-contains clinical records from primary care 1995–2001 | SSRIs: citalopram, fluoxetine, fluvoxamine paroxetine, sertraline Other: flupenthixol, mirtazapine, reboxetine, tryptophan, venlafaxine MAOIs: phenelzine, isocarboxazid, tranylcypromine, moclobemide TCAs: amimtriptyline, amoxapine, clomipramine, dosulepin or dothiepin, doxepin, imipramine, lofepramine, notrtriptyline, trimipramine, maprotiline, mianserin, trazodone. | N: 146,095 people with new antidepressant prescription (no antidepressants within last year) Diagnosed with depression, bipolar disorder, or dysthymic disorder Age: 10–90 yrs, 18% >60 yrs % Female: 65 % mild depression: 69 | 62,224 person- yrs Observation in years-median (interquartile range): 0.66 (0.57–1.03) | Suicides-All drugs 69/146,095 persons (4.7/10,000) 19–30 yrs: 19/34,792 persons; (5.5/10,000) >30 yrs: 50/106,016 persons; (4.7/10,000) Female: 13/94,767 persons; (1.4/10,000) Male: 56/51,328 persons; (10.9/10,000) Standardized incidence rate (age and sex): 6.2 (95% CI 4.0 to 8.5) per 10,000 py Female: 0.9 (0.1 to 1.8) per 10,000 py Male: 11.7 (7.2 to 16.3) per 10,000 py Non-fatal self harm-All drugs 1968/146,095 persons (134.7/10,000) 19–30 yrs: 747/34,792 persons; (214.7/10,000) >30 yrs: 936/106,016 persons; (88.3/10,000) Female: 1105/94,767 persons;(116.6/10,000) Male: 863/51,328 persons; (168.1/10,000) Standardized incidence rate (age and sex): 289.4 (95% CI 261.8 to 317.0) per 10,000 py. No differences by sex. | Descriptive data clearly indicate differences in those treated with SSRIs vs. others=especially TCAs (e.g., younger, increased history of self harm and referral to psychiatrists). Therefore drug-to-drug comparisons are confounded. 36/69 people (52%). were taking antidepressants at the time of death. Self-harm events were primarily drug overdoses (81%).
Jick 1995^127^ BMJ Funder: Pharmaceutical companies, RW Johnson Pharmaceutical Research Institute Fair Quality | UK General Practice Research Database - primary care records 1988–1993 | SSRIs: fluoxetine TCAs: dothiepin, amitriptyline, clomipramine, imipramine, lofepramine, doxepin Tetracyclic: mianserin Other: trazodone, flupenthixol | N: 172,598 of all indications 1,198,303 prescriptions 67/143 had history of suicidal behavior or had been prescribed >1 antidepressant 112/143 had documentation of depressive illness | 6 mo after antidepressant prescribed 167,819 py | Suicides 143/172,598 persons (8.3/10,000) 8.5 (95% CI 7.2, 10.0) per 10,000 py | Quality Issues: Death ascertainment mostly limited to medical records. Comments: In nested case control analyses, men had 2.8 (95% CI 1.9, 4.0) greater risk of suicide.
Mackay 1999^147^ Brit J of Gen Prac Mackay 1997^145^ Pharm and Drug Safety Funder: Drug Safety Research Unit Fair-Poor Quality | UK Prescription Event Monitoring Database -includes data studies monitoring 6 newly released antidepressants 1989–1996. Surveys of GPs six months following the first prescription for each patient in immediate post-marketing period. Response rates 55–64%. | SSRIs: fluoxetine, sertraline, paroxetine Other: nefazodone, venlafaxine, moclobemide | N: 74,748 patients of all indications (>80% depression) Mean age: 45.5–50.1 Female: 62.1–69.8% | 6 mo | Suicide and parasuicide-All drugs 2.7–5.6 per 1000 patient months (324–672/10,000 py) | Quality Issues: Low survey response rate (55–64%) and possible differential reporting of those with or without the events. Comments: All analyses excluded patients treated for mania, hypermania, agitation, or anxiety. Report of mania: 1.2 per 1000 pt-months of treatment during 90 days. Any type of death-All drugs-6 mo. 1098/74,748 persons (146.9/10,000-calculated) [underlined: Most frequently reported events in 1]^st^ [underlined: month of treatment, range across medications:] Nausea/vomiting 26.3–71.9 per 1000 pt-months Malaise 9.9–25.0 per 100 pt months Headache 12.5–25.1 per 1000 pt-months. Dizziness 6.7–31.9 per 1000 pt-months Drowsiness 7.3–25.5 per 1000 pt-months
(Data specific to Mackay 1997^145^ | Four studies from Prescription Monitoring Database 1987–1992 | SSRIs: fluvoxamine, fluoxetine, sertraline, paroxetine | N: 50,150 of all indications (>70% depression) Mean age: 48.6–51.0 Female: 67.5–70.1% | 6 mo | Suicides 110/50,150 persons; (21.9/10,000) | Same quality issues.
Gibbons 2007^146^ Fair-to-Poor Quality | US Veteran’s Administration National Patient Care Database and Pharmacy Benefits Management Database 2003–2004 | SSRIs (agents not specified); non-SSRI 2^nd^ generation (bupropion, mirtazapine, nefazodone, venlafaxine); TCAs | N: 226,866 with depressive disorders or unipolar mood disorders in medical record in 2003 or 2004 and no indication of depression in 2000–2002. 59,432 not treated with antidepressant 114,475 treated with one class of antidepressants 52,959 treated with >1 class of antidepressants Mean age: 57.4 yrs (SD 14.8) Female: 8.4% | 6–24 months of follow-up | Suicide attempts 36.4/10,000, among those treated with SSRI alone or in combination with other antidepressants 33.5/10,000 among those not treated with an antidepressant | Quality Issues: Drug-to- drug comparison distorted due to confounding by indication; did not statistically control for indicators of severity and more patients with MDD treated with non-SSRIs than SSRIs. Examined subgroup of those taking only one type of antidepressant-not representative of any treatment practice. Therefore, most analyses exclude 52,959/167,434 (32%) of those treated as they used combinations of medications. Comments: Did not examine suicide deaths

SSR-selective serotonin reuptake inhibitor; TCA-tricyclic antidepressant; MAOI- monoamine oxidase inhibitor; py-person years; F/U follow-up; GP-general practitioner; RR-relative risk; AD-antidepressant.

Appendix G Table 6 Evidence table of studies of discontinuation of SSRIs

Study | Data Included | Drugs | Trials and Participants | Time Period/Follow-up | Outcomes | Comments | Quality
Meta-analyses/Systematic Reviews of RCTs
Arroll 2005^72^ Systematic Review | Published articles through 2004 involving RCTs of SSRI or TCA vs placebo in adult primary care patients. Studies of primarily children or elderly were excluded. | Sertraline (2); Escitalopram (3); Citalopram (1) | 4 trials of SSRI vs placebo addressed discontinuation 3 trials included only those with MDD; 1 had heterogenous depression diagnoses N: 1149 participants Sample characteristics NR | 6–24 weeks | Discontinuation due to AE (4 studies) SSRI: 5.2% (30/576) Placebo: 2.6%) (15/573) RR (Fixed; 95% CI): 2.01 (1.10–3.69) P<0.02 | All 4 studies were commercially funded - receiver was not. Sensitivity analyses found no difference for high quality vs low quality studies in primary analysis | Good
Mulrow 2000^95^ Williams 2000^75^ Meta-analysis | Published and unpublished RCTs measuring clincal outcomes for any of 32 newer antidepressants with another antidepressant, psychosocial intervention, or placebo in primary care or general practice setting. Searched 1980-Jan 1998, many databases and extensive hand-searching | Newer meds for treating depression: Fluoxetine, Fluvoxamine, Paroxetine, Sertraline, Citalopram, Indalpine, Tomoxetine, Litoxetine, Femoxetine, Venlafaxine, Milnacipran, Mirtazapine, Viloxazine, Reboxetin, Moclobemine, Medifoxamine, Brofaromine, Toloxatone, Nefazodone, Ritanserin, Gepirone, Ipsapirone, Tandospirone, Felsinoxan, Fengabine, Amisulpride, Sulpiride, Bupropion, Minaprine, St. John’s Wort | 28 trials with 90% or more of patients related to primary care N: 5940 Mean age: 45 years Female: 71% Depressed adults Other sample characteristics NR | Required > 6 weeks; most were 6–8 weeks (up to 24 weeks) | Discontinuation due to AE SSRI (range): 6–11% Placebo: 2% (raw Ns NR) Overall drop-out rate SSRI: 16–29% | 27 trials from Europe; one from US. 20/28 funded by manufacturer; 8/28 not reported. Many trials used doses toward the lower range of standard dosages | Good - intent to treat analyses used throughout Excluded patients with: 1) Serious medical illnesses 2) Cognitive impairment 3) Alcohol abuse
Beasley 2000^91^ Meta-analysis by manufacturer | 25 US Investigative New Drug Trials (RCTs) comparing fluoxetine with placebo, TCAs, or both. Trials completed through 1998; likely includes unpublished data. | Fluoxetine (20–80 mg/d) | 25 trials of fluoxetine vs placebo Patients with MDDN: 4016 12–90 yrs old; mean 46 yrs White: 92% Female: 62% Average run-in 1 wk Depression severity and suicide history NR Total patients in discontinuation trials: 2562 Fluoxetine: 160 Placebo: 952 | 5–12 weeks | Discontinuation due to AE: 20–80 mg/d Fluoxetine: 13.7% (221/1610 calc) Placebo: 6.0% (57/952 calc) P< 0.001 20 mg/d Fluoxetine: 9.0% (62/690 calc) Placebo: 7.7% (44/568 calc) P< 0.39 Total Discontinuation: 20–80 mg/d Fluoxetine: 37.7% (607/1610 calc) Placebo: 38.2% (364/952 calc) P=0.211 20 mg/d Fluoxetine: 29% (200/690 calc) Placebo: 27.5% (156/568 calc) P=0.832 | Researchers from Eli Lilly Includes patients under age 18 - but what % age is not provided Excluded patients: 1) Improved 20% in 1 week placebo run-in 2) History of substance abuse 3) Serious suicide risk 4) Psychosis, unstable medical condition Adverse events done by blinded investigation | Fair - due to potential conflict of interest and from lack of quality assessment (assumes all Investigational New Drug Trials are well done)
Gartlehner 2007^92^ Comparative Effectiveness Review | High-quality meta-analyses, head-to-head double-blind RCTs, or controlled observational studies. Searched 1980–Feb 2006, included strategies for unpublished data. | 2nd generation antidepressants approved for us in the U.S.: Buproprion, Citalopram, Duloxetine, Escitalopram, Fluoxetine, Fluvoxamine, Mirtazapine, Nefazodone, Paraxetine, Sertraline, Trazodone, Venlafaxine | MDD, dysthymia, or subsyndromal depression Discontinuation N, trials: NR N, patients: NR Sample characteristics NR | Minimum 6 wks for RCTs, 3 months for observational studies | Discontinuation due to AE SSRIs: 8.1% Buproprion: 6.7% Duloxetine: 5.5% Mirtazapine: 9.5% Nefazodone: 15.0% Trazodone: 7.0% Venlafaxine: 11.5% Total Discontinuation: SSRIs: 20.8% Buproprion: 14.1% Duloxetine: 17.2% Mirtazapine: 21.6% Nefazodone: 23.6% Trazodone: 20.7% Venlafaxine: 24.8% (raw Ns NR) | Did not review all placebo controlled RCTs for this as it was a Comparative effectiveness review. Reporting does not allow data for discontinuation to be verified | Fair - due to reporting
Mottram 2005^94^ Cochrane comparative effectiveness review | RCTs comparing two or more antidepressants in treatment of depression in older (55+) adults. Searched through July 2003, may have included some unpublished data. | SSRIs: Paroxetine, fluoxetine, citalopram, fluvoxamine, sertraline; Other 2nd Generation: buspirone, bupropion, milnacipan, venlafaxine, reboxetine; | 18 trials conducted in outpatient settings primarily in 1302 patients with MDD, dysthymia, unipolar depression, or non-specified depression N: 554 SSRI recipients Sample characteristics NR | 4–8 weeks | Discontinuation due to AE SSRIs: 17.3% (96/554) Other 2nd generation: 8.0% (60/748) Total Discontinuation: SSRIs: 27.4% (152/554) Other 2nd generation: 36.0% (269/748) | | Good
Anderson 2000^90^ Meta-analysis | Published RCTs comparing efficacy and/or tolerability of SSRIs and TCAs in treatment of depression in adults. Searched MEDLINE through May 1997 and cross-referenced with previous meta-analyses and reviews | SSRIs: Paroxetine, fluoxetine, citalopram, fluvoxamine, sertraline; | 95 RCTs N: 10,839 Patients with unipolar major depressive illness Sample characteristics NR | Most 4–8 weeks | Discontinuation due to AE SSRIs: 12.4% Adults 65+ SSRI or TCA: 21.8% Adults <65 SSRI or TCA: 14.7% Total Discontinuation: SSRIs: 27.0% Adults 65+ SSRI or TCA: 36.5% Adults<65 SSRI or TCA: 29.2% Raw Ns – NR | Reported that total discontinuation and discontinuation due to adverse events in elderly were similar between TCAs and SSRIs | Good
MacGillivray 2003^93^ Meta-analysis | RCTs comparing SSRIs with TCA in adult primary care patients. Searched Cochrane Depression, Anxiety, and Neurosis group database through April 2002. Included efforts to identify unpublished literature. | SSRIs and TCAs (did not specify agents) | 8 RCTs Mean age 40–45 yrs 75% female in most trials Mostly Caucasian Predominantly adults in primary care with depressive disorder | NR | Discontinuation due to AE SSRIs: 11.6% (164/1416) 95% CI (9.9%, 13.3%) Total Discontinuation: SSRIs: 20.7% (264/1275) | Primary results robust to excluding or including poorer quality trials | Fair - due to limited search strategy
Cohort Studies/Uncontrolled Treatment Trials
Rush 2006^46^ STAR-D | Treatment discontinuation after each of four treatment phases, only those unsuccessfully treated in previous step move to subsequent step | Step 1: Citalopram Step 2: Bupropion; Sertraline; Venlafaxine; Citalopram plus bupropion, buspirone, or cognitive therapy; or Cognitive therapy Step 3: Nortriptyline, Mirtazapine, Lithium augmentation, T3 augmentation, Bupropion, or Venlafaxine Step 4: Tranylcypromine or Venlafaxine XR+Mirtazapine | Non-psychotic major depressive disorder At initial treatment step: Mean age: 40.7 yrs Female: 62.2% White: 76.8% Black: 16.8% Hispanic: 11.9% Depression severity and history of suicidality NR | Average 8.6 –10.1 weeks for each step | Discontinuation due to AE* Step 1: 16.3% (599/3671) Step 2: 19.5% (281/1439) Step 3: 25.6% (100/390) Step 4: 30.1% (37/123) *Discontinuation <4 wks or indicated intolerance as reason for exit from study | | Fair
Kroenke, 2001^96^ ARTIST | Open-label intention - to-treat trial or depressed primary care patients | Paroxetine, Fluoxetine, Sertraline | MDD, Dysthymia, Minor Depression Mean age: 47.2 (Paroxetine) 47.1 (Fluoxetine) 44.1 (Sertraline) % Female: 76% (Paroxetine) 86% (Fluoxetine) 75% (Sertraline) % White: 85% (Paroxetine) 88% (Fluoxetine) 79% (Sertraline) | Follow-up at 1, 3, 6, and 9 months | Discontinuation due to AE at 9 months: Paroxetine: 30% (56/189) Fluoxetine: 23% (44/193) Sertaline: 24% (46/191) Total Discontinuation, by drug at 9 months: Paroxetine: 45% (85/189) Fluoxetine: 34% (66/193) Sertaline: 41%* (77/191) *41% reported, but calculates as 40% from raw Ns Total Discontinuation, all drugs: 1 mo: 13% 3 mo: 23% 6 mo: 32% 9 mo: 40% (raw Ns NR) | Total discontinuation: Stopped taking antidepressant or switched to another antidepressant Community-based primary care network research | Fair

RCT- randomized controlled trial; MDD- major depressive disorder; SSRI-selective serotonin reuptake inhibitor; TCA-tricyclic antidepressant; NR-not reported; RR-relative risk; AE-adverse events.

Appendix G Table 7 Studies excluded from the review.

Reference | Reason for exclusion
Ackermann RT, Williams JW. Rational treatment choices for non-major depressions in primary care: an evidence-based review. J Gen Intern Med 2002; 17(4): 293–301. | Exclusive focus on minor depression
Addis A, Koren G. Safety of fluoxetine during the first trimester of pregnancy: a meta-analytical review of epidemiological studies. Psychol Med 2000; 30(1): 89–94. | Focus on pregnancy-related screening
Adler DA, Bungay KM, Wilson IB, Pei Y, Supran S, Peckham E et al. The impact of a pharmacist intervention on 6-month outcomes in depressed primary care patients. General Hospital Psychiatry 2004; 26(3): 199–209. | Focus on treatment comparison, matching, or fine-tuning
Alexopoulos GS, Raue P, Arean P. Problem-solving therapy versus supportive therapy in geriatric major depression with executive dysfunction. American Journal of Geriatric Psychiatry 2003; 11(1): 46–52. | Not a general primary care population
Ali S, Milev R. Switch to Mania Upon Discontinuation of Antidepressants in Patients With Mood Disorders: A Review of the Literature. Canadian Journal of Psychiatry 2003; 48(4): 258–264. | Not one of included study designs for relevant key question
Allard P, Gram L, Timdahl K, Behnke K, Hanson M, Sogaard J. Efficacy and tolerability of venlafaxine in geriatric outpatients with major depression: a double-blind, randomised 6-month comparative trial with citalopram. Int J Geriatr Psychiatry 2004; 19(12): 1123–1130. | Not one of included study designs for relevant key question
Ames D. Depression and the elderly. In: Dawson A, Tylee A, editors. Depression: Social and exonomic timebomb. London: BMJ Publishing Group; BMA House; Tavistock Square, 2001: 49–62. | Not one of included study designs for relevant key question
Arean PA, Alvidrez J. Treating depressive disorders: who responds, who does not respond, and who do we need to study? J Fam Pract 2001; 50(6): E2. | Does not report included outcomes
Arean PA, Gum A, McCulloch CE, Bostrom A, Gallagher-Thompson D, Thompson L. Treatment of depression in low-income older adults. Psychology & Aging 2005; 20(4): 601–9. | Focus on treatment comparison, matching, or fine-tuning
Arean PA, Perri MG, Nezu AM, Schein RL, Christopher F, Joseph TX. Comparative effectiveness of social problem-solving therapy and reminiscence therapy as treatments for depression in older adults. J Consult Clin Psychol 1993; 61(6): 1003–1010. | Not one of included study designs for relevant key question
Arthur AJ, Jagger C, Lindesay J, Matthews RJ. Evaluating a mental health assessment for older people with depressive symptoms in general practice: a randomised controlled trial. Br J Gen Pract 2002; 52(476): 202–207. | Focus on treatment comparison, matching, or fine-tuning
Arya DK. Suicidality and the use of serotonin reuptake inhibitors. Aust.N.Z.J.Psychiatry 1995; 29(3): 517–518. | Not one of included study designs for relevant key question
Aursnes I, Tvete IF, Gaasemyr J, Natvig B. Suicide attempts in clinical trials with paroxetine randomised against placebo. BMC Med 2005; 3:14. | Updated/covered by a more recent SER/MA
Badamgarav E, Weingarten SR, Henning JM, Knight K, Hasselblad V, Gano A, Jr. et al. Effectiveness of disease management programs in depression: a systematic review. American Journal of Psychiatry 2003; 160(12): 2080–90. | Not a screening intervention trial with usual care control group
Bains J, Birks JS, Dening TR. Antidepressants for treating depression in dementia. Cochrane Database of Systematic Reviews 2005;(3). | Not a general primary care population
Bak S, Tsiropoulos I, Kjaersgaard JO et al. Selective serotonin reuptake inhibitors and the risk of stroke: a population-based case-control study. Stroke. 2002; 33: 1465–1473. | Baseline groups not comparable on age, and outcomes is strongly related to age.
Baker R, Reddish S, Robertson N, Hearnshaw H, Jones B. Randomised controlled trial of tailored strategies to implement guidelines for the management of patients with depression in general practice. Br J Gen Pract 2001; 51(470): 737–741. | Not a screening intervention trial with usual care control group
Ballesteros J, Callado LF. Effectiveness of pindolol plus serotonin uptake inhibitors in depression: a meta-analysis of early and late outcomes from randomised controlled trials. J Affect Disord 2004; 79(1–3): 137–147. | Focus on treatment comparison, matching, or fine-tuning
Barak Y, Aizenberg D. Association between antidepressant prescribing and suicide in Israel. Int Clin Psychopharmacol 2006; 21(5): 281–284. | Not one of included study designs for relevant key question
Barak Y, Olmer A, Aizenberg D. Antidepressants reduce the risk of suicide among elderly depressed patients. Neuropsychopharmacology 2006; 31(1): 178–181. | Not a general primary care population
Barbui C, Hotopf M, Freemantle N, Boynton J, Churchill R, Eccles MP et al. Treatment discontinuation with selective serotonin reuptake inhibitors (SSRIs) versus tricyclic antidepressants (TCAs). Cochrane Database of Systematic Reviews 2005;(3). | Focus on treatment comparison, matching, or fine-tuning
Barbui C, Percudani M. Epidemiological impact of antidepressant and antipsychotic drugs on the general population. Current Opinion in Psychiatry 2006; 19(4): 405–410. | Not one of included study designs for relevant key question
Barlow J, Coren E, Stewart-Brown S. Meta-analysis of the effectiveness of parenting programmes in improving maternal psychosocial health. Br J Gen Pract 2002; 52(476): 223–233. | Not a screening intervention trial with usual care control group
Barlow J, Coren E, Stewart-Brown SSB. Parent-training programmes for improving maternal psychosocial health. Cochrane Database of Systematic Reviews 2005;(3). | Not a screening intervention trial with usual care control group
Barrett B, Byford S, Knapp M. Evidence of cost-effective treatments for depression: a systematic review. J Affect Disord 2005; 84(1): 1–13. | Comparative-effectiveness
Barsevick AM, Sweeney C, Haney E, Chung E. A systematic qualitative analysis of psychoeducational interventions for depression in patients with cancer. Oncol Nurs Forum 2002; 29(1): 73–84. | Not a general primary care population
Bartels SJ, Coakley EH, Zubritsky C, Ware JH, Miles KM, Arean PA et al. Improving access to geriatric mental health services: A randomized trial comparing treatment engagement with integrated versus enhanced referral care for depression, anxiety, and at-risk alcohol use. Am J Psychiatry 2004; 161(8): 1455–1462. | Focus on treatment comparison, matching, or fine-tuning
Bauer M, Dopfmer S. Lithium augmentation in treatment-resistant-depression: meta-analysis of placebo-controlled studies. J Clin Psychopharmacol 1999; 19(5): 427–434. | Focus on treatment comparison, matching, or fine-tuning
Bech P. Meta-analysis of placebo-controlled trials with mirtazapine using the core items of the Hamilton Depression Scale as evidence of a pure antidepressive effect in the short-term treatment of major depression. Int J Neuropsychopharmacol 2001; 4(4): 337–345. | Screen not used in clinical care
Berardi D, Menchetti M, Cevenini N, Scaini S, Versari M, De Ronchi D. Increased recognition of depression in primary care. Comparison between primary-care physician and ICD-10 diagnosis of depression. Psychotherapy & Psychosomatics 74(4): 225–30, 2005. | Not a screening intervention trial with usual care control group
Beusterien KM, Buesching DP, Robison RN, Keats MM, Tomlinson JR, Cofran KW, Bailit HL, Adler DA, Bungay KM, Schrammel PN, Goss TF. Evaluation of an information exchange program for primary care patients with depression. Disease Management 2000; 3(1): 1–9. | Focus on treatment comparison, matching, or fine-tuning
Beutler LE, Scogin F, Kirkish P, Schretlen D, Corbishley A, Hamblin D et al. Group cognitive therapy and alprazolam in the treatment of depression in older adults. J Consult Clin Psychol 1987; 55(4): 550–556. | Not one of included study designs for relevant key question
Bezchlibnyk-Butler K, Aleksic I, Kennedy SH. Citalopram--a review of pharmacological and clinical effects. Journal of Psychiatry & Neuroscience 2000; 25(3): 241–254. | Updated/covered by another more recent SER/MA
Bijl D, van Marwijk HW, de Haan M, van Tilburg W, Beekman AJ. Effectiveness of disease management programmes for recognition, diagnosis and treatment of depression in primary care. European Journal of General Practice 2004; 10(1): 6–12. | Used as source document only
Bijl D, van Marwijk HWJ, Beekman ATF, de Haan M, van Tilburg W. A randomized controlled trial to improve the recognition, diagnosis and treatment of major depression in elderly people in general practice: Design, first results and feasibility of the West Friesland Study. Primary Care Psychiatry 2003; 8(4): 135–140. | Does not report included outcomes
Blanchard MR WA. The effect of primary care nurse intervention upon older people screened as depressed. International Journal of Geriatric Psychiatry 1995; 10(4): 289–298. | Focus on treatment comparison, matching, or fine-tuning
Blanchard MR, Waterreus A, Mann AH. Can a brief intervention have a longer-term benefit? The case of the research nurse and depressed older people in the community. International Journal of Geriatric Psychiatry 1999; 14(9): 733–8. | Focus on treatment comparison, matching, or fine-tuning
Blier P, Tremblay P. Physiologic mechanisms underlying the antidepressant discontinuation syndrome. J Clin Psychiatry 2006; 67: Suppl-13. | Does not address included outcomes
Bohlmeijer E, Smit F, Cuijpers P. Effects of reminiscence and life review on late-life depression: a meta-analysis. Int J Geriatr Psychiatry 2003; 18(12): 1088–1094. | Not one of included study designs for relevant key question
Bourin M. Use of paroxetine for the treatment of depression and anxiety disorders in the elderly: a review. Human psychopharmacology 2003; 18(3): 185–190. | Updated/covered by another more recent SER/MA
Brambilla P, Cipriani A, Hotopf M, Barbui C. Side-effect profile of fluoxetine in comparison with other SSRIs, tricyclic and newer antidepressants: a meta-analysis of clinical trial data. Pharmacopsychiatry 38(2): 69–77, 2005. | Focus on treatment comparison, matching, or fine-tuning
Brannan SK, Mallinckrodt CH, Brown EB, Wohlreich MM, Watkin JG, Schatzberg AF. Duloxetine 60 mg once-daily in the treatment of painful physical symptoms in patients with major depressive disorder. J Psychiatr Res 2005;(1): 43–53. | Focus on non-elderly adults
Breggin PR. Recent U.S., Canadian and British regulatory agency actions concerning antidepressant-induced harm to self and others: A review and analysis. International Journal of Risk & Safety in Medicine 2004; 16(4): 247–259. | Not one of included study designs for relevant key question
Breggin PR. Suicidality, violence and mania caused by selective serotonin reuptake inhibitors (SSRIs): A review and analysis. International Journal of Risk & Safety in Medicine 16(1), 31–49. 2003. | Not one of included study designs for relevant key question
Bruce ML, Ten Have TR, Reynolds CFI, Katz II, Schulberg HC, Mulsant BH et al. Reducing Suicidal Ideation and Depressive Symptoms in Depressed Older Primary Care Patients: A Randomized Controlled Trial. JAMA: Journal of the American Medical Association 2004; 291(9): 1081–1091. | Not one of included interventions
Buchberger R, Wagner W. Fluvoxamine: safety profile in extensive post-marketing surveillance. Pharmacopsychiatry 2002; 35(3): 101–108. | Updated/covered by another more recent SER/MA
Burke WJ. Escitalopram. Expert Opinion on Investigational Drugs 2002; 11(10): 1477–1486. | Updated/covered by another more recent SER/MA
Burt VK, Wohlreich MM, Mallinckrodt CH, Detke MJ, Watkin JG, Stewart DE. Duloxetine for the treatment of major depressive disorder in women ages 40 to 55 years. Psychosomatics 2005; 46(4): 345–354. | Not one of included study designs for relevant key question
Bush DE, Ziegelstein RC, Patel U, V, Thombs BD, Ford DE, Fauerbach JA et al. Post-myocardial infarction depression. Evidence Report: Technology Assessment (Summary) 2005; (123): 1–8. | Not a general primary care population
Calil HM. Fluoxetine: A suitable long-term treatment. J.Clin.Psychiatry 2001; 62(Suppl 22), 24–29. | Not one of included study designs for relevant key question
Callahan CM, Hendrie HC, Dittus RS, Brater DC, Hui SL, Tierney WM. Improving treatment of late life depression in primary care: a randomized clinical trial. J Am Geriatr Soc 1994; 42(8): 839–846. | Does not report included outcomes
Carroll BJ. Citalopram and the Curate’s egg in geriatric depression. Am J Psychiatry 2005; 162(9): 1762–1763. | Not one of included study designs for relevant key question
Casacalenda N, Perry JC, Looper K. Remission in major depressive disorder: a comparison of pharmacotherapy, psychotherapy, and control conditions. Am J Psychiatry 2002; 159(8): 1354–1360. | Non-elderly treatment study
Cassano GB, Puca F, Scapicchio PL, Trabucchi M, Italian Study Group on Depression in Elderly Patients. Paroxetine and fluoxetine effects on mood and cognitive functions in depressed nondemented elderly patients. Journal of Clinical Psychiatry 2002; 63(5): 396–402. | Focus on treatment comparison, matching, or fine-tuning
Chisholm D, Sanderson K, Ayuso-Mateos JL, Saxena S. Reducing the global burden of depression: population-level analysis of intervention cost-effectiveness in 14 world regions. Br J Psychiatry 2004; 184: 393–403. | Does not report included outcomes
Christensen KS, Toft T, Frostholm L, Ornbol E, Fink P, Olesen F. Screening for common mental disorders: who will benefit? Results from a randomised clinical trial. Fam Pract 2005; 22(4): 428–434. | Missing both depression-specific screener and depression-specific outcome
Churchill R, Dewey M, Gretton V, Duggan C, Chilvers C, Lee A. Should general practitioners refer patients with major depression to counsellors: a review of current published evidence. Br J Gen Pract 1999; 49(446): 738 | Years covered precede 1999
Churchill R, Hunot V, Corney R, Knapp M, McGuire H, Tylee A et al. A systematic review of controlled trials of the effectiveness and cost-effectiveness of brief psychological treatments for depression. Health Technol Assess 2001; 5(35): 1–173. | Updated/covered by another more recent SER/MA
Cipriani A, Brambilla P, Barbui C, Hotopf M. Fluoxetine versus other types of pharmacotherapy for depression. Cochrane Database of Systematic Reviews 2005;(3). | Focus on treatment comparison, matching, or fine-tuning
Cohen D, Hoeller K. Screening for depression: preventive medicine or telemarketing? Ethical Human Sciences & Services 5(1): 3–6, 2003. | Not one of included study designs for relevant key question
Cohen JS. Avoiding adverse reactions. Effective lower-dose drug therapies for older patients. Geriatrics 2000; 55(2): 54–6, 59–60, 63–4. | Not one of included study designs for relevant key question
Cole MG, Elie LM, McCusker J, Bellavance F, Mansour A. Feasibility and effectiveness of treatments for post-stroke depression in elderly inpatients: systematic review. J Geriatr Psychiatry Neurol 2001; 14(1): 37 | Not a general primary care population
Cole MG, McCusker J, Elie M, Dendukuri N, Latimer E, Belzile E. Systematic detection and multidisciplinary care of depression in older medical inpatients: a randomized trial. CMAJ Canadian Medical Association Journal 2006; 174(1): 38–44. | Focus on inpatient, residential treatment, psychiatric, or community settings
Coleman CC, Cunningham LA, Foster VJ, Batey SR, Donahue RM, Houser TL et al. Sexual dysfunction associated with the treatment of depression: a placebo-controlled comparison of bupropion sustained release and sertraline treatment. Ann Clin Psychiatry 1999; 11(4):205–215. | Does not report included outcomes
Coleman CC, King BR, Bolden-Watson C, Book MJ, Segraves RT, Richard N et al. A placebo-controlled comparison of the effects on sexual functioning of bupropion sustained release and fluoxetine. Clin Ther 2001; 23(7):1040–1058. | Does not report included outcomes
Coleman EA, Grothaus LC, Sandhu N, Wagner EH. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults see comments. Journal of the American Geriatrics Society 1999; 47(7):775. | Not a general primary care population
Cookson J, Gilaberte I, Desaiah D, Kajdasz DK. Treatment benefits of duloxetine in major depressive disorder as assessed by number needed to treat. Int.Clin.Psychopharmacol. 2006;21(5), 267–273. | Focus on non-elderly adults
Corney R, Simpson S. Thirty-six month outcome data from a trial of counselling with chronically depressed patients in a general practice setting. Psychology and Psychotherapy: Theory, Research and Practice 2005; 78(1):127–138. | Focus on non-elderly adults
Cowen PJ, Ogilvie AD, Gama J. Efficacy, safety and tolerability of duloxetine 60 mg once daily in major depression. Current Medical Research & Opinion 2005; 21(3):345–356. | Focus on non-elderly adults
Coyne J, Palmer S, Sullivan P. Screening for Depression in Adults. Ann Intern Med 2003; 138(9):767–768. | Excluded study design
Croft H, Settle E Jr, Houser T, Batey SR, Donahue RM, Ascher JA. A placebo-controlled comparison of the antidepressant efficacy and effects on sexual functioning of sustained-release bupropion and sertraline. Clin Ther 1999; 21(4):643–658. | Does not repot included outcomes
Cuijpers P, van Lier PAC, van Straten A, Donker M. Examining differential effects of psychological treatment of depressive disorder: An application of trajectory analyses. Journal of Affective Disorders 2005; 89(1–3):137–146. | Focus on non-elderly adults
Cuijpers P. Psychological outreach programmes for the depressed elderly: a meta-analysis of effects and dropout. Int J Geriatr Psychiatry 1998; 13(1):41–48. | Intervention out of scope
De Lima MS, Hotoph M, Wessely S. The efficacy of drug treatments for dysthymia: a systematic review and meta-analysis. Psychol Med 1999; 29(6):1273–1289. | Exclusive focus on dysthymia
Delgado PL. Monoamine depletion studies: implications for antidepressant discontinuation syndrome. J Clin Psychiatry 2006; 67:Suppl-6. | Does not meet quality criteria
Detke MJ, Wiltse CG, Mallinckrodt CH, McNamara RK, Demitrack MA, Bitter I. Duloxetine in the acute and long-term treatment of major depressive disorder: a placebo- and paroxetine-controlled trial. European neuropsychopharmacology : the journal of the European College of Neuropsychopharmacology 2004;(6):457–470. | Focus on non-elderly adults
Dew MA, Reynolds CF, Mulsant B, Frank E, Houck PR, Mazumdar S, Begley A, Kupfer DJ. Initial recovery patterns may predict which maintenance therapies for depression will keep older adults well. Journal of affective disorders 2006;65(2):155–66. | Focus on non-elderly adults
Dobscha SK, Corson K, Hickam DH, Perrin NA, Kraemer DF, Gerrity MS. Depression decision support in primary care: a cluster randomized trial. Ann Intern Med 2006; 145(7):477–487. | Not one of included study designs for relevant key question
Dobscha SK, Gerrity MS, Corson K, Bahr A, Cuilwik NM. Measuring adherence to depression treatment guidelines in a VA primary care clinic. General Hospital Psychiatry 2003;25(4):230–7. | Not a screening intervention trial with usual care control group
Donovan S, Clayton A, Beeharry M, Jones S, Kirk C, Waters K et al. Deliberate self-harm and antidepressant drugs. Investigation of a possible link. Br.J.Psychiatry 2000;(177): 551–556. | Not one of included study designs for relevant key question
Dowrick C. Does testing for depression influence diagnosis or management by general practitioners? Fam Pract. 1995;12:461–465 | Does not report included outcomes
Dwight-Johnson M, Unutzer J, Sherbourne C, Tang L, Wells KB. Can quality improvement programs for depression in primary care address patient preferences for treatment? Medical Care 2001;39(9):934–44. | Does not report included outcomes
Einarson TR. Evidence based review of escitalopram in treating major depressive disorder in primary care. Int Clin Psychopharmacol 2004; 19(5):305–310. | Non-elderly treatment study
Entsuah AR, Huang H, Thase ME. Response and remission rates in different subpopulations with major depressive disorder administered venlafaxine, selective serotonin reuptake inhibitors, or placebo. J Clin Psychiatry 2001; 62(11):869–877. | Sparse data on treatment vs. placebo in older adults
Ernst CL, Goldberg JF. Antisuicide properties of psychotropic drugs: a critical review. Harv Rev Psychiatry 2004; 12(1):14–41. | Did not report on an included intervention
Fabian TJ, Amico JA, Kroboth PD, Mulsant BH, Reynolds CF, III, Pollock BG. Paroxetine-induced hyponatremia in the elderly due to the syndrome of inappropriate secretion of antidiuretic hormone (SIADH). Journal of Geriatric Psychiatry & Neurology 2003; 16(3):160–164. | Not one of included study designs for relevant key question
Fahey T, Sullivan F, MacGillivray S. Screening for depression in primary care. Study analysis and conclusions are flawed. Bmj. 2003;326(7396):982 | Not one of included study designs for relevant key question
Fava M, Amsterdam JD, Deltito JA, Salzman C, Schwaller M, Dunner DL. A double-blind study of paroxetine, fluoxetine, and placebo in outpatients with major depression. Ann Clin Psychiatry 1998; 10(4):145–150. | Not one of included study designs for relevant key question
Fava M, Hoog SL, Judge RA, Kopp JB, Nilsson ME, Gonzales JS. Acute efficacy of fluoxetine versus sertraline and paroxetine in major depressive disorder including effects of baseline insomnia. J Clin Psychopharmacol 2002; 22(2):137–147. | Non-elderly treatment study
Fava M, Judge R, Hoog SL, Nilsson ME, Koke SC. Fluoxetine versus sertraline and paroxetine in major depressive disorder: changes in weight with long-term treatment. J Clin Psychiatry 2000; 61(11):863–867. | Non-elderly treatment study
Fava M, Mallinckrodt CH, Detke MJ, Watkin JG, Wohlreich MM. The effect of duloxetine on painful physical symptoms in depressed patients: do improvements in these symptoms result in higher remission rates? J Clin Psychiatry 2004; 65(4):521–530. | Non-elderly treatment study
Fava M. Prospective studies of adverse events related to antidepressant discontinuation. J Clin Psychiatry 2006; 67:Suppl-21. | Not one of included study designs for relevant key question
Feighner JP, Gardner EA, Johnston JA, Batey SR, Khayrallah MA, Ascher JA et al. Double-blind comparison of bupropion and fluoxetine in depressed outpatients. J Clin Psychiatry 1991; 52(8):329–335. | Not one of included study designs for relevant key question
Ferguson JM, Shrivastava RK, Stahl SM, Hartford JT, Borian F, Ieni J et al. Reemergence of sexual dysfunction in patients with major depressive disorder: double-blind comparison of nefazodone and sertraline. Journal of Clinical Psychiatry 2001;62(1):24–9. | Not one of included study designs for relevant key question
Finkel SI, Richter EM, Clary CM. Comparative efficacy and safety of sertraline versus nortriptyline in major depression in patients 70 and older. International Psychogeriatrics 1999;11(1):85–99. | Comparative-effectiveness
Fishbain D. Evidence-based data on pain relief with antidepressants. Ann Med 2000; 32(5):305–316. | Non-elderly treatment study
Fraguas R, Jr., Gonsalves Henriques S Jr, De Lucia MS, Iosifescu DV, Schwartz FH, Rossi MP et al. The detection of depression in medical setting: A study with PRIME-MD. J Affect Disord 2006; 91(1):11–17. | Not a screening intervention trial with usual care control group
Frazer CJ, Christensen H, Griffiths KM. Effectiveness of treatments for depression in older people. Medical Journal of Australia 2005;182(12):627–32. | Does not meet quality criteria
Freudenstein U, Jagger C, Arthur A, Donner-Banzhoff N. Treatments for late life depression in primary care: a systematic review. Fam Pract 2001; 18(3):321–327. | Updated/covered by another more recent SER/MA
Friedman MA, Detweiler-Bedell JB, Leventhal HE, Horne R, Keitner G, Miller IW. Combined psychotherapy and pharmacotherapy for the treatment of major depressive disorder. Clinical Psychology: Science and Practice 2004; 11(1):47 | Non-elderly treatment study
Furukawa TA, McGuire H, Barbui C. Meta-analysis of effects and side effects of low dosage tricyclic antidepressants in depression: systematic review. BMJ 2002; 325:991–999. | Non-elderly treatment study
Gartlehner G, Hansen RA, Carey TS, Lohr KN, Gaynes BN, Randolph LC. Discontinuation rates for selective serotonin reuptake inhibitors and other second-generation antidepressants in outpatients with major depressive disorder: A systematic review and meta-analysis. Int.Clin.Psychopharmacol. 2005;20(2), 59–69. | Updated/covered by another more recent SER/MA
Gastpar M, Singer A, Zeller K. Comparative efficacy and safety of a once-daily dosage of hypericum extract STW3-VI and citalopram in patients with moderate depression: A double-blind, randomised, multicentre, placebo-controlled study. Pharmacopsychiatry 2006;39(2), 66–75. | Non-elderly treatment study
Gatz M, Fiske A, Fox LS, Kaskie B, Kasl-Godley JE, McCallum TJ et al. Empirically validated psychological treatments for older adults. Journal of Mental Health and Aging 1998; 4(1):9–46. | Not one of included study designs for relevant key question
Geddes JR, Carney SM, Davies C, Furukawa TA, Kupfer DJ, Frank E et al. Relapse prevention with antidepressant drug treatment in depressive disorders: a systematic review. Lancet 2003; 361(9358):653–661. | Depression prevention or treatment maintenance interventions
German PS, Shapiro S, Skinner EA et al. Detection and management of mental health problems of older patients by primary care providers. JAMA. 1987;257:489–493. | Does not report included outcomes
Gerson S, Belin TR, Kaufman A, Mintz J, Jarvik L. Pharmacological and psychological treatments for depressed older patients: a meta-analysis and overview of recent findings. Harv Rev Psychiatry 1999; 7(1):1–28. | Not one of included study designs for relevant key question
Ghazi-Noori S, Chung TH, Deane KHO, Rickards H, Clarke CE. Therapies for Depression in Parkinson’s Disease. Cochrane Database of Systematic Reviews 2005;(3). | Not a general primary care population
Gilbody S, House AO, Sheldon TA. Screening and case finding instruments for depression. Cochrane Database of Systematic Reviews 2005;(4):CD002792. | Not one of included study designs for relevant key question
Gilbody S, Whitty P, Grimshaw J, Thomas R. Educational and organisational interventions to improve the management of depression in primary care. JAMA 2003; 289(23):3145–3151. | Not one of included study designs for relevant key question
Gilbody SM, House AO, Sheldon TA. Routinely administered questionnaires for depression and anxiety: systematic review. BMJ 2001; 322(7283):406–409. | Not one of included study designs for relevant key question
Gill D, Hatcher S. A systematic review of the treatment of depression with antidepressant drugs in patients who also have a physical illness. J Psychosom Res 1999; 47(2):131–143. | Not a general primary care population
Gill D, Hatcher S. Antidepressants for depression in medical illness. Cochrane Database of Systematic Reviews 2000;(4):CD001312. | Not a general primary care population
Gill D. Prescribing antidepressants in general practice: Systematic review of all pertinent trials is required to establish guidelines. BMJ March 15, 1997; 314(7083):826–827. | Not one of included study designs for relevant key question
Glassman AH, O’Connor CM, Califf RM, Swedberg K, Schwartz P, Bigger JT, Jr. et al. Sertraline treatment of major depression in patients with acute MI or unstable angina. JAMA 2002; 288(6):701–709. | Not a general primary care population
Gloaguen V, Cottraux J, Cucherat M, Blackburn IM. A meta-analysis of the effects of cognitive therapy in depressed patients. J Affect Disord 1998; 49(1):59 | Non-elderly treatment study
Goldberg D, Privett M, Ustun B, Simon G, Linden M. The effects of detection and treatment on the outcome of major depression in primary care: a naturalistic study in 15 cities. Br J Gen Pract 1998; 48(437):1840–1844. | Not a screening intervention trial with usual care control group
Goldberg D. The “NICE Guideline” on the treatment of depression. Epidemiol Psichiatr Soc 2006; 15(1):11–15. | Not one of included study designs for relevant key question
Goldberg HI, Wagner EH, Fihn SD, Martin DP, Horowitz CR, Christensen DB et al. A randomized controlled trial of CQI teams and academic detailing: can they alter compliance with guidelines? Joint Commission Journal on Quality Improvement 1998;24(3):130–42. | Not a general primary care population
Goldstein DJ LY. Duloxetine in the treatment of depression: a double-blind placebo-controlled comparison with paroxetine. J Clin Psychopharmacol 2004;(4):389–399. | Non-elderly treatment study
Grotzinger KM CB. Clinical outcomes after depression: improvement in clinical and economic outcomes after implementing a disease management program for patients with depression. 51st Institute on Psychiatric Services; 1999; 1999 October 25th–November 2nd; New Orleans, LA, USA 1999.:-November. | Not a general primary care population
Grunebaum MF, Ellis SP, Li S, Oquendo MA, Mann JJ. Antidepressants and suicide risk in the United States, 1985–1999. J Clin Psychiatry 2004; 65(11):1456–1462. | Not one of included study designs for relevant key question
Gunnell D, Ashby D. Antidepressants and suicide: what is the balance of benefit and harm. BMJ 2004; 329(7456):34–38. | Not one of included study designs for relevant key question
Guthrie E K. Randomised controlled trial of brief psychological intervention after deliberate self poisoning. BMJ (Clinical research ed) 2001;323(7305):135–8. | Not a primary care population
Haby MM, Donnelly M, Corry J, Vos T. Cognitive behavioural therapy for depression, panic disorder and generalized anxiety disorder: a meta-regression of factors that may predict outcome. Australian & New Zealand Journal of Psychiatry 2006;40(1):9–19. | Non-elderly treatment study
Hackett ML, Anderson CS, House AO. Management of depression after stroke: a systematic review of pharmacological therapies. Stroke 2005;36(5):1098–103. | Not a general primary care population
Hall WD, Lucke J. How have the selective serotonin reuptake inhibitor antidepressants affected suicide mortality? Australian & New Zealand Journal of Psychiatry 2006; 40(11–12):941–950. | Does not meet quality criteria
Hansen RA, Gartlehner G, Lohr KN, Gaynes BN, Carey TS. Efficacy and safety of second-generation antidepressants in the treatment of major depressive disorder. Ann Intern Med 2005; 143(6):415–426. | Focus on treatment comparison, matching, or fine-tuning
Hayes D. Recent developments in antidepressant therapy in special populations. Am J Manag Care 2004; 10(6:Suppl):Suppl-85. | Not a treatment outcomes study
Healey D. Lines of evidence on the risk of suicide with selective serotonin reuptake inhibitors: Reply. Psychother. Psychosom. 2003;72(6), 359–360. | Not one of included study designs for relevant key question
Healy D, Whitaker C. Antidepressants and suicide: risk-benefit conundrums. J Psychiatry Neurosci 2003; 28(5):331–337. | Not one of included study designs for relevant key question
Healy D. Lines of evidence on the risks of suicide with selective serotonin reuptake inhibitors. Psychother Psychosom 2003; 72(2):71–79. | Not one of included study designs for relevant key question
Henkel V, Mergl R, Coyne JC, Kohnen R, Moller HJ, Hegerl U. Screening for depression in primary care: will one or two items suffice? Eur Arch Psychiatry Clin Neurosci. 2004;254:215–223. | Does not report included outcomes
Hensley PL, Nadiga D, Uhlenhuth EH. Long-term effectiveness of cognitive therapy in major depressive disorder. Depress Anxiety 2004; 20(1):1–7. | Non-elderly treatment study
Hickie IB, Davenport TA, Ricci CS. Screening for depression in general practice and related medical settings. Med J Aust 2002; 177 Suppl:S111–S116. | Not one of included study designs for relevant key question
Hicks JA, Argyropoulos SV, Rich AS, Nash JR, Bell CJ, Edwards C et al. Randomised controlled study of sleep after nefazodone or paroxetine treatment in out-patients with depression. Br J Psychiatry2002; 180:528–535. | Non-elderly treatment study
Himei A, Okamura T. Discontinuation syndrome associated with paroxetine in depressed patients: a retrospective analysis of factors involved in the occurrence of the syndrome. CNS Drugs 2006; 20(8):665–672. | Does not report included outcomes
Hippisley-Cox J, Pringle M, Hammersley V, Crown N, Wynn A, Meal A et al. Antidepressants as risk factor for ischaemic heart disease: case-control study in primary care. BMJ 2001; 323(7314):666–669. | Does not meet quality criteria
Hoeper EW, Nycz GR, Kessler LG, Burke JD, Jr., Pierce WE. The usefulness of screening for mental illness. Lancet. 1984;1:33–3 | Does not report included outcomes
Hsieh HF, Wang JJ. Effect of reminiscence therapy on depression in older adults: a systematic review. Int J Nurs Stud 2003; 40(4):335 | Not one of included study designs for relevant key question
Hudson JI, Wohlreich MM, Kajdasz DK, Mallinckrodt CH, Watkin JG, Martynov OV. Safety and tolerability of duloxetine in the treatment of major depressive disorder: analysis of pooled data from eight placebo-controlled clinical trials. Human psychopharmacology 2005; 20(5):327–341. | Updated/covered by another more recent SER/MA
Huibers MJH, Beurskens AJHM, Bleijenberg G, van Schayck CP. The effectiveness of psychosocial interventions delivered by general practitioners. Cochrane Database of Systematic Reviews 2005;(3):223. | Non-elderly treatment study
Hunkeler EM, Katon W, Tang L, Williams JW, Jr., Kroenke K, Lin EH et al. Long term outcomes from the IMPACT randomised trial for depressed elderly patients in primary care. BMJ 2006; 332(7536):259–263. | Intervention out of scope
Hunziker ME, Suehs BT, Bettinger TL, Crismon ML. Duloxetine hydrochloride: a new dual-acting medication for the treatment of major depressive disorder. Clin Ther 2005; 27(8):1126–1143. | Does not address included adverse effects
Isacsson G, Holmgren P, Ahlner J. Selective serotonin reuptake inhibitor antidepressants and the risk of suicide: a controlled forensic database study of 14,857 suicides. Acta Psychiatr Scand 2005; 111(4):286–290. | Excluded for quality; high likelihood of confounding by indication.
Jarrett RB, Basco MR, Risser R, Ramanan J, Marwill M, Kraft D et al. Is there a role for continuation phase cognitive therapy for depressed outpatients? Journal of Consulting & Clinical Psychology 1998;66(6):1036–40. | Non-elderly treatment study
Jarvik LF, Mintz J, Steuer J, Gerner R. Treating geriatric depression: a 26-week interim analysis. J Am Geriatr Soc 1982; 30(11):713–717. | Not one of included study designs for relevant key question
Jimenez-Jimenez FJ, Molina JA. Extrapyramidal symptoms associated with selective serotonin reuptake inhibitors: Epidemiology, mechanisms and management. CNS Drugs 2000;14(5), 367–379. | Not one of included study designs for relevant key question
Johnstone A, Goldberg D. Psychiatric screening in general practice. A controlled trial. Lancet. 1976;1:605–608. | Missing both depression-specific screener and depression-specific outcome
Juurlink DN, Mamdani MM, Kopp A, Redelmeier DA. The risk of suicide with selective serotonin reuptake inhibitors in the elderly. Am J Psychiatry 2006; 163(5):813–821. | Not one of included study designs for relevant key question
Karel MJ, Hinrichsen G. Treatment of depression in late life: psychotherapeutic interventions. Clin Psychol Rev 2000; 20(6):707–729. | Used as source document only
Kasper S, de SH, Friis AH. Escitalopram in the treatment of depressed elderly patients. Am J Geriatr Psychiatry 2005; 13(10):884–891. | Not one of included study designs for relevant key question
Katon W, Von Korff M, Lin E, Simon G, Walker E, Unutzer J et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: a randomized trial. Arch Gen Psychiatry 1999; 56(12):1109–1115. | Not a general primary care population
Katona C, Livingston G. How well do antidepressants work in older people: a systematic review of number needed to treat. J Affect Disord 2002; 69(1–3):47 | Updated/covered by another more recent SER/MA
Katzelnick DJ, Simon GE, Pearson SD, Manning WG, Helstad CP, HH et al. Randomized trial of a depression management program in high utilizers of medical care. Archives of Family Medicine 2000;9(4): 345–51. | Not a general primary care population
Katzelnick DJ, Simon GE, Pearson SD, Manning WG, Helstad CP, Henks, HJ. Clinical outcomes care study. 152nd Annual Meeting of the American Psychiatric Association; Washington DC, USA; 1999. | Not a general primary care population
Kaye JL. Target complaints as a measure of outcome in psychotherapy with the depressed elderly. Dissertation Abstracts International: Section B: The Sciences and Engineering 2001; 62(5-B):2488. | Focus on treatment comparison, matching, or fine-tuning
Keller M. Lack of efficacy of the substance p (neurokinin1 receptor) antagonist aprepitant in the treatment of major depressive disorder. Biol Psychiatry 2006;(3):216–223. | Non-elderly treatment study
Kendrick T, Stevens L, Bryant A, Goddard J, Stevens A, Raftery J et al. Hampshire depression project: changes in the process of care and cost consequences. Br J Gen Pract 2001; 51(472):911–913. | Not a screening intervention trial with usual care control group
Kennedy GJ. New drugs for old folks: the evidence-based argument for newer antidepressants. J Am Geriatr Soc 2001; 49(2):227–228. | Focus on treatment comparison, matching or fine-tuning
Kessler D, Bennewith O, Lewis G, Sharp D. Detection of depression and anxiety in primary care: follow up study. BMJ2002;325(7371):1016–7. | Not one of included study designs for relevant key question
Kessler D, Lloyd K, Lewis G, Gray DP. Cross sectional study of symptom attribution and recognition of depression and anxiety in primary care. BMJ 1999; 318(7181):436–439. | Does not meet inclusion criteria
Khan A, Brodhead AE, Schwartz KA, Kolts RL, Brown WA. Sex differences in antidepressant response in recent antidepressant clinical trials. J Clin Psychopharmacol 2005; 25(4):318–324. | Non-elderly treatment study
Khan A, Warner HA, Brown WA. Symptom reduction and suicide risk in patients treated with placebo in antidepressant clinical trials: an analysis of the Food and Drug Administration database. Arch Gen Psychiatry 2000; 57(4):311–317. | Updated/covered by another more recent SER/MA
Khan A. Severity of depressive symptoms and response to antidepressants and placebo in antidepressant trials. J Psychiatr Res 2005;39(2):145–150. | Non-elderly treatment study
Kiev A, Feiger A. A double-blind comparison of fluvoxamine and paroxetine in the treatment of depressed outpatients. J Clin Psychiatry 1997; 58(4):146–152. | Comparative-effectiveness
Kirsch I, Scoboria A. Apples, oranges, and placebos: heterogeneity in a meta-analysis of placebo effects. Advances in Mind-Body Medicine2004; 17(4):307–9; discussion 312–8. | Does not report included outcomes
Klausner EJ, Snyder CR, Cheavens J. A hope-based group treatment for depressed older adult outpatients. 2000. | Not a general primary care population
Klein DN, Santiago NJ, Vivian D, Blalock JA, Kocsis JH, Markowitz JC et al. Cognitive-behavioral analysis system of psychotherapy as a maintenance treatment for chronic depression. Journal of Consulting& Clinical Psychology 2004;72(4):681–8. | Non-elderly treatment study
Koren G, Matsui D, Einarson A, Knoppert D, Steiner M. Is maternal use of selective serotonin reuptake inhibitors in the third trimester of pregnancy harmful to neonates? CMAJ 2005; 172(11):1457–1459. | Focus on pregnancy-related screening
Krampen G. Long-term evaluation of the effectiveness of additional autogenic training in the psychotherapy of depressive disorders. European Psychologist 1999; 4(1):11–18. | Non-elderly treatment study
Krishnan KR, Doraiswamy PM, Clary CM. Clinical and treatment response characteristics of late-life depression associated with vascular disease: a pooled analysis of two multicenter trials with sertraline. Prog Neuropsychopharmacol Biol Psychiatry 2001; 25(2):347–361. | Not a general primary care population
Kurdyak PA, Juurlink DN, Kopp A, Herrmann N, Mamdani MM. Antidepressants, warfarin, and the risk of hemorrhage. J Clin Psychopharmacol. 2005;25:561–564. | Not a primary care population
Lane DA, Chong AY, Lip GYH. Psychological interventions for depression in heart failure. Cochrane Database of Systematic Reviews 2005;(3). | Not a general primary care population
Lapierre YD. Suicidality with selective serotonin reuptake inhibitors: Valid claim?. Journal of Psychiatry & Neuroscience 2003; 28(5):340–347. | Not one of included study designs for relevant key question
Lejoyeux M, Ades J. Antidepressant discontinuation: a review of the literature. J Clin Psychiatry 1997; 58:Suppl-5. | Not one of included study designs for relevant key question
Lenze EJ, Dew MA, Mazumdar S, Begley AE, Cornes C, Miller MD et al. Combined pharmacotherapy and psychotherapy as maintenance treatment for late-life depression: effects on social adjustment. American Journal of Psychiatry 2002;159(3):466–8. | Depression prevention or treatment maintenance interventions
Lepola UM LH. Escitalopram (10–20 mg/day) is effective and well tolerated in a placebo-controlled study in depression in primary care. Int Clin Psychopharmacol 2003;(4):211–217. | Non-elderly treatment study
Levkovitz Y, Shahar G, Native G, Hirsfeld E, Treves I, Krieger I et al. Group interpersonal psychotherapy for patients with major depression disorder - pilot study. Journal of Affective Disorders 2000;60(3):191–5. | Non-elderly treatment study
Lewis G, Sharp D, Bartholomew J, Pelosi AJ. Computerized assessment of common mental disorders in primary care: effect on clinical outcome. Fam Pract. 1996;13:120–126. | Missing both depression-specific screener and depression-specific outcomes
Lexchin J, Bero LA, Djulbegovic B, Clark O. Pharmaceutical industry sponsorship and research outcome and quality: systematic review. BMJ 2003; 326(7400):1167–1170. | Does not report included outcomes
Lima MS, Hotopf M. Pharmacotherapy for dysthymia. Cochrane Database of Systematic Reviews 2005;(3). | Exclusive focus on dysthymia
Lima MS, Moncrieff J. Drugs versus placebo for dysthymia. Cochrane Database of Systematic Reviews 2005;(3). | Exclusive focus on dysthymia
Lin EH, VonKorff M, Russo J, Katon W, Simon GE, Unutzer J et al. Can depression treatment in primary care reduce disability? A stepped care approach. Arch Fam Med 2000; 9(10):1052–1058. | Not a general primary care population
Lin YC, Dai YT, Hwang SL. The effect of reminiscence on the elderly population: a systematic review. Public Health Nurs 2003; 20(4):297–306. | Not one of included study designs for relevant key question
Linn LS, Yager J. The effect of screening, sensitization, and feedback on notation of depression. J Med Educ. 1980;55:942–949. | Does not report included outcomes
Lip GYH, Lane DA, Millane TA. Psychological interventions for depression in adolescent and adult congenital heart disease. Cochrane Database of Systematic Reviews 2005;(3). | Not a general primary care population
Looper KJ. Potential medical and surgical complications of serotonergic antidepressant medications. Psychosomatics. 2007;48:1–9. | Not one of included study design for relevant key question
Lowe B, Kroenke K, Grafe K. Detecting and monitoring depression with a two-item questionnaire (PHQ-2). Journal of Psychosomatic Research 2005;58(2):163–71. | Not a screening intervention trial with usual care control group
Mackay FR, Dunn NR, Martin RM, Pearce GL, Freemantle SN, Mann RD. Newer antidepressants: a comparison of tolerability in general practice. Br J Gen Pract 1999; 49(448):892–896. | Does not meet design-specific criteria
Magruder-Habib K, Zung WW, Feussner JR. Improving physicians’ recognition and treatment of depression in general medical care. Results from a randomized clinical trial. Med Care. 1990;28:239–250. | Does not report included outcomes
Malt UF, Robak OH, Madsbu HP, Bakke O, Loeb M. The Norwegian naturalistic treatment study of depression in general practice (NORDEP)-I: randomised double blind study. BMJ 1999;318(7192):1180–4. | Non-elderly treatment study
Mann AH BR. An evaluation of practice nurses working with general practitioners to treat people with depression. British Journal of General Practice 1998;48(426):875–879. | Not a general primary care population
Mastel-Smith BA, McFarlane J, Sierpina M, Malecha A, Haile B. Improving depressive symptoms in community-dwelling older adults: a psychosocial intervention using life review and writing. J Gerontol Nurs. 2007;33:13–19. | Not one of included study design for relevant key question
McCrone P, Knapp M, Proudfoot J, Ryden C, Cavanagh K, Shapiro DA et al. Cost-effectiveness of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. British Journal of Psychiatry 2004;185:55–62. | Non-elderly treatment study
McDermut W, Miller IW, Brown RA. The efficacy of group psychotherapy for depression: a meta-analysis and review of the empirical research. Clinical Psychology: Science and Practice 2001; 8(1):98. | Non-elderly treatment study
Means-Christensen AJ, Arnau RC, Tonidandel AM, Bramson R, Meagher MW. An efficient method of identifying major depression and panic disorder in primary care. Journal of Behavioral Medicine 2005;28(6):565–72. | Not a screening intervention trial with usual care control group
Meijer WE, Heerdink ER, van Eijk JT, Leufkens HG. Adverse events in users of sertraline: results from an observational study in psychiatric practice in The Netherlands. Pharmacoepidemiol Drug Saf 2002; 11(8):655–662. | Comparative-effectiveness
Melander H, Ahlqvist-Rastad J, Meijer G, Beermann B. Evidence b(i)ased medicine--selective reporting from studies sponsored by pharmaceutical industry: review of studies in new drug applications. BMJ 2003; 326(7400):1171–1173. | Does not report included outcomes
Meyers, Burnett S. Optimizing the use of data generated by geriatric depression treatment studies during a time of diminishing resources. American Journal of Geriatric Psychiatry 15[7], 545–552. 2007. | Not a relevant outcome
Milane MS, Suchard MA, Wong ML, Licinio J. Modeling of the temporal patterns of fluoxetine prescriptions and suicide rates in the United States. PLoS Medicine/Public Library of Science 2006; 3(6):e190. | Not one of included study designs for relevant key question
Miser WF. Treating depression in older ambulatory patients. J Fam Pract 1998; 47(1):16–17. | Not one of included study designs for relevant key question
Mitchell AJ, Subramaniam H. Prognosis of depression in old age compared to middle age: a systematic review of comparative studies. Am J Psychiatry 2005; 162(9):1588–1601. | Comparing subgroups rather than treatment vs. control
Moncrieff J, Wessely S, Hardy R. Active placebos versus antidepressants for depression. Cochrane Database of Systematic Reviews 2005;(3):223. | Non-elderly treatment study
Moncrieff J, Wessely S, Hardy R. Meta-analysis of trials comparing antidepressants with active placebos. Br J Psychiatry 1998; 172(3):227–231. | Non-elderly treatment study
Moore AA, Siu A, Partridge JM, Hays RD, Adams J. A randomized trial of office-based screening for common problems in older persons. American Journal of Medicine 1997;102(4):371–8. | Missing both depression-specific screener and depression-specific outcome
Moore JT, Silimperi DR, Bobula JA. Recognition of depression by family medicine residents: the impact of screening. J Fam Pract. 1978;7:509–513. | Does not report included outcomes
Moreno RA, Teng CT, Almeida KM, Tavares JH. Hypericum perforatum versus fluoxetine in the treatment of mild to moderate depression: a randomized double-blind trial in a Brazilian sample. Revista Brasileira de Psiquiatria 2006; 28(1):29–32. | Non-elderly treatment study
Mottram P, Wilson K, Strobl J. Antidepressants for depressed elderly. Cochrane Database of Systematic Reviews 2006;(1):CD003491. | Focus on treatment comparison, matching, or fine-tuning
Mulsan BH SHS. Major depression in older primary care patients conference abstract. 11th Annual Meeting of the American Association for Geriatric Psychiatry 1998; San Diego, California, USA. 8th–11th March,. 1998. | Not one of included study designs for relevant key question
Mutch C, Tobin M, Hickie I, Davenport T, Burke D. Improving community-based services for older patients with depression: the benefits of an educational and service initiative. Aust N Z J Psychiatry 2001; 35(4):449–454. | Not one of included study designs for relevant key question
Nease DE, Jr., Maloin JM. Depression screening: a practical strategy. Journal of Family Practice 2003;52(2):118–24. | Not a screening intervention trial with usual care control group
Nease DE, Klinkman MS, Volk RJ. Improved detection of depression in primary care through severity evaluation. Journal of Family Practice 51(12):1065–70, 2002. | Not a screening intervention trial with usual care control group
Nelson JC, Wohlreich MM, Mallinckrodt CH, Detke MJ, Watkin JG, Kennedy JS. Duloxetine for the treatment of major depressive disorder in older patients. Am J Geriatr Psychiatry 2005; 13(3):227–235. | Not one of included study designs for relevant key question
Neumeyer-Gromen A, Lampert T, Stark K, Kallischnigg G. Disease management programs for depression: a systematic review and meta-analysis of randomized controlled trials. Med Care 2004; 42(12):1211 | Not a screening intervention trial with usual care control group
Newhouse PA, Krishnan KR, Doraiswamy PM, Richter EM, Batzar ED, Clary CM. A double-blind comparison of sertraline and fluoxetine in depressed elderly outpatients. Journal of Clinical Psychiatry 2000;61(8):559–68. | Focus on treatment comparison, matching, or fine-tuning
Ning J. Observation of the clinical efficacy and safety of mirtazapine on elder depression treatment. Clnical Pharmaceuticals. 2004;13:63–64. | Not one of included study design for relevant key question
Nunes E, V, Levin FR. Treatment of depression in patients with alcohol or other drug dependence: a meta-analysis. JAMA 2004; 291(15):1887–1896. | Not a general primary care population
Nutting PA, Dickinson LM, Rubenstein LV, Keeley RD, Smith JL, Elliott CE. Improving detection of suicidal ideation among depressed patients in primary care. Annals of Family Medicine 2005;3(6):529–36. | Not a screening intervention trial with usual care control group
Ong PS. Late-life depression: current issues and new challenges. Ann Acad Med Singapore 2003; 32(6):764–770. | Not one of included study designs for relevant key question
Oslin DW THTSJDCW. Probing the safety of medications in the frail elderly: evidence from a randomized clinical trial of sertraline and venlafaxine in depressed nursing home residents. The Journal of clinical psychiatry 2003;(8):875–882. | Focus on treatment comparison, matching, or fine-tuning
Oslin DW, Sayers S, Ross J, Kane V, Ten Have T, Conigliaro J et al. Disease management for depression and at-risk drinking via telephone in an older population of veterans. Psychosomatic Medicine 65(6):931 –7, 2003;-Dec. | Comparative-effectiveness
Palmer SC, Coyne JC. Screening for depression in medical care: pitfalls, alternatives, and revised priorities. J Psychosom Res 2003; 54(4):279–287. | Not one of included study designs for relevant key question
Pampallona S, Bollini P, Tibaldi G, Kupelnick B, Munizza C. Combined pharmacotherapy and psychological treatment for depression: a systematic review. Arch Gen Psychiatry 2004; 61(7):714–719. | Focus on treatment comparison, matching, or fine-tuning
Papakostas GI, Petersen T, Denninger JW, Montoya HD, Nierenberg AA, Alpert JE et al. Treatment-related adverse events and outcome in a clinical trial of fluoxetine for major depressive disorder. Ann Clin Psychiatry 2003; 15(3–4):187–192. | Not one of included study designs for relevant key question
Patten S, Cipriani A, Brambilla P, Nose M, Barbui C. International dosage differences in fluoxetine clinical trials. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie 2005; 50(1):31–38. | Not one of included study designs for relevant key question
Pedersen AG. Escitalopram and suicidality in adult depression and anxiety. Int Clin Psychopharmacol 2005; 20(3):139–143. | Updated/covered by another more recent SER/MA
Perahia DG, Kajdasz DK, Walker DJ, Raskin J, Tylee A. Duloxetine 60 mg once daily in the treatment of milder major depressive disorder. Int J Clin Pract 2006; 60(5):613–620. | Non-elderly treatment study
Pesola GR, Avasarala J. Bupropion seizure proportion among new-onset generalized seizures and drug related seizures presenting to an emergency department. Journal of Emergency Medicine 2002;22(3):235–9. | Not one of included study designs for relevant key question
Pignone M, Gaynes B, Lohr K, Rushton JL, Mulrow C. Screening for Depression in Adults. Ann Intern Med 2003; 138(9):767–768. | Used as source document only
Pignone MP, Gaynes BN, Rushton JL, Burchell CM, Orleans CT, Mulrow CD et al. Screening for depression in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med 2002; 136(10):765–776. | Used as source document only
Pirraglia PA, Rosen AB, Hermann RC, Olchanski NV, Neumann P. Cost-utility analysis studies of depression management: a systematic review. Am J Psychiatry 2004; 161(12):2155–2162. | Does not report included outcomes
Plummer WP. Screening for depression in primary care. Scientific and statistical errors should have been picked up in peer review. BMJ. 2003;326(7396):982. | Not one of included study designs for relevant key question
Posternak MA, Miller I. Untreated short-term course of major depression: a meta-analysis of outcomes from studies using wait-list control groups. J Affect Disord 2001; 66(2–3):139–146. | Non-elderly treatment study
Proudfoot J, Goldberg D, Mann A, Everitt B, Marks I, Gray JA. Computerized, interactive, multimedia cognitive-behavioural program for anxiety and depression in general practice. Psychological Medicine 2003; 33(2):217–227. | Non-elderly treatment study
Proudfoot J, Ryden C, Everitt B, Shapiro DA, Goldberg D, Mann A et al. Clinical efficacy of computerised cognitive-behavioural therapy for anxiety and depression in primary care: randomised controlled trial. British Journal of Psychiatry 2004;185:46–54. | Non-elderly treatment study
Rapaport MH, Schneider LS, Dunner DL, Davies JT, Pitts CD. Efficacy of controlled-release paroxetine in the treatment of late-life depression. J Clin Psychiatry 2003; 64(9):1065–1074. | Not one of included study designs for relevant key question
Reifler DR, Kessler HS, Bernhard EJ, Leon AC, Martin GJ. Impact of screening for mental health concerns on health service utilization and functional status in primary care patients. Arch Intern Med. 1996;156:2593–2599. | Missing both depression-specific screener and depression-specific outcome
Reimherr FW, Strong RE, Marchant BK, Hedges DW, Wender PH. Factors affecting return of symptoms 1 year after treatment in a 62- week controlled study of fluoxetine in major depression. J Clin Psychiatry 2001; 62 Suppl 22:16–23. | Not one of included study designs for relevant key question
Reith D, Fountain J, Tilyard M, McDowell R. Antidepressant poisoning deaths in New Zealand for 2001. N Z Med J 2003; 116(1184):U646. | Does not report included outcomes
Reynolds CF, III, Dew MA, Pollock BG, Mulsant BH, Frank E, Miller MD et al. Maintenance treatment of major depression in old age. N Engl J Med 2006; 354(11):1130–1138. | Depression prevention or treatment maintenance interventions
Reynolds CF, III, Frank E, Dew MA, Houck PR, Miller M, Mazumdar S et al. Treatment of 70(+)-year-olds with recurrent major depression. Excellent short-term but brittle long-term response. American Journal of Geriatric Psychiatry 1999;7(1):64–9. | Depression prevention or treatment maintenance interventions
Reynolds CF, III, Frank E, Perel JM, Imber SD, Cornes C, Miller MD et al. Nortriptyline and interpersonal psychotherapy as maintenance therapies for recurrent major depression: a randomized controlled trial in patients older than 59 years. JAMA 1999;281(1):39–45. | Depression prevention or treatment maintenance interventions
Reynolds CF, III. Paroxetine treatment of depression in late life. Psychopharmacol Bull 2003; 37:Suppl-34. | Not one of included study designs for relevant key question
Richards A, Barkham M, Cahill J, Richards D, Williams C, Heywood P. PHASE: a randomised, controlled trial of supervised self-help cognitive behavioural therapy in primary care. British Journal of General Practice 2003;53(495):764–70. | Non-elderly treatment study
Rihmer Z, Akiskal H. Do antidepressants t(h)reat(en) depressives? Toward a clinically judicious formulation of the antidepressant- suicidality FDA advisory in light of declining national suicide statistics from many countries. J Affect Disord 2006; 94(1–3):3–13. | Not one of included study designs for relevant key question
Rokke PD TJJ. Self-management therapy and educational group therapy for depressed elders. Cognitive Therapy & Research 2000;24(1):99–119. | Not one of included study designs for relevant key question
Rokke PD, Tomhave JA, Jocic Z. The role of client choice and target selection in self-management therapy for depression in older adults. Psychol Aging 1999; 14(1):155–169. | Not one of included study designs for relevant key question
Rollman BL, Hanusa BH, Gilbert T, Lowe HJ, Kapoor WN, Schulberg HC. The electronic medical record. A randomized trial of its impact on primary care physicians’ initial management of major depression. Arch Intern Med 2001; 161(2):189–197. | Screen not used in care of patient
Rollman BL, Hanusa BH, Lowe HJ, Gilbert T, Kapoor WN, Schulberg HC. A randomized trial using computerized decision support to improve treatment of major depression in primary care. J Gen Intern Med 2002; 17(7):493–503. | Screen not used in care of patient
Roose SP, Sackeim HA, Krishnan KR, Pollock BG, Alexopoulos G, Lavretsky H et al. Antidepressant pharmacotherapy in the treatment of depression in the very old: a randomized, placebo-controlled trial. Am J Psychiatry 2004; 161(11):2050–2059. | Not one of included study designs for relevant key question
Roose SP, Sackeim HA. Antidepressant medication for the treatment of late-life depression. In: Roose SP, Sackeim HA, eds. Late-life depression. New York, NY: Oxford University Press; 2004:192–202. | Not one of included study designs for relevant key question
Roose SP, Schatzberg AF. The Efficacy of Antidepressants in the Treatment of Late-Life Depression. J.Clin.Psychopharmacol. 2005;25(4, Suppl1), S1–S7. | Not one of included study designs for relevant key question
Rosenthal MZ, Cheavens JS, Compton JS, Thorp SR, Lynch TR. Thought suppression and treatment outcome in late-life depression. Aging & Mental Health 2005;9(1):35–9. | Focus on treatment comparison, matching, or fine-tuning
Rossini D, Serretti A, Franchini L, Mandelli L, Smeraldi E, De RD et al. Sertraline versus fluvoxamine in the treatment of elderly patients with major depression: a double-blind, randomized trial. J Clin Psychopharmacol 2005; 25(5):471–475. | Not one of included study designs for relevant key question
Rost K, Pyne JM, Dickinson LM, LoSasso AT. Cost-Effectiveness of Enhancing Primary Care Depression Management on an Ongoing Basis. Annals of Family Medicine 2005; 3(1):7–14. | Does not report included outcomes
Sabate E. Depression in Young People and the Elderly. 10-7-2004. World Health Organization. Priority Medicines for Europe and the World. | Not one of included study designs for relevant key question
Sauer H, Huppertz-Helmhold S, Dierkes W. Efficacy and safety of venlafaxine ER vs. amitriptyline ER in patients with major depression of moderate severity. Pharmacopsychiatry 2003; 36(5):169–175. | Not one of included study designs for relevant key question
Schade CP, Jones ER, Jr., Wittlin BJ. A ten-year review of the validity and clinical utility of depression screening. Psychiatr Serv 1998; 49(1):55–61. | Years covered precede 1999
Schatzberg A, Roose S. A double-blind, placebo-controlled study of venlafaxine and fluoxetine in geriatric outpatients with major depression. Am J Geriatr Psychiatry 2006; 14(4):361–370. | Not one of included study designs for relevant key question
Schatzberg AF, Kremer C, Rodrigues HE, Murphy GM, Jr. Double-blind, randomized comparison of mirtazapine and paroxetine in elderly depressed patients. Am J Geriatr Psychiatry 2002; 10(5):541–550. | Focus on treatment comparison, matching, or fine-tuning
Schatzberg AF. Efficacy and tolerability of duloxetine, a novel dual reuptake inhibitor, in the treatment of major depressive disorder. J Clin Psychiatry 2003; 64:Suppl-7. | Non-elderly treatment study
Schneider LS, Nelson JC, Clary CM, Newhouse P, Krishnan KR, Shiovitz T et al. An 8-week multicenter, parallel-group, double-blind, placebo-controlled study of sertraline in elderly outpatients with major depression. Am J Psychiatry 2003; 160(7):1277–1285. | Not one of included study designs for relevant key question
Schoenbaum M, Unutzer J, Sherbourne C, Duan N, Rubenstein LV, Miranda J et al. Cost-effectiveness of practice-initiated quality improvement for depression: results of a randomized controlled trial. JAMA 2001;286(11):1325–30. | Does not report included outcomes
Schone W, Ludwig M. A double-blind study of paroxetine compared with fluoxetine in geriatric patients with major depression. J Clin Psychopharmacol 1993; 13(6 Suppl 2):34S–39S. | Not one of included study designs for relevant key question
Schultz CL. The effect of cognitive group therapy in the treatment of depression among residents of senior communities. - Dissertation Abstracts International: Section B: The Sciences and Engineering 1996; 56(9-B):5183. | Not one of included study designs for relevant key question
Scogin F, Hamblin D, Beutler L. Bibliotherapy for depressed older adults: a self-help alternative. Gerontologist 1987; 27(3):383–387. | Not one of included study designs for relevant key question
Scogin F, Jamison C, Gochneaur K. Comparative efficacy of cognitive and behavioral bibliotherapy for mildly and moderately depressed older adults. J Consult Clin Psychol 1989; 57(3):403–407. | Does not meet quality criteria, including follow-up of less than six weeks
Segraves RT, Kavoussi R, Hughes AR, Batey SR, Johnston JA, Donahue R et al. Evaluation of sexual functioning in depressed outpatients: a double-blind comparison of sustained-release bupropion and sertraline treatment. J Clin Psychopharmacol 2000; 20(2):122–128. | Does not report included outcomes
Serby M, Yu M. Overview: depression in the elderly. Mt Sinai J Med 2003; 70(1):38–44. | Not one of included study designs for relevant key question
Sheffield RE, Lo Sasso AT, Young CH, Way K. Selective serotonin reuptake inhibitor usage patterns as risk factors for hospitalization. Administration & Policy in Mental Health 2002; 30(2):121–139. | Does not report included outcomes
Sheikh JI, Cassidy EL, Doraiswamy PM, Salomon RM, Hornig M, Holland PJ et al. Efficacy, safety, and tolerability of sertraline in patients with late-life depression and comorbid medical illness. J Am Geriatr Soc 2004; 52(1):86–92. | Not one of included study designs for relevant key question
Simon GE, VonKorff M, Heiligenstein JH, Revicki DA, Grothaus L, Katon W et al. Initial antidepressant choice in primary care. Effectiveness and cost of fluoxetine vs tricyclic antidepressants. JAMA 1996; 275(24):1897–1902. | Non-elderly treatment study
Simpson S, Corney R, Fitzgerald P, Beecham J. A randomized controlled trial to evaluate the effectiveness and cost-effectiveness of psychodynamic counselling for general practice patients with chronic depression. Psychol Med 2003; 33(2):229–239. | Non-elderly treatment study, comparative- effectiveness
Sirey JA, Bruce ML, Alexopoulos GS. The Treatment Initiation Program: an intervention to improve depression outcomes in older adults. American Journal of Psychiatry 2005;162(1):184–6. | Focus on treatment comparison, matching, or fine-tuning
Sloane RB SFSL. Interpersonal therapy vs. nortriptyline for depression in the elderly. Clinical and pharmacological studies in psychiatric disorders Biological psychiatry - new prospects 344–6p1985. | Not one of included study designs for relevant key question
Smit F, Ederveen A, Cuijpers P, Deeg D, Beekman A. Opportunities for cost-effective prevention of late-life depression: an epidemiological approach. Arch Gen Psychiatry 2006; 63(3):290–296. | Not a screening intervention trial with usual care control group
Sondergard L, Kvist K, Lopez AG, Andersen PK, Kessing LV. Temporal changes in suicide rates for persons treated and not treated with antidepressants in Denmark during 1995–1999. Acta Psychiatr.Scand. 2006; 114 (3):168–176. | Information included in Sondergard Int Clin Psychopharmacol 2006
Steed L, Cooke D, Newman S. A systematic review of psychosocial outcomes following education, self-management and psychological interventions in diabetes mellitus. Patient Educ Couns 2003; 51(1):5 | Not a general primary care population
Stimpson N, Agrawal N, Lewis G. Randomised controlled trials investigating pharmacological and psychological interventions for treatment-refractory depression. Br J Psychiatry 2002; 181(4):284–294. | Not a general primary care population
Storosum JG, Elferink AJ, van Zwieten BJ, van den Brink W, Gersons BP, van Strik R et al. Short-term efficacy of tricyclic antidepressants revisited: a meta-analytic study. Eur Neuropsychopharmacol 2001;11(2):173–180. | Non-elderly treatment study
Suh T, Gallo JJ. Symptom profiles of depression among general medical service users compared with specialty mental health service users. Psychol Med 1997; 27(5):1051–1063. | Does not report included outcomes
Swindle RW, Rao JK, Helmy A, Plue L, Zhou XH, Eckert GJ et al. Integrating clinical nurse specialists into the treatment of primary care patients with depression. Int J Psychiatry Med 2003; 33(1):17–37. | Focus on treatment comparison, matching, or fine-tuning
Taylor WD, Doraiswamy PM. A systematic review of antidepressant placebo-controlled trials for geriatric depression: limitations of current data and directions for the future. Neuropsychopharmacology 2004; 29(12):2285 | Updated/covered by another more recent SER/MA
Thase ME. Effects of venlafaxine on blood pressure: a meta-analysis of original data from 3744 depressed patients. J Clin Psychiatry 1998; 59(10):502–508. | Does not report included outcomes
Thomas HV, Lewis G, Watson M, Bell T, Lyons I, Lloyd K et al. Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. British Journal of General Practice 2004;54(508):832–7. | Focus on treatment comparison, matching, or fine-tuning
Thomas SP. From The Editor--Caution Urged in Prescribing Psychotropic Drugs for Older Patients. Issues Ment.Health Nurs. 2005;26(4), 357–358. | Not one of included study designs for relevant key question
Thompson C, Kinmonth AL, Stevens L, Peveler RC, Stevens A, Ostler KJ et al. Effects of a clinical-practice guideline and practice- based education on detection and outcome of depression in primary care: Hampshire Depression Project randomised controlled trial. Lancet 355(9199):185–91, 2000. | Screen not used in care of patient
Thompson LW, Gallagher D, Breckenridge JS. Comparative effectiveness of psychotherapies for depressed elders. J Consult Clin Psychol 1987; 55(3):385–390. | Not one of included study designs for relevant key question
Townsend E, Hawton K, Altman DG, Arensman E, Gunnell D, Hazell P et al. The efficacy of problem-solving treatments after deliberate self-harm: meta-analysis of randomized controlled trials with respect to depression, hopelessness and improvement in problems. Psychol Med 2001; 31(6):979–988. | Non-elderly treatment study
Trindade E, Menon D, Topfer LA, Coloma C. Adverse effects associated with selective serotonin reuptake inhibitors and tricyclic antidepressants: a meta-analysis. Can Med Assoc J 1998; 159(10):1245–1252. | Years covered precede 1999
University of York. NHS Centre for Reviews and Dissemination. Improving the recognition and management of depression in primary care. Eff Health Care 2002;7(5):1–12. | Not one of included study designs for relevant key question
Unutzer J, Katon W, Callahan CM, Williams JW, Jr., Hunkeler E, Harpole L et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA 2002; 288(22):2836–2845. | Focus on treatment comparison, matching, or fine-tuning
van de Meent H, Geurts AC, van Limbeek J. Pharmacologic treatment of poststroke depression: a systematic review of the literature. Topics in Stroke Rehabilitation 2003;10(1):79–92. | Not a general primary care population
van den Berg S, Shapiro DA, Bickerstaffe D, Cavanagh K. Computerized cognitive-behaviour therapy for anxiety and depression: a practical solution to the shortage of trained therapists. Journal of Psychiatric & Mental Health Nursing 2004;11(5):508–13. | Not a treatment outcomes study
van Os TW, van den Brink RH, Tiemens BG, Jenner JA, van der Meer K, Ormel J. Are effects of depression management training for General Practitioners on patient outcomes mediated by improvements in the process of care? J Affect Disord 2004;80(2–3):173–179. | Not a screening intervention trial with usual care control group
van Walraven C, Mamdani MM, Wells PS, Williams JI. Inhibition of serotonin reuptake by antidepressants and upper gastrointestinal bleeding in elderly patients: retrospective cohort study. BMJ 2001;323(7314):655–658. | Updated/covered by another more recent SER/MA
Verkaik R, van Weert JC, Francke AL. The effects of psychosocial methods on depressed, aggressive and apathetic behaviors of people with dementia: a systematic review. Int J Geriatr Psychiatry 2005; 20(4):301–314. | Not a general primary care population
Viney LL, Benjamin YN, Preston CA. An evaluation of personal construct therapy for the elderly. Br J Med Psychol 1989; 62(Pt 1):35–41. | Not one of included study designs for relevant key question
Volkers AC, Nuyen J, Verhaak PF, Schellevis FG. The problem of diagnosing major depression in elderly primary care patients. Journal of Affective Disorders 2004;82(2):259–63. | Not one of included study designs for relevant key question
Von Korff M, Goldberg D. Improving outcomes in depression. BMJ 2001; 323(7319):948–949. | Not one of included study designs for relevant key question
Vos T, Haby MM, Barendregt JJ, Kruijshaar M, Corry J, Andrews G. The burden of major depression avoidable by longer-term treatment strategies. Arch Gen Psychiatry 2004; 61(11):1097–1103. | Does not report included outcomes
Wagner W, Zaborny BA, Gray TE. Fluvoxamine. A review of its safety profile in world-wide studies. Int Clin Psychopharmacol 1994; 9(4):223–227. | Updated/covered by another more recent SER/MA
Walsh BT, Sysko R. Placebo control groups in trials of major depressive disorder among older patients. J Clin Psychopharmacol 2005; 25(4:Suppl 1):Suppl-33. | Focus on interventions that are not primarily CBT-related or IPT in nature
Walsh MT, Dinan TG. Selective serotonin reuptake inhibitors and violence: a review of the available evidence. Acta Psychiatr Scand 2001; 104(2):84–91. | Updated/covered by another more recent SER/MA
Watson LC, Pignone MP. Screening accuracy for late-life depression in primary care: a systematic review. J Fam Pract 2003; 52(12):956–964. | Not a screening intervention trial with usual care control group
Weatherall M. A randomized controlled trial of the Geriatric Depression Scale in an inpatient ward for older adults. Clin Rehabil. 2000;14:186–191. | Does not report included outcomes
Weihs KL, Settle EC, Jr., Batey SR, Houser TL, Donahue RM, Ascher JA. Bupropion sustained release versus paroxetine for the treatment of depression in the elderly. J Clin Psychiatry 2000; 61(3):196–202. | Comparative-effectiveness
Weinrieb RM, Auriacombe M, Lynch KG, Chang KM, Lewis JD. A critical review of selective serotonin reuptake inhibitor-associated bleeding: balancing the risk of treating hepatitis C-infected patients. J Clin Psychiatry 2003; 64(12):1502 | Not a general primary care population
Wells JL, Seabrook JA, Stolee P, Borrie MJ, Knoefel F. State of the art in geriatric rehabilitation. Part II: clinical challenges. Arch Phys Med Rehabil 2003; 84(6):898–903. | Not a general primary care population
Wen SW, Walker M. Risk of fetal exposure to tricyclic antidepressants. J Obstet Gynaecol Can 2004; 26(10):887–892. | Focus on pregnancy-related screening
Wessely S, Kerwin R. Suicide Risk and the SSRIs. JAMA: Journal of the American Medical Association 2004;292(3), 379–381. | Not one of included study designs for relevant key question
Wessinger S, Kaplan M, Choi L et al. Increased use of selective serotonin reuptake inhibitors in patients admitted with gastrointestinal haemorrhage: a multicentre retrospective analysis. Aliment Pharmacol Ther. 2006;23:937–944. | Not a primary care population
Westen D, Morrison K. A multidimensional meta-analysis of treatments for depression, panic, and generalized anxiety disorder: an empirical examination of the status of empirically supported therapies. J Consult Clin Psychol 2001; 69(6):875–899. | Non-elderly treatment study
Whitehead C, Moss S, Cardno A, Lewis G. Antidepressants for people with both schizophrenia and depression. Cochrane Database of Systematic Reviews 2005;(3). | Not a general primary care population
Whittington CJ, Kendall T, Fonagy P, Cottrell D, Cotgrove A, Boddington E. Selective serotonin reuptake inhibitors in childhood depression: systematic review of published versus unpublished data. Lancet 2004; 363(9418):1341–1345. | Focus on children or adolescents
Whyte EM, Mulsant BH. Post stroke depression: epidemiology, pathophysiology, and biological treatment. Biol Psychiatry 2002; 52(3):253–264. | Not a general primary care population
Wilson KCM, Mottram PG. Long-term treatments for older depressed people. Cochrane Database of Systematic Reviews 2005;(3). | Depression prevention or treatment maintenance intervention
Wisner KL, Gelenberg AJ, Leonard H, Zarin D, Frank E. Pharmacologic treatment of depression during pregnancy. JAMA 1999; 282(13):1264–1269. | Focus on pregnancy-related screening
Wohlfarth T, Storosum JG, Elferink AJ, van Zwieten BJ, Fouwels A, van den BW. Response to tricyclic antidepressants: independent of gender? Am J Psychiatry 2004; 161(2):370–372. | Non-elderly treatment study
Wright JH, Wright AS, Albano AM, Basco MR, Goldsmith LJ, Raffield T et al. Computer-assisted cognitive therapy for depression: maintaining efficacy while reducing therapist time. American Journal of Psychiatry 2005;162(6):1158 -64. | Non-elderly treatment study
Zetin M. Psychopharmaco-hazardology: major hazards of treating depression and anxiety. Comprehensive Therapy 2004;30(1):18–24. | Not one of included study designs for relevant key question
Zung WW, Magill M, Moore JT, George DT. Recognition and treatment of depression in a family medicine practice. J Clin Psychiatry. 1983;44:3–6. | Does not meet quality criteria

Appendix G Table 8 Fair- to poor-quality cohort study details.

Gibbons 2007:^146^ A fair-to-poor quality observational study of Veteran’s Administration patients identified 226,866 patients with evidence of depression in 2003 or 2004, and no history of treatment for depression in the previous 3 years. Use of SSRIs, non-SSRI second generation agents (bupropion, mirtazapine, nefazodone, and venlafaxine), and TCAs was abstracted from electronic medical records. Among these patients, 114,475 were treated with a single type of antidepressants (SSRI, other second generation, or TCA), 52,959 were treated with antidepressants in more than one of these categories, and 59,432 had no record of antidepressant use. Suicide attempts (including those that were fatal) which led to contact with the VA system over 6–24 months after new antidepressant treatment initiation were identified using diagnosis codes in the medical record. The study was not able to examine all suicide-related deaths. The overall rate of suicide attempts in those initiating SSRI treatment (alone or in combination with other medications) was 36.4/10,000 compared with 33.5/10,000 suicide attempts among those diagnosed but not treated. The remaining analyses are not useful since they compared the experience of a selected subgroup who received only one type of antidepressant, which excluded 26 percent of all depressed patients (and 34 percent of those treated with antidepressants). Further, comparisons between medications for this subgroup are likely confounded by indication, since more patients with major depressive disorder were treated with non-SSRIs than with SSRIs.
Sondergard 2006:^144^ In a fair-to-poor quality cohort study using national registries for all Danish prescriptions and deaths in 1995–1999, Sondergard and colleagues determined the rates of suicides per 10,000 person-years in 438,625 adults dispensed any type of antidepressants (24 different medications) for any indication over up to five years of follow-up.144 Mean follow-up was not reported. Suicides in persons treated with antidepressants ranged from 11.5 to 48.6 per 10,000 person-years, with rates in men two-three times higher than those in women. Seventy percent of the 1474 persons receiving antidepressants who committed suicide did so during the first month of treatment. In the untreated control group that was selected “randomly” from all non-users, there were 1.3 suicides per 10,000 person-years of follow-up (2.0 in men and 0.56 in women). More precise estimates of suicide rates in antidepressant-treated adults are not available as all rates of suicides were reported only by drug type and numbers of dispenses, and this data has a high potential for confounding by indication (particularly since patients being treated for all indications were examined). Confounding by indication is also a concern since these were not clearly incident users, as prior treatment history was not considered (except for excluding those with previous lithium dispenses). Comparisons of the untreated controls with the treated patients is further limited by lack of matching or adjustment for potential confounders such as age.
Mackay 1999:^143,145^ Two fair-to-poor quality studies reported survey data examining GP-reports of suicide and other adverse events in patients identified using Prescription Event Monitoring Database records from 1987–1996.^143,145^ Investigators surveyed GPs six months after one of their patients received their first prescription during the post-marketing period for one of seven newly approved antidepressants (4 SSRIs two other second-generation antidepressants, one first-generation). Recall surveys focused on indications, starting and stopping dates, response to treatment, events during and after treatment (defined to elicit possible-drug related events), and reasons for discontinuation. Response rates were low (55 to 64 percent). There were at least 10,000 persons in the final cohort for each antidepressant, and at least 71 to 80 percent of the patients were being treated for depression, excluding any patients treated for mania, hypomania, agitation, or anxiety. The combined rate for suicide and “parasuicide” (not further defined) among those taking any of the antidepressant drugs was 324–672/10,000 person-years, depending on medication. Data were not reported on the completeness of returned surveys or on whether doctors used medical records or simply recall in completing forms. Given the low GP response rates, estimates could be too high if doctors preferentially reported on patients with serious side-effects or too low if the opposite were true.

Appendix G Table 9 FDA summary.

In the 2006 FDA report, there was a large difference in event rates for suicide, particularly in patients with MDD, and in suicidal behaviors, compared with the findings in multiple other independent analyses. Particularly puzzling is the difference in event rates between the 2006 report and another 2006 publication representing similar FDA work apparently using some of the same datasets. The 2006 FDA report provides several explanations for its lower event rates than earlier reports by Gunnell and Fergusson, including potential over-counting of multiple suicide-related events per person in these other analyses. However, since suicide cannot be counted twice, this does not explain the two- to four- fold reduction in suicide rates in the 2006 FDA report compared to others evaluating similar patient groups. Other possible explanations are: 1) differences in event definitions (definitions for suicide-related behaviors may have excluded events counted elsewhere;138 2) differences in event determination (it is not clear the FDA searched for adverse events in case record forms to identify events not flagged as drug-related or significant by the trial investigator as did the MHRA-related work);105 and 3) differences in event categorization, including the fact that the FDA relied on companies to categorize adverse events using a protocol (as did the MHRA) and required narratives for all potential suicide-related adverse effects, but did not collect or review them all (in contrast to the requirements in the MHRA-related analyses). Potential differences due to event categorization could not be assessed since the FDA report did not provide event numbers for serious adverse events that were not included in the suicide-related outcomes (i.e., self-injurious behavior, intent unknown, not enough information-fatal, not enough information-non-fatal) and did not provide the numbers upon request. Finally, 4) a lower event rate in the FDA report could reflect the time frame in which adverse events could be counted. This limited the FDA report to active treatment only, and events were not counted if they occurred during placebo run-in before randomization (which is appropriate) or greater than one day after medication discontinuation (which could lead to underascertainment, particularly with so many discontinuing treatment early). In one of the observational studies we reviewed in which 69 suicides occurred in adults after receiving their first dispense of antidepressants, the person was not taking antidepressants at the time of their suicide in about half of the cases (52 percent).128
The FDA indicated it requests information on any death occurring within the period ending 90 days after the intended treatment period in order to look for informative censoring. However, it is not clear if or how this reporting approach affected the final analyses. In considering differences between its 2006 report and others, the FDA rightly notes that it has a superior method with individual level meta-analysis as compared to trial level meta-analysis. However, the differences between the FDA 2006 report findings and other meta-analyses would not be primarily explained by these analytic differences. Finally, by choosing a primary outcome that combined ideation with behavior, we found that many of the FDA report’s results were not clarifying. Raw event data from the 2006 FDA report indicate that the impact of antidepressants, compared with placebo, on suicidal behaviors differs in direction from the impact on suicidal ideation. These findings are corroborated in other reviews that find a statistically significant impact on suicidal behavior, but not ideation, in the few patient subgroups with any suicide-related adverse events.