# Meta-analysis decision factors

Appendix F Table 1 Meta-analysis decision factors

Study Reference Design | Newly identified cases only? | Unscreened control group? Location and timing of screening? | Percent of screened patients who were positive for depression | Percent of patients currently or recently treated for depression at time of screen | Patient-level intervention beyond assessment and antidepressant medication? | Followup | Screening Instrument | Results, Primary Outcome % control group in remission at followup
Older Adults
Whooley et al 2000^111^ Cluster RCT | No | No Waiting room, usually before visit | 14.1% positive | approx 20% used antidepressant in past 12 mos | Yes: series of 6 psycho-ed classes + 1 booster (but 12% pts attended) | 24-mo | GDS | No group differences in GDS 50% remission @ 24 mos
Bosmans et al 2006^115^ Cluster RCT | Yes | No Before visit, presume waiting room | 14.7% positive | 0% currently treated | No | 12-mo | GDS | No group differences in MADRS score 48% remission @ 12 mos
Callahan et al 1994^112^ Cluster RCT | No | No In exam room, during visit | 16.2% positive on CESD (first screener) 4.6% completed both screens, positive on both | approx 12% on antidepressant at baseline | Yes: educational materials, 3 depression-focused visits with provider | 6-mo | CESD + HAMD (2-step process) | No group differences on CESD 12% responded @ 6 mo
Rubenstein et al 2007^116^ | No | No By mail | 41.0%, among those who met threshold for high risk for five conditions | NR | Yes: quarterly followup by case manager | 12-mo | GDS | I-group greater improvement in GDS (small effect) NR
No focus on older adults
Williams et al 1999^10^ (low income) RCT | No | Yes Waiting room, before appt Also had research diagnostic interview w/in 2 wks of baseline appt. | 1-item screen: 41% pos CES-D: 33% pos | NR | No | 3-mo | CESD or 1-item | Mixed: no differences in % depressed but great % of I-group in full remission. Assessed via diagnostic interview 27% remission @ 3 mos
Wells et al 2000^110^ Cluster RCT | No | No Waiting area, probably same day at appt, pts may have gotten results | 14.3% positive | NR | extensive | 6-mo, 12-mo, 57-mo | CIDI (2-step) | I-group better outcomes, % dep per CESD 50% @ 6-mo
Bergus et al 2005^113^ (rural) RCT | No | No Waiting room, before visit | 13.8% positive | 38% on meds for dep OR anxiety, 60% history of tx for depression | No | 1-mo, 2.5-mo, 6-mo | PHQ-9 | No group diffs, change in PHQ, % remission 38% remission @ 6 mos
Jarjoura et al 2004^114^ (indigent) RCT | Yes | No Waiting room, before visit | 45.4% positive overall 9.2% positive AND not currently being treated for depression | 0% | minimal | 6-mo, 12-mo | BDI | I-group better outcomes, mixed model repeated measure BDI 21% showed ≥33% improvement in BDI score (avg of 6- and 12-mo scores)
Rost et al 2001^109^ Cluster RCT | No, but only reported newly-identified and previously-identified cases separately | No Waiting room, before visit | 6.8% positive | ~44% overall | Yes, 8 weekly nurse education session, discuss treatment options, homework to enhance readiness to enage in treatment. | 6-mo | CIDI (2-step) | I-group better outcomes (change in CESD) among newly identified cases only 22% remission among newly identified cases only

GDS=Geriatric Depression Scale; CESD=Center of Epidemiologic Studies Depression Scale; HAMD-Hamilton Depression Rating Scale; CIDI=Composite International Diagnostic Interview; PHQ-9=9-item Patient Health Questionnaire; BDI=Beck Depression Inventory