# Detailed methods

## Key Questions and Analytic Framework

Using the USPSTF methods, we developed an analytic framework (Figure 1) to guide our literature search. This review focused on five KQs related to this analytic framework that the USPSTF determined needed to be updated for its recommendation.

### Critical Key Questions Addressed in This Update

KQ1. Is there direct evidence that screening for depression among adults and the elderly in primary care reduces morbidity (including improved depression response and remission) and/or mortality?

KQ1a. What is the impact of clinician feedback of screening test results (with our without additional care management support) on depression response and remission in screen-detected depressed patients receiving primary care?

KQ2. What are the adverse effects of screening for depressive disorders in adults and the elderly?

KQ3. Is antidepressant and/or psychotherapy treatment of elderly depressed patients effective in improving health outcomes?

KQ4. What are the adverse effects of antidepressant treatment (suicidality, psychiatric hospitalization, and discontinuation of medication due to adverse events) for depression in adults and the elderly?

### Key Questions Not Updated in This Review

- Efficacy of treatment in adults
- Accuracy of screening instruments in adults and older patients

## Literature Search Strategy

We initially searched for systematic evidence reviews (SERs) and meta-analyses (MAs) on depression treatment or screening in adults and elderly in Pubmed-Medline from 1998 through December 2007 and in the Database of Abstracts of Reviews (DARE), and Cochrane Database of Systematic Review (CDSR) in October, 2005, with an updated search in October, 2006 to capture studies published in the interim. We screened systematic reviews (SR) and meta analyses (MA) at the abstract stage and at the article review stage for relevance to each of our key questions and for quality(Appendix C for inclusion/exclusion criteria).

Subsequent searches specific to each key question were done to supplement evidence found in the search of reviews and meta-analyses. All searches were examined by two reviewers for relevance to all key questions. We also hand-searched the Robert Wood Johnson Foundation and the MacArthur Foundation websites, as well as reviewing the National Institute for Health and Clinical Excellence guideline for management of depression in primary and secondary care and its complete bibliography.57

For KQ1 and KQ1a, none of the systematic reviews of depression screening were wholly consistent with our inclusion-exclusion parameters. We, therefore, conducted a primary literature search to cover the time period since the previous USPSTF review (1998 through December, 2007) for controlled trials (RCTs and CCTs) of depression screening in primary care settings in Ovid-Medline, Psychinfo, and Cochrane Collaboration Registry of Controlled Trials (CCRCT). Search terms are listed in Appendix D Table 1. In addition, in order to locate other screening trials for KQ1, comparing screened and a non-screened groups, we searched Ovid-Medline, Science Citation Index, Social Science Citation Index, Science Direct, HighWire Press, and Google Scholar from 2000 to March, 2006 for articles referencing the single screening article from the previous USPSTF review that included a non-screened control group.10 We also evaluated all trials that involved screening and reported health outcomes in the previous USPSTF review1,71 the 2005 Cochrane review on depression screening,100 and a recent review on educational and organizational interventions for depression.101

For KQ2, we searched all abstracts found for KQ1 and KQ1a and all articles pulled for further examination for KQ1 and KQ1a for evidence of harms. We also examined systematic and non-systematic reviews for evidence of harms or potential harms. Additionally, we searched Ovid-Medline, PubMed, and Psychinfo from 1998 through December, 2007 using the same search terms as KQ1 and KQ1a except without restrictions on study design, and adding terms to capture harms generally (i.e., adverse events, harms), and one specific potential harm suggested in review articles (labeling).

For KQ3, in addition to the initial SER search described above, we searched Ovid-Medline, PsycINFO, and CCRCT specifically for controlled trials, systematic reviews, or meta-analyses of psychotherapy and antidepressant treatment in the elderly in two separate searches covering 1998- December, 2007 for psychotherapy trials and 2003-December, 2007 for antidepressant trials. (We only searched for original trials beginning in 2003 for antidepressant treatment because we found one meta-analysis in our original SER search that covered trials published through 2004.) Reference lists of all articles reviewed from these searches were hand-searched for potentially relevant trials or systematic reviews. We reviewed abstracts and articles from three meta-analyses that met our inclusion criteria and appeared to capture the relevant trials comprehensively. Because these meta-analyses were recent and comprehensive we used them as our evidence for this question rather than using individual trials.

For KQ4, in addition to the initial search for SERs and MAs and hand searches described above, we reviewed all abstracts located for KQ1, KQ2, and KQ3 for treatment-associated harms and used one comparative effectiveness review of second generation antidepressants92 and one evidence-based depression care guideline57 as source documents for systematic reviews and primary articles addressing harms. Additionally, we searched MEDLINE and PsycINFO from 1988 through December, 2007 to locate large (minimum of 10,000 observations and 6 months of followup for suicide-related harms, and minimum 1000 observations and 3 months of followup for non-suicide-related harms) observational studies addressing adverse effects by searching for publications that included SSRI terms and terms related to either suicide or discontinuation without restrictions related to study design.

## Inclusion/Exclusion Criteria

We developed a set of inclusion/exclusion criteria that were applied to each key questions, with specific criteria for inclusion and exclusion as needed for each key question.

Populations and Disorders. The population of interest: general population non-pregnant adults (ages 18 and over) treated in primary care setting in the US, Canada, UK, Australia, New Zealand, for non-synthesized literature, with inclusion of studies from other northern European countries when data were not adequate for a specific key question. Diagnostic categories of interest: Major Depressive Disorder, Dysthymia, and Depression Not Otherwise Specified (including Minor Depression), or “depression” with no further diagnostic specificity. We did not include studies with a primary focus on pregnancy-related depression, Bipolar Disorders, Schizoaffective disorder, Seasonal Affective Disorder, Cyclothymia, Substance-Induced Mood Disorder, or Adjustment Disorder with depressed mood. We excluded studies focusing only on patients at high-risk for depression and those focused exclusively on Dysthymia or Minor Depression.

Settings. Primary care or community practices. We excluded studies conducted exclusively in inpatient, residential treatment, psychiatric, or non-health care community settings (e.g. worksites).

Screening (KQ1/1a, KQ2). We included RCTs/CCTs of screening programs comparing screened vs. unscreened patients, and RCTs/CCTs in screened-detected patients examining the health outcomes from screening and feedback of test results to primary care clinicians, with or without other depression care supports. Screening studies were required to use a depression-specific screening instrument or, if no depression-specific screener is used then they must report depression-specific outcomes. We excluded any system-level, Q.I., or depression care management interventions that did not involve screening. Screening trials must have used the screening results in the care of the intervention participants and must not have used the screening results in the care of the control participants.

Treatments (KQ3, KQ4). To be consistent with the previous review for the USPSTF, we limited treatments to antidepressant medications, psychotherapy, or combinations of these two for KQ3. We limited medication treatments to antidepressants, excluding mood stabilizers such as lithium, valproic acid, and Carbamazepine. For harms (KQ4), we focused on antidepressants only, and on newer (“second-generation”) antidepressant in particular.

Outcomes. For all key questions except KQ4, health outcomes of interest included: depressive symptomatology (response), quality of life ratings, assessments of functioning, change in fulfilling criteria for the diagnosis of a study-relevant depressive illness (remission), suicidality (attempts or ideation), or change in health status (e.g., death, improvement in co-morbid disorders, reduction in physical complaints). We did not consider recognition or treatment of depression as health outcomes. For KQ4, we focused on suicide-related events, serious psychiatric events, serious medical events (for older adults), and discontinuation (overall and due to adverse events).

Study Designs. For KQ1 and KQ1a we limited our searches to RCTs and well-designed, non-randomized controlled trials. Designs for key question 2 included RCTs, CCTs, and high-quality observational studies. Evidence for KQ3 was limited to high-quality recent meta-analyses. For KQ4, we included systematic reviews, regulatory reviews, or meta-analyses of RCTs and large observational studies (minimum of 10,000 observations and 6 months of followup for suicide-related harms, and minimum 1000 observations and 3 months of followup for non-suicide-related harms).

Quality. We excluded studies that met criteria for “Poor” quality using the USPSTF design-specific criteria.

Language. We excluded non-English language abstracts and articles.

Costs. We retrieved articles on cost and cost-effectiveness relevant to depression screening in primary care.

## Literature Review Process

We reviewed a total of 4088 abstracts and 412 complete articles for all KQs (Appendix D Figure 1). Abstracts were reviewed by two investigators against inclusion/exclusion criteria specific for each key question. Retrieved articles were compared to inclusion and exclusion criteria by two investigators for the applicable key question(s). Included studies that met all criteria were then rated by two raters for quality according to USPSTF standards.104 Separate criteria were used to judge quality of original research articles and systematic reviews. The rating process involved the independent examination of several key quality indicators listed in Appendix B Table 1. Articles were rated as good (no notable flaws), fair (minor flaws) or poor, (major flaw(s) or numerous minor flaws) by each rater, and disagreements were settled by consensus.

For KQ1 and KQ1a we examined 248 articles, and of these retained one trial for KQ1 and seven trials for KQ1a. Five of the KQ1 and KQ1a studies were included in the 2002 USPSTF review, and three additional studies were found from our database searches. Hierarchical inclusion criteria for KQ1a are presented in Appendix D Figure 2. Briefly, we included trials that screened consecutively or randomly selected adult patients in a primary care setting. Screening instruments were required to be specific to depression or to include a module specific to depression. Studies ranged considerably in the extensiveness of the depression education and care supports provided in addition to screening and feedback. We included studies, regardless of the level of additional intervention, as long as screening results were used in the clinical care of the patient. We excluded studies that screened high-risk populations rather than general populations. An unscreened control group was required for KQ1, but for KQ1a the control group was screened but without results being systematically returned to the provider.

For KQ2 we included studies that measured adverse events related to depression screening. We did not find any studies in any of the searches used for KQ2 that met our inclusion-exclusion criteria for harms of screening.

For KQ3 we included controlled trials or systematic reviews of antidepressant or psychotherapy treatment in populations of older patients. We excluded studies that focused on specific high risk groups, such as stroke patients. We retained three systematic reviews that included meta-analyses.

For KQ4, we limited our review to systematic or regulatory reviews of RCTS reporting specific, serious harms (suicidality, psychiatric morbidity and, in the elderly, medical morbidity) and tolerability (early discontinuation overall and due to adverse effects) as a proxy for a large range of common, less serious adverse events. We supplemented synthesized short-term trial data with large observational studies.

For suicide-related adverse events, we included one systematic review and five regulatory reviews from our SER search, from our searches for other key questions, and from hand-searches. Two types of reviews were included: 1) regulatory reviews, which included all clinical trials submitted to national regulatory agencies by the manufacturers to support drug approval, with reviews conducted by the agency or by outside investigators; and 2) published systematic reviews, that may not include all unpublished regulatory trials, but may also include RCTs that are funded by an agency other than the drug’s manufacturer.

For serious psychiatric events (e.g. hospitalization), we did not find any existing systematic reviews, but included one large clinical trial (STAR-D) and one uncontrolled trial.

For serious medical events in the elderly, we located one systematic review of upper gastrointestinal bleeding.

For tolerability, we located seven systematic reviews or meta-analyses and two cohort or uncontrolled trials which reported discontinuation (overall and due to adverse events).

## Data Abstraction

One primary reviewer abstracted relevant information into standardized evidence tables for each included article for KQ1 and KQ1a combined, KQ3, and KQ4 (in two tables: one for meta-analyses and one for cohort and observational studies) (Appendix G). A second reviewer checked the abstracted data for accuracy and completeness.

## Literature Synthesis

We did not conduct quantitative synthesis for any key question, although we relied extensively on these data from published meta-analyses for KQ3 (treatment in the elderly) and KQ4 (adverse effects of treatment). For KQ4, we abstracted data to calculate absolute event rates for suicide-related events were abstracted from meta-analyses and systematic reviews, with 95 percent CI calculated based on a Poisson distribution using the SAS version 8.2 GENMOD procedure with the offset option set at the log of the event rate. Risk differences with 95 percent CI for suicide-related events in patients with MDD (a relatively homogeneous risk group) on active medication were calculated using the RISKDIFF option of the FREQ procedure in SAS 8.2. This procedure uses a normal approximation to the binomial distribution to construct asymptotic confidence intervals (SAS Version 8.2 for Windows, SAS Institute Inc., Cary, North Carolina). The only key questions for which we relied solely on original research was KQ1 and KQ1a. For KQ1a, we did not attempt meta-analysis of results as we judged that the included studies displayed too much clinical diversity (e.g. screening instruments, extent of the interventions, and populations) and methodological diversity (e.g., comparability of intervention and control groups across studies) to be synthesized quantitatively (Appendix F).235 Instead, we qualitatively synthesized our results, discussing studies with a focus on elderly patients separately.

Appendix D Figure 1 Search results and article flow by key question.

* Overlap occurs between the articles reviewed for each key question.

Appendix D Table 1 Search Strategies

Systematic Review
Databases: MedLine, Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects
Dates: 1998 to December 2007
1 | depression/dt [drug therapy] OR depression/pc[prevention and control] OR depression/rh[rehabilitation] OR depression/th[therapy]
2 | depression, postpartum/dt[drug therapy] OR depression, postpartum/pc[prevention and control] OR depression, postpartum/rh[rehabilitation] OR depression, postpartum/th[therapy]
3 | depressive disorder, major/dt[drug therapy] OR depressive disorder, major/pc[prevention and control] OR depressive disorder, major/rh[rehabilitation] OR depressive disorder, major/th[therapy]
4 | dysthymic disorder/dt[drug therapy] OR dysthymic disorder/pc[prevention and control] OR dysthymic disorder/rh[rehabilitation] OR dysthymic disorder/th[therapy]
5 | depressive disorder/dt[drug therapy] OR depressive disorder/pc[prevention and control] OR depressive disorder/rh[rehabilitation] OR depressive disorder/th[therapy]
6 | depression/OR depressive disorder OR depression, postpartum/OR depressive disorder, major/OR dysthymic disorder/
7 | “mass screening” OR screen$.ti,ab
8 | 6 AND 7
9 | 1 OR 2 OR 3 OR 4 OR 5 OR 8
10 | 9 AND systematic[sb] Field: All Fields, Limits: All Adult: 19+ years, Publication Date from 1998 to 2006, English
11 | 9 AND systematic[sb]
Screening Trials
Database: MedLine, PsychInfo, Cochrane Central Register of Controlled Trials
Dates: 1996 to December 2007
1 | Depression/
2 | Depressive Disorder/
3 | Depressive Disorder, Major/
4 | 1 or 2 or 3
5 | Mass Screening/
6 | screen$.ti,ab.
7 | case finding.ti,ab.
8 | casefinding.ti,ab.
9 | 5 or 6 or 7 or 8
10 | 4 and 9
11 | Mental Disorders/di
12 | depress$.ti,ab.
13 | 9 and 11 and 12
14 | 10 or 13
15 | limit 14 to (clinical trial or controlled clinical trial or randomized controlled trial)
16 | clinical trials/or controlled clinical trials/or randomized controlled trials/
17 | double-blind method/or random allocation/or single-blind method/
18 | random$.ti,ab.
19 | 16 or 17 or 18
20 | 14 and 19
21 | 15 or 20
22 | limit 21 to english language
23 | limit 22 to yr= “1998 – 2006”
Screening Harms
Database: Ovid MEDLINE(R), PubMed, PsychInfo
Dates: 1966 to December 2007
1 | Depression/
2 | Depressive Disorder/
3 | Depressive Disorder, Major/
4 | Mental Disorders/di [Diagnosis]
5 | depress$.ti,ab.
6 | 4 and 5
7 | 1 or 2 or 3 or 6
8 | Mass Screening/
9 | screen$.ti,ab.
10 | case finding.ti,ab.
11 | casefinding.ti,ab.
12 | 8 or 9 or 10 or 11
13 | 7 and 12
14 | adverse effects.fs.
15 | adverse effect$.ti,ab.
16 | harm$.ti,ab.
17 | label$.ti,ab.
18 | 14 or 15 or 16 or 17
19 | 13 and 18
20 | limit 19 to english language
21 | limit 20 to yr= “1998 – 2006”
Elderly-Treatment trials
Database: Ovid MEDLINE(R), PsycInfo, Cochrane Central Register of Controlled Trials
Dates: 1998- December 2007
1 | Depression
2 | Depressive Disorder, Major
3 | Depressive Disorder
4 | depress$.ti,ab
5 | Mental Disorders
6 | 4 and 5
7 | 1 or 2 or 3 or 6
8 | Psychotherapy/
9 | Behavior Therapy/
10 | Cognitive Therapy/
11 | Psychotherapy, Brief/
12 | Counseling/
13 | Directive Counseling/
14 | Problem Solving/
15 | psychotherap$.ti,ab.
16 | (behavi$ and (therap$ or treatment$ or intervention$)).ti,ab.
17 | (Cognitive and (therap$ or treatment$ or intervention$)).ti,ab.
18 | interpersonal therap$.ti,ab.
19 | interpersonal psychotherap$.ti,ab.
20 | interpersonal intervention$.ti,ab.
21 | counsel$.ti,ab.
22 | problem solving.ti,ab.
23 | 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22
24 | aged/or “aged, 80 and over”/or frail elderly/
25 | older.ti,ab.
26 | elder$.ti,ab.
27 | geriatric$.ti,ab,hw.
28 | senior$.ti,ab.
29 | 24 or 25 or 26 or 27 or 28
30 | 7 and 23 and 29
31 | limit 30 to (clinical trial or controlled clinical trial or randomized controlled trial)
32 | clinical trials/or controlled clinical trials/or randomized controlled trials/
33 | double-blind method/or random allocation/or single-blind method/
34 | random$.ti,ab.
35 | 32 or 33 or 34
36 | 30 and 35
37 | 31 or 36
38 | limit 37 to english language
Observational Studies of SSRI Harms
Databse: PsycINFO and MEDLINE
Dates: 1988- December 2007
1 | Antidepressive Agents, Second-Generation/
2 | Serotonin Uptake Inhibitors/
3 | ssri$.ti.
4 | selective serotonin reuptake inhibitor$.ti.
5 | antidepress$.ti.
6 | (ssri$ or selective serotonin reuptake inhibitor$).ab.
7 | 5 and 6
8 | 1 or 2 or 3 or 4 or 7
9 | suicide$.ti,ab,hw.
10 | suicidal$.ti,ab,hw.
11 | discontinu$.ti,ab,hw.
12 | 9 or 10 or 11
13 | 8 and 12
14 | observational.ti,ab.
15 | (cohort adj (study or studies)).ti,ab.
16 | cohort analys$.ti,ab.
17 | cohort studies/
18 | retrospective$.ti,ab.
19 | retrospective studies/
20 | longitudinal$.ti,ab.
21 | longitudinal studies/
22 | (follow up adj (study or studies)).ti,ab.
23 | follow-up studies/
24 | prospective$.ti,ab.
25 | prospective studies/
26 | database$.ti,ab,hw.
27 | nonrandomi$.ti,ab.
28 | population$.ti,ab.
29 | case control$.ti,ab.
30 | case-control studies/
31 | 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30
32 | 13 and 31
33 | limit 32 to “all child (0 to 18 years)”
34 | limit 32 to “all adult (19 plus years)”
35 | 33 not 34
36 | 32 not 35
37 | limit 36 to (english language and yr= “1988–2007”)

Appendix D Figure 2 Screening Study Interventions and Approaches: Model for Inclusions and Exclusions