# USPSTF Hierarchy of research design and quality rating criteria104

## Hierarchy of Research Design

I Properly conducted randomized controlled trial (RCT)
II-1 Well-designed controlled trial without randomization
II-2 Well-designed cohort or case-control analytic study
II-3 Multiple time series with or without the intervention; dramatic results from uncontrolled experiments
III Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees

## Design-Specific Criteria

### Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance are especially important for systematic reviews

### Case-Control Studies

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

### Randomized Controlled Trials and Cohort Studies

Criteria:

- Initial assembly of comparable groups
  - -for RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  - -for cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of the interventions
- All important outcomes considered

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate result in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test

Appendix B Table 1 Specific Quality Rating Criteria

Randomized Controlled Trials | Systematic Reviews
Random assignment | Is there a clear review question?
Allocation concealment | Was the literature search strategy stated
Groups similar at baseline | Were there explicit inclusion/exclusion criteria reported relating to selection of the primary studies
Eligibility criteria specified | Selection Bias
Clear definition of Intervention | Is there evidence of a substantial effort to search for all relevant research
Training of treatment providers reported | Is the validity of included studies adequately assessed
Supervision of treatment providers reported | Is sufficient detail of the individual studies presented
Patient and provider treatment allegiance or preference reported | Are any important studies missing
Blinded outcomes assessors | Are the primary studies summarized appropriately
Attrition <40% and not differential | Were the authors’ conclusions supported by the evidence they presented
Adherence reported | What was the funding source and role of funder
Cross-over reported
Likelihood of contamination
Appropriate statistical analysis