# References

1 U.S. Preventive Services Task Force. (2002). Screening for breast cancer: recommendations and rationale. Ann Intern Med.
2 Humphrey L, Helfand M, Chan BKS, et al. (2002). Breast cancer screening: a summary of the evidence Systematic Evidence Review (Prepared by the Oregon Evidence-based Practice Center for the Agency for Healthcare Research and Quality).
3 Humphrey LL, Helfand M, Chan BKS, et al. (2002). Breast cancer screening: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med.
4 Simpson JF, Wilkinson EJ. (2004). Malignant neoplasia of the breast: infiltrating carcinomas. Bland KI, Copeland EM, editors. The breast: comprehensive management of benign and malignant disorders.
5 Schwartz GF. (2004). Biology and management of lobular carcinoma in situ of the breast. Bland KI, Copeland EM, editors. The breast: comprehensive management of benign and malignant disorders.
6 Page DL, Lagios MD. (2004). In situ carcinomas of the breast: ductal carcinoma in situ, Paget’s disease, lobular carcinoma in situ. Bland KI, Copeland EM, editors. The breast: comprehensive management of benign and malignant disorders.
7 American Cancer Society. Cancer facts and figures 2007.
8 American Cancer Society. (2008). Statistics.
9 Ries LAG, Melbert D, Krapcho M, et al. SEER cancer statistics review, 1975–2004.
10 Ries LAG, Harkins D, Krapcho M, et al. SEER cancer statistics review, 1975–2003.
11 Ravdin PM, Cronin KA, Howlader N, et al. (2007). The decrease in breast-cancer incidence in 2003 in the United States. N Engl J Med.
12 Centers for Disease Control and Prevention. (2007). Decline in breast cancer incidence - United States, 1999–2003. MMWR.
13 Kerlikowske K, Miglioretti DL, Buist DS, et al. (2007). Declines in invasive breast cancer and use of postmenopausal hormone therapy in a screening mammography population. J Natl Cancer Inst.
14 Chagpar AB, McMaster KM. (2007). Trends in mammography and clinical breast examination: a population-based study. J Surg Res.
15 American Cancer Society. Breast cancer facts & figures 2005–2006.
16 Edwards BK, Brown ML, Wingo PA, et al. (2005). Annual report to the nation on the status of cancer, 1975–2002, featuring population-based trends in cancer treatment. J Natl Cancer Inst.
17 Berry DA, Cronin KA, Plevritis SK, et al. (2005). Effect of screening and adjuvant therapy on mortality from breast cancer. N Engl J Med.
18 Lawson JS, Gunzburg WH, Whitaker NJ. (2006). Viruses and human breast cancer. Future Microbiol.
19 Sontag L, Axelrod DE. (2005). Evaluation of pathways for progression of heterogeneous breast tumors. J Theor Biol.
20 Allred DC, Wu Y, Mao S, et al. (2008). Ductal carcinoma in situ and the emergence of diversity during breast cancer evolution. Clin Cancer Res.
21 Burstein HJ, Polyak K, Wong JS, et al. (2004). Ductal carcinoma in situ of the breast. N Engl J Med.
22 Park K, Han S, Kim HJ, Kim J, Shin E. (2006). HER2 status in pure ductal carcinoma in situ and in the intraductal and invasive components of invasive ductal carcinoma determined by fluorescence in situ hybridization and immunohistochemistry. Histopathology.
23 Warnberg F, Nordgren H, Bergkvist L, et al. (2001). Tumour markers in breast carcinoma correlate with grade rather than with invasiveness. Br J Cancer.
24 Erbas B, Provenzano E, Armes J, et al. (2006). The natural history of ductal carcinoma in situ of the breast: a review. Breast Cancer Res Treat.
25 Armstrong K, Moye E, Williams S, et al. (2007). Screening mammography in women 40 to 49 years of age: a systematic review for the American College of Physicians. Ann Intern Med.
26 Bijker N, Peterse JL, Duchateau L, et al. (2001). Risk factors for recurrence and metastasis after breast-conserving therapy for ductal carcinoma-in-situ: analysis of European Organization for Research and Treatment of Cancer Trial 10853. J Clin Oncol.
27 Nelson HD, Huffman LH, Fu R, et al. (2005). Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med.
28 Martin AM, Weber BL. (2000). Genetic and hormonal risk factors in breast cancer. J Natl Cancer Inst.
29 Boyd NF, Guo H, Martin LJ, et al. (2007). Mammographic density and the risk and detection of breast cancer. N Engl J Med.
30 Chlebowski RT, Hendrix SL, Langer RD, et al. (2003). Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women’s Health Initiative Randomized Trial. JAMA.
31 Bhatia S, Robinson LL, Oberlin O, et al. (1996). Breast cancer and other second neoplasms after childhood hodgkin’s disease. N Engl J Med.
32 Smith-Bindman R, Chu PW, Miglioretti DL, et al. (2003). Comparison of screening mammography in the United States and the United Kingdom. JAMA.
33 Pisano ED, Gatsonis C, Hendrick E, et al. (2005). Diagnostic performance of digital versus film mammography for breast-cancer screening. N Engl J Med.
34 Kriege M, Brekelmans CTM, Boetes C, et al. (2004). Efficacy of MRI and mammography for breast-cancer screening in women with a familial or genetic predisposition. N Engl J Med.
35 Kuhl CK, Schrading S, Leutner CC, et al. (2005). Mammography, breast ultrasound, and magnetic resonance imaging for surveillance of women at high familial risk for breast cancer. J Clin Oncol.
36 Leach MO, Boggis CRM, Dixon AK, et al. (2005). Screening with magnetic resonance imaging and mammography of a U.K. population at high familial risk of breast cancer: a prospective multicentre cohort study (MARIBS). Lancet.
37 Lehman CD, Blume JD, Weatherall P, et al. (2005). Screening women at high risk for breast cancer with mammography and magnetic resonance imaging. Cancer.
38 Warner E, Plewes DB, Hill KA, et al. (2004). Surveillance of BRCA1 and BRCA2 mutation carriers with magnetic resonance imaging, ultrasound, mammography, and clinical breast examination. JAMA.
39 Saslow D, Boetes C, Burke W, et al. (2007). American Cancer Society guidelines for breast screening with MRI as an adjunct to mammography. CA Cancer J Clin.
40 U.S. Preventive Services Task Force. (2005). Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: recommendation statement. Ann Intern Med.
41 Flobbe K, Bosch AM, Kessels AG, et al. (2003). The additional diagnostic value of ultrasonography in the diagnosis of breast cancer. Arch Intern Med.
42 Bedrosian I, Mick R, Orel SG, et al. (2003). Changes in the surgical management of patients with breast carcinoma based on preoperative magnetic resonance imaging. Cancer.
43 Fajardo LL, Pisano ED, Caudry DJ, et al. (2004). Stereotactic and sonographic large-core biopsy of nonpalpable breast lesions: results of the Radiologic Diagnostic Oncology Group V study. Acad Radiol.
44 Pisano ED, Fajardo LL, Caudry DJ, et al. (2001). Fine-needle aspiration biopsy of nonpalpable breast lesions in a multicenter clinical trial: results from the radiologic diagnostic oncology group V. Radiology.
45 Silverstein MJ, Lagios MD, Recht A, et al. (2005). Image-detected breast cancer: state of the art diagnosis and treatment. J Am Coll Surg.
46 Krontiras H, De Los Santos JF, Bland KI. (2004). The breast: comprehensive management of benign and malignant disorders. Bland KI, Copeland EM, editors. The breast: comprehensive management of benign and malignant disorders.
47 Tripathy D. (2005). Targeted therapies in breast cancer. Breast.
48 Smith RA, Saslow D, Sawyer KA, et al. (2003). American Cancer Society guidelines for breast cancer screening: Update 2003. CA: Cancer J Clin.
49 National Cancer Institute. (2007). Screening mammograms: questions and answers.
50 American College of Obstetricians and Gynecologists (ACOG). (2003). ACOG practice bulletin. Obstet Gynecol.
51 Canadian Task Force on Preventive Health Care. (1998). Screening for breast cancer.
52 World Health Organization (WHO). Screening for breast cancer.
53 Canadian Task Force on Preventive Health Care. (2001). Breast self-examination to screen for breast cancer.
54 Baxter N. (2001). Preventive health care 2001 update: should women be routinely taught breast self-examination to screen for breast cancer?. CMAJ.
55 Day NE. (2005). Overdiagnosis and breast cancer screening. Breast Cancer Res.
56 Web of Science®. Software by Thomson.
57 Semiglazov VF, Manikhas AG, Moiseenko VM, et al. (2003). Rezul’taty prospektivnogo randomizirovannogo isledovaniia [Rossiia (Sankt-Peterburg)/VOZ] znacheniia samoobsledovaniia v rannem vyiavlenii raka molochnoi zhelezy. [Results of a prospective randomized investigation [Russia (St. Petersburg)/WHO] to evaluate the significance of self-examination for the early detection of breast cancer]. Vopr Onkol. Voprosy. onkologii. Vol.
58 National Cancer Institute. Breast Cancer Surveillance Consortium.
59 Ballard-Barbash R, Taplin SH, Yankaskas BC, et al. (1997). Breast Cancer Surveillance Consortium: a national mammography screening and outcomes database. Am J Roentgenol.
60 Detsky AS, Laupacis A. (2007). Relevance of cost-effectiveness analysis to clinicians and policy makers. JAMA.
61 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med.
62 R Development Core Team. (2006). R: A Language and Environment for Statistical Computing.
63 Thomas A, O’Hara B, Ligges U, et al. (2006). Making BUGS Open. R News.
64 D’Orsi CJ, Bassett LW, Berg WA. (2003). Follow-up and outcome monitoring. Breast imaging reporting and data system: ACR BIRADS.
65 Rosenberg RD, Yankaskas BC, Abraham LA, et al. (2006). Performance benchmarks for screening mammography. Radiology.
66 Moss SM, Cuckle H, Evans A, et al. (2006). Effect of mammographic screening from age 40 years on breast cancer mortality at 10 years’ follow-up: a randomised controlled trial. Lancet.
67 Bjurstam N, Bjorneld L, Warwick J, et al. (2003). The Gothenburg Breast Screening Trial. Cancer.
68 Nystrom L, Andersson I, Bjurstam N, et al. (2002). Long-term effects of mammography screening: updated overview of the Swedish randomised trials. Lancet.
69 Bjurstam N, Bjorneld L, Duffy SW, et al. (1997). The Gothenburg Breast Cancer Screening Trial: preliminary results on breast cancer mortality for women aged 39–49. J Natl Cancer Inst.
70 Habbema JD, van Oortmarssen GJ, van Putten DJ, et al. (1986). Age-specific reduction in breast cancer mortality by screening: an analysis of the results of the Health Insurance Plan of Greater New York study. J Natl Cancer Inst.
71 Miller AB, To T, Baines CJ, et al. (2002). The Canadian National Breast Screening Study-1: breast cancer mortality after 11 to 16 years of follow-up. A randomized screening trial of mammography in women age 40 to 49 years. Ann Intern Med.
72 Tabar L, Fagerberg G, Chen HH, et al. (1995). Efficacy of breast cancer screening by age. New results from the Swedish Two-County Trial. Cancer.
73 Tabar L, Vitak B, Chen HH, et al. (2000). The Swedish Two-County Trial twenty years later. Updated mortality results and new insights from long-term follow-up. Radiol Clin North Am.
74 Miller AB, To T, Baines CJ, et al. (2000). Canadian National Breast Screening Study-2: 13-year results of a randomized trial in women aged 50–59 years. J Natl Cancer Inst.
75 Pisani P, Parkin DM, Ngelangel C, et al. (2006). Outcome of screening by clinical examination of the breast in a trial in the Philippines. Int J Cancer.
76 National Cancer Institute. Cancer control research.
77 Boulos S, Gadallah M, Neguib S, et al. (2005). Breast screening in the emerging world: high prevalence of breast cancer in Cairo. Breast.
78 Thomas DB, Gao DL, Ray RM, et al. (2002). Randomized trial of breast self-examination in Shanghai: final results. J Natl Cancer Inst.
79 Semiglazov VF, Moiseyenko VM, Manikhas AG, et al. (1999). Interim results of a prospective randomised study of self-examination for early detection of breast cancer. Vopr Onkol.
80 Semiglazov VF, Moiseyenko VM, Bavli JL, et al. (1992). The role of breast self-examination in early breast cancer detection (results of the 5-years USSR/WHO randomized study in Leningrad). Eur J Epidemiol.
81 Hackshaw AK, Paul EA. (2003). Breast examination and death from breast cancer: a meta-analysis. Br J Cancer.
82 Kosters JP, Gotzsche PC. (2008). Regular self-examination or clinical examination for early detection of breast cancer. Cochrane Database Syst Rev.
83 Spelic DC. Dose and image quality in mammography: trends during the first decade of MQSA. U.S. Food and Drug Administration, 2003.
84 Brenner DJ, Sawant SG, Hande MP, et al. (2002). Routine screening mammography: how important is the radiation-risk side of the benefit-risk equation?. Int J Radiat Biol.
85 Heyes GJ, Mill AJ, Charles MW. (2006). Enhanced biological effectiveness of low energy X-rays and implications for the UK breast screening programme. Br J Radiol.
86 John EM, Phipps AI, Knight JA, et al. (2007). Medical radiation exposure and breast cancer risk: findings from the Breast Cancer Family Registry. Int J Cancer.
87 Law J, Faulkner K. (2006). Radiation benefit and risk at the assessment stage of the U.K. breast screening programme. Br J Radiol.
88 Sechopoulos I, Suryanarayanan S, Vedantham S, et al. (2008). Radiation dose to organs and tissues from mammography: Monte Carlo and phantom study. Radiology.
89 Miller D, Livingstone V, Herbison P. (2008). Interventions for relieving the pain and discomfort of screening mammography. Cochrane Database Syst Rev.
90 Brett J, Bankhead C, Henderson B, et al. (2005). The psychological impact of mammographic screening. A systematic review. Psychooncology.
91 Brewer NT, Salz T, Lillie SE. (2007). Systematic review: the long-term effects of false-positive mammograms. Ann Intern Med.
92 Mushlin AI, Kouides RW, Shapiro DE. (1998). Estimating the accuracy of screening mammography: a meta-analysis. Am J Prev Med.
93 Olivotto IA, Kan L, Coldman AJ. (1998). False positive rate of screening mammography. N Engl J Med.
94 Hofvind S, Thoresen S, Tretli S. (2004). The cumulative risk of a false-positive recall in the Norwegian Breast Cancer Screening Program. Cancer.
95 Elmore JG, Barton MB, Moceri VM, et al. (1998). Ten-year risk of false positive screening mammograms and clinical breast examinations. N Engl J Med.
96 Drossaert CHC, Boer H, Seydel ER. (2001). Does mammographic screening and a negative result affect attitudes towards future breast screening?. J Med Screen.
97 Joensuu H, Asola R, Holli K, et al. (1994). Delayed diagnosis and large size of breast cancer after a false negative mammogram. Eur J Cancer.
98 Yankaskas BC, Taplin SH, Ichikawa L, et al. (2005). Association between mammography timing and measures of screening performance in the United States. Radiology.
99 Moss S. (2005). Overdiagnosis and overtreatment of breast cancer: overdiagnosis in randomised controlled trials of breast cancer screening. Breast Cancer Res.
100 Paci E, Miccinesi G, Puliti D, et al. (2006). Estimate of overdiagnosis of breast cancer due to mammography after adjustment for lead time. Breast Cancer Res.
101 Paci E, Warwick J, Falini P, et al. (2004). Overdiagnosis in screening: is the increase in breast cancer incidence rates a cause for concern?. J Med Screen.
102 de Koning HJ, Draisma G, Fracheboud J, et al. (2006). Overdiagnosis and overtreatment of breast cancer: microsimulation modelling estimates based on observed screen and clinical data. Breast Cancer Res.
103 Olsen AH, Agbaje OF, Myles JP, et al. (2006). Overdiagnosis, sojourn time, and sensitivity in the Copenhagen mammography screening program. Breast J.
104 Duffy SW, Agbaje O, Tabar L, et al. (2005). Overdiagnosis and overtreatment of breast cancer: estimates of overdiagnosis from two trials of mammographic screening for breast cancer. Breast Cancer Res.
105 Yen MF, Tabar L, Vitak B, et al. (2003). Quantifying the potential problem of overdiagnosis of ductal carcinoma in situ in breast cancer screening. Eur J Cancer.
106 Zackrisson S, Andersson I, Janzon L, et al. (2006). Rate of over-diagnosis of breast cancer 15 years after end of Malmo mammographic screening trial: follow-up study. BMJ.
107 Zahl PH, Strand BH, Maehlen J. (2004). Incidence of breast cancer in Norway and Sweden during introduction of nationwide screening: Prospective cohort study. BMJ.
108 Fenton JJ, Barton MB, Geiger AM, et al. (2005). Screening clinical breast examination: how often does it miss lethal breast cancer?. J Natl Cancer Inst.
109 Tu SP, Reisch LM, Taplin SH, et al. (2006). Breast self-examination: self-reported frequency, quality, and associated outcomes. J Cancer Educ.
110 Badgwell BD, Giordano SH, Duan ZZ, et al. (2008). Mammography before diagnosis among women age 80 years and older with breast cancer. J Clin Oncol.
111 Galit W, Green MS, Lital KB. (2007). Routine screening mammography in women older than 74 years: a review of the available data. Maturitas.
112 Svendsen AL, Olsen AH, von Euler-Chelpin M, et al. (2006). Breast cancer incidence after the introduction of mammography screening: what should be expected?. Cancer.