# Acknowledgements

The authors acknowledge the contributions of the AHRQ Project Officer, Mary Barton, MD, MPP, and USPSTF Leads Russ Harris, MD, MPH; Allen Dietrich, MD; Carol Loveland-Cherry, PhD, RN; Judith Ockene, PhD, MEd; and Bernadette Melnyk, PhD, RN, CPNP/NPP. Andrew Hamilton, MLS, MS, conducted the literature searches and Sarah Baird, MS, managed the bibliography at the Oregon EPC. The authors thank the BCSC investigators, participating mammography facilities, and radiologists for the data used in this project. A list of the BCSC investigators and procedures for requesting BCSC data for research purposes are available at http://breastscreening.cancer.gov/. The authors also thank Patricia A. Carney, PhD; Steve Taplin, MD; Sebastien Haneuse, PhD; and Rod Walker, MS, for their direct work with this project.