# 3 Results

## Key Question 1a. Does screening with mammography (film and digital) or MRI decrease breast cancer mortality among women age 40–49 years and 70 years and older?

### Summary

No trials of screening average-risk women specifically evaluating the effectiveness of digital mammography or MRI have been published.

Since the 2002 review and meta-analysis of mammography screening trials,2 2 trials have been published that provide data for women age 40–49 years. The Age trial66 was designed specifically to determine the effectiveness of screening women age 40–49 years in the United Kingdom. Results indicate a relative risk for breast cancer mortality of 0.83 (95% confidence interval [CI], 0.66–1.04) for women randomly assigned to screening, and a number needed to invite for screening to prevent one breast cancer death over 10 years of 2,512 (95% CI, 1,149–13,544). For women age 40–49 years, data from the Age trial66 and updated results from the Gothenburg trial67 from Sweden (age 39–49 years) were combined in a meta-analysis with 6 trials included in the previous review. Results indicate a relative risk for breast cancer mortality of 0.85 (95% CrI, 0.75–0.96) for women randomly assigned to screening, and a number needed to invite for screening to prevent one breast cancer death of 1,904 (95 % CrI, 929–6,378) over multiple screening rounds that vary by trial.

For women age 70 years and older, the only data from screening trials comes from the Swedish Two-County trial. Results indicate a relative risk for breast cancer mortality of 1.12 (95% CI, 0.73–1.72)68 for women randomly assigned to screening. However, results are based on a small number of women (number needed to invite for screening not estimable from these data).

### Detailed Findings

The 2002 evidence review for the USPSTF included a meta-analysis of 7 randomized trials of mammography screening that were rated fair quality (Table 2).2 For women age 40–49 years, results of the 2002 meta-analysis indicated a relative risk for breast cancer mortality of 0.85 (95% CrI, 0.73–0.99) for women randomly assigned to screening over 14 years of follow-up, with a number needed to invite to screening of 1,792 (95% CrI, 764–10,540).2, 3

Table 2 Mammography Screening Trials Included in Meta-analysis

| | | | | | Screening Protocol
Study; Author, Year | Baseline Study Year | Setting or Population (screening, n; control, n) | Enrollment Age, y | Randomization Method | Study Group | Interval, mo | Round, n | View, n | Follow-up, y | USPSTF Quality Rating
Health Insurance Plan (HIP) of Greater New York; Habbema et al, 1986^70^ | 1963 | New York health plan members (30,239; 30,256) | 40–64 | Pairs of women stratified by age and family size were individually randomly assigned by drawing from a list. | Mammography + CBE vs. usual care | 12 | 4 | 2 | 18 | Fair
Canadian National Breast Screening Study-1 (CNBSS-1); Miller et al, 2002^71^ | 1980 | 15 centers in Canada, self-selected participants (25,214; 25,216) | 40–49 | Blocks were stratified by center and 5-year age group after CBE. | Mammography + CBE vs. usual care (all women prescreened and instructed in BSE) | 12 | 4–5 | 2 | 13 | Fair
Gothenburg^*^ Breast Screening trial; Bjurstam et al, 2003^67^ | 1982 | All women born from 1923–1944, living in Gothenburg, Sweden (20,724; 28,809) | 39–59 | Cluster, based on day of birth (1923–1935 cohort [18%]), and individual (1936–1944 cohort [82%]). | Mammography vs. usual care; control participants offered screening after5 years, completed screening at approximately 7 years. | 18 | 5 | 1–2 | 12 | Fair
Stockholm; Nystrom et al, 2002^68^ | 1981 | Residents of southeast greater Stockholm, Sweden (40,318; 19,943) | 40–64 | Individual, by day of month; screening to control group ratio is 2:1. | Mammography vs. usual care | 24–28 | 2 | 1 | 11.4 | Fair
Malmo; Nystrom et al, 2002^68^ | 1976–1978 | All women born from 1927–1945 living in Malmo, Sweden (21,088; 21,195) | 45–70 | Individual, within birth year. | Mammography vs. usual care; control participants offered screening after 14 years. | 18–24 | 9 | 1–2 | 11–13 15.5 | Fair
Swedish Two-County trial (2 trials); Nystrom et al, 2002^68^; Tabar et al, 1995^72^ | 1977 | From Ostergotland and Kopparberg counties in Sweden (77,080; 55,985) | 40–74 | Clusters, based on geographic units; blocks designed to be demographically homogeneous. | Mammography vs. usual care; control participants offered screening after 7 years. | 24–33 | 3 | 1 | 20 15.5 | Fair
Age trial;^*^ Moss et al, 2006^66^ | 1991 | 23 National Health Service breast screening units in England, Scotland, and Wales (53,884; 106,956) | 39–41 | Individual, stratified by general practitioner group with random number generation (1991–1992); randomization through Health Authority computer system (1992-onward). | Mammography vs. usual care; all women offered screening at age 50–52. | 12 | 4–6, varied by center | 2 | 10.7 | Fair

* New data since the previous recommendation.

Abbreviations: BSE=breast self examination; CBE=clinical breast examination; USPSTF=U.S. Preventive Services Task Force.

Since then, a randomized trial from the United Kingdom evaluating the effect of mammography screening specifically in women age 40–49 years has been published,66 as well as updated data from a previously reported Swedish trial67 which was included in the 2002 meta-analysis. Both of these trials meet USPSTF criteria for fair quality.

The Age trial included 160,921 women age 39–41 years who were randomly assigned between 1991–1997 to screening with annual mammography until age 48 years or a control group who received usual care.66 The prevalent screen was with 2-view mammography and subsequent screens were 1-view. Follow-up was conducted through the National Health Service central register, and the analysis included deaths from breast cancer during the trial and during follow-up using intention-to-screen analysis. Overall, 81% of women attended at least one screen, and the mean number of screens in the trial was 4.5. After 10.7 years of follow-up, the relative risk was 0.97 (95% CI, 0.89–1.04) for all-cause mortality, and 0.83 (95% CI, 0.66–1.04) for breast cancer mortality among women randomly assigned to screening. On the basis of the absolute reduction in breast cancer mortality among women randomly assigned to screening, the number needed to invite for screening to prevent one death from breast cancer over 10 years was 2,512 (95% CI, 1,149–13,544). The Age trial met USPSTF criteria for fair rather than good quality because contamination of groups was not described and 70% or fewer women attended screening across the trial.

A new publication provides additional follow-up data from the Gothenburg trial,67 rated fair quality in the 2002 report.2 The trial began in 1982 to evaluate mammography screening among the entire female population of Gothenburg, Sweden born between 1923–1944 (age 39–59 years).67, 69 The trial enrolled 21,904 women, and those randomly assigned to screening had mammography approximately every 18 months. The screening intervention included initial 2-view mammography followed by 1-view incident mammography unless 2-views were more appropriate based on the prevalence screen. The control group received usual care. Women with breast cancer diagnosed before randomization were excluded from the study. After the trial was closed, women in both groups were invited to regular screening.

Breast cancers among all women were ascertained through treatment centers, pathology laboratories, and the national cancer registration system, and follow-up was conducted until December 1996. Mortality from breast cancer was determined by local follow-up and the Swedish Cause of Death Register. Breast cancer mortality rates and risk ratios were calculated using 3 methods with 2 independent endpoint committees determining the cause of death for all women using blinded patient records. Attendance at the first screening round for the study group was above 80% and varied by age. Analysis was conducted using intention-to-screen analysis. Among women ages 39–49 at trial entry, the relative risk of breast cancer mortality using the follow-up method was 0.69 (95% CI, 0.45–1.05) among women randomized to screening after 13 years of follow-up.67

#### Meta-analysis for women age 39–49 years

Eight trials provided data for the meta-analysis, including 6 from the 2002 meta-analysis (Health Insurance Plan [HIP] of Greater New York,70 Canadian National Breast Screening Study-1 [CNBSS-1],71 Stockholm,68 Malmo,68 Swedish Two-County [2 trials]68, 72), and the 2 new trial reports (Age,66 Gothenburg67). All trials met criteria for fair quality.2 Combining results, the pooled relative risk for breast cancer mortality for women randomly assigned to mammography screening was 0.85 (95% CrI, 0.75–0.96), which indicates a 15% reduction in breast cancer mortality in favor of screening (Figure 2). This corresponds to a number needed to invite for screening to prevent one breast cancer death of 1,904 (95% CrI, 929–6,378) over multiple screening rounds that varied by trial (2–9 rounds), and 11–20 years of follow-up. A funnel plot did not indicate the presence of publication bias, and an L’Abbé plot did not reveal serious heterogeneity between the studies (Appendix C2). Results are consistent with the 2002 meta-analysis.

Figure 2 Pooled Relative Risk for Breast Cancer Mortality from Mammography Screening Trials for Women Age 39 to 49 Years

Sensitivity analysis excluded the HIP trial70 because it was conducted more than 30 years ago and used outdated technology and the CNBSS-1 trial71 because it enrolled prescreened volunteers rather than unselected samples. Exclusion of these trials did not significantly influence the results (Table 3).

Table 3 Sensitivity Analysis: Meta-analysis of Screening Trials of Women Age 39 to 49 Years

Meta-analysis | Differences from Updated Meta-analysis^*^ | Number of trials | RR for Breast Cancer Mortality (95% CrI) | NNI to Prevent 1 Breast Cancer Death (95% CrI)
2002 Review2,3 | Does not include Age trial; includes older Gothenburg data | 7 | 0.85 (0.73–0.99) | 1,787 (715–10,737)
Update | | 8 | 0.85 (0.75–0.96) | 1,904 (929–6,378)
Sensitivity analysis #1 | Excludes HIP trial | 7 | 0.87 (0.75–0.98) | 2,253 (1,016–10,927)
Sensitivity analysis #2 | Excludes CNBSS-1 trial | 7 | 0.82 (0.72–0.94) | 1,677 (881–4,915)
Sensitivity analysis #3 | Excludes HIP and CNBSS-1 trials | 6 | 0.83 (0.72–0.96) | 1,877 (904–8,969)

* Trials and their acronyms are discussed in the text.

Abbreviations: CNBSS-1=Canadian National Breast Screening Study-1; CrI=credible interval; HIP=Health Insurance Plan of Greater New York; NNI=number needed to invite to screening; RR=relative risk.

#### Results for women age 70–74 years

The 2002 evidence review did not report results specifically for women age 70–74 years, but included them in a larger age category of women age 65–74 years.2 Results for women age 70 or older were confined to data from the Swedish Two-County trial68 (Ostergotland) of women age 70–74 years, precluding meta-analysis. These results indicate a relative risk for breast cancer mortality of 1.12 (95% CI, 0.73–1.72),68 based on a more conservative determination of cause of death than previous reports.73 The absolute numbers of deaths were not reported, the number of enrolled women was low (approximately 5,000 in each group), and an estimate of number needed to screen was not estimable. Results are summarized in Table 4.

Table 4 Summary of Screening Trials of Women Age 70 to 74 Years

Study; Author, Year | Trials Included^*^ | Number of trials | RR for Breast Cancer Mortality (95% CrI) | NNI to Prevent 1 Breast Cancer Death (95% CrI)
2002 Review (age 65–74 y); Humphrey, et al, 2002^2,3^ | Malmo and Swedish 2-County trials | 2 | 0.78 (0.62–0.99) | Not available
Swedish 2-County trial(age 70–74 y); Nystrom et al, 2002^68^ | Swedish 2-County trial least biased estimate using Ostergotland only | 1 subgroup of1 trial | 1.12 (0.73–1.72) | Not available

* Trials and their acronyms are discussed in the text.

Abbreviations: CrI=confidence interval for individual trial results and credible interval for meta-analysis results; NNI=number needed to invite to screening; RR=relative risk.

#### Comparisons with meta-analyses for women age 50–59 years and 60–69 years

Meta-analyses of trials for women age 50–59 years and 60–69 years included results of screening trials from the previous evidence review,2 and new data utilizing the follow-up method from the Gothenburg trial for women age 50–59 years.67 Not all of the published trials reported results by age and these could not be included in the meta-analysis.

For women age 50–59 years, 6 trials (CNBSS-1,^71^ Stockholm,68 Malmo,68 Swedish Two-County [2 trials],68 Gothenburg67) provided a pooled relative risk of 0.86 (95% CrI, 0.75–0.99) for breast cancer mortality for women randomly assigned to mammography screening. The number needed to invite for screening to prevent one breast cancer death was 1,339 (95% CrI, 322–7,455). Sensitivity analysis that excluded the CNBSS-1 resulted in a lower relative risk (0.81; 95% CrI, 0.68–0.95).

For women age 60–69 years, 2 trials (Malmo68 and Swedish Two-County [Ostergotland]68) provided a pooled relative risk of 0.68 (95% CI, 0.54–0.87) for breast cancer mortality for women randomly assigned to mammography screening. The number needed to invite for screening to prevent one breast cancer death was 377 (95% CrI, 230–1,050). Table 5 summarizes the meta-analysis results by age group.

Table 5 Pooled Relative Risk for Breast Cancer Mortality from Mammography Screening Trials for All Ages

Age, y | Trials Included, n^*^ | RR for Breast Cancer Mortality (95% CrI) | NNI to Prevent 1 Breast Cancer Death (95% CrI)
39–49 | 8 | 0.85 (0.75–0.96) | 1,904 (929–6,378)
50–59 | 6 | 0.86 (0.75–0.99) | 1,339 (322–7,455)
60–69 | 2 | 0.68 (0.54–0.87) | 377 (230–1,050)
70–74 | 1 | 1.12 (0.73–1.72) | Not available

* Trials and their acronyms are discussed in the text.

Abbreviations: CrI=confidence interval for individual trial results and credible interval for meta-analysis results; NNI=number needed to invite to screening; RR=relative risk.

## Key Question 1b. Does CBE screening decrease breast cancer mortality? Alone or with mammography?

### Summary

Few trials have evaluated the effectiveness of CBE in decreasing breast cancer mortality. In countries with widely practiced mammography screening, the use of CBE rests on its additional contribution to mortality reduction. The CNBSS-2 trial, which compares mammography with CBE versus CBE alone, showed no difference in mortality between the these two approaches.74

Three trials were designed to determine mortality outcomes by using CBE as the primary screening approach in countries with limited health care resources and without mammography screening programs (Table 6). The applicability of these trials to the United States is limited. A randomized trial comparing CBE with no screening was conducted in the Philipines.75 However, it was discontinued after one screening round because of poor community acceptance and is inconclusive. Two randomized trials comparing CBE with no screening are ongoing in India76 and Egypt.77

Table 6 Trials of Clinical Breast Examination and Breast Self Examination

Author, Year | Technique | Years | Setting or Population (screening, n; control, n) | Enrollment Age, y | Study Design | Intervention | Primary Outcomes | Secondary Outcomes | USPSTF Quality Rating
Pisani et al, 2006^75^ | CBE | 1996–1997 | Manila, Philippines; women living in the 12 central areas (151,168; controls not indicated) | 35–64 | RCT; block randomization of 202 health centers | 5 annual CBEs vs. usual care provided by nurses and midwives; CBE instruction using the MAMMACARE program | Breast cancer mortality not reported | * False-negative result: 80 of 133 diagnosed breast cancer cases; * False-positive result: 1,182 of 1,220 (96.9%) who completed follow-up | Poor; low participation, discontinued after1 round
Boulos et al, 2005^77^ | CBE/BSE | Pilot: 2000–2002 RCT: ongoing | Cairo, Egypt; women living in area around Italian Hospital (1,924; 1,927) | 39–65 | RCT; block randomization | CBE/BSE x2 (intervention) vs. CBE/BSE x1 (control) provided by female physicians; CBE training at Italian Hospital 2 months before study | Breast cancer incidence | Benign procedures: 1.2% after 1 round | Not rated (in progress)
National Cancer Institute76 | CBE/BSE | 1998 and ongoing | Mumbai, India; women living in area around Tata Memorial Hospital (150,000; controls not indicated) | 35–64 | RCT; cluster randomization | CBE + BSE + breast health education every 24 months for 4 rounds vs. education alone provided by trained female health workers; CBE training for5 months before trial | Breast cancer mortality | Not available | Not rated (in progress)
Thomas et al, 2002^78^ | BSE | 1989–2000 | Shanghai, China; women working at 1 of 519 factories (132,979; 133,085) | 31–65 | RCT; factories assigned to BSE or control group | BSE instruction with periodic reinforcement provided by trained former factory medical workers vs. no instruction; initial BSE instruction, follow- up sessions at 1 and 3 years, medically supervised BSE every 6 months | Breast cancer mortality: RR 1.03 (95% CI, 0.81–1.31) | Benign biopsies: RR 1.57(95% CI, 1.48–1.68) | Good
Semiglazov et al, 2003^57^ | BSE | 1985–2001 | St. Petersburg, Russia; women attending 1 of 28 clinics (58,985; 64,763) | 40–64 | RCT; cluster randomization | BSE instruction with refresher every 3 years provided by trained nurses or physicians vs. no instruction; providers received 3-hour training; instruction given to groups of 5–20 women | All cause mortality: RR1.07 (95% CI, 0.88–1.29) | Benign biopsies: RR 2.05(95% CI, 1.80–2.33) | Fair; low adherence, inconsistent data reported

* Risks not calculated because diagnostic follow-up for a positive CBE was 35%.

Abbreviations: BSE=breast self examination; CBE=clinical breast examination; CI=confidence interval; RCT=randomized controlled trial; RR=relative risk.

### Detailed Findings

The CNBSS-2 was designed to evaluate the benefit of adding mammography to breast cancer screening using CBE and BSE before mammography screening programs were instituted in Canada in 1988.^74^ From 1980 to 1985, 39,405 women, age 50–59 years, were randomly assigned to receive five annual screening visits consisting of mammography with CBE and BSE instruction versus CBE and BSE instruction without mammography. CBE was performed by a trained nurse or physician, and included visual inspection followed by a thorough 10-minute examination. With an average of 13 years follow-up through 1996, for cancers detected during the screening phase of the trial, the cumulative mortality rate ratio between study and control groups was 1.09 (95% CI, 0.78–1.51). For cancers detected through the follow-up period, the cumulative mortality rate ratio was 1.02 (95% CI, 0.78–1.33).

A trial conducted in Manila, Philippines was designed to assess the feasibility of mass screening by CBE in an urban population where mammography screening is not available and determine effects on breast cancer mortality.75 Women were assigned to receive either 5 annual CBEs conducted by trained nurses and midwives versus no active intervention on the basis of cluster randomization procedures determined by regional health center. CBE training used the MammaCare technique. The intervention was discontinued after the first round because of poor compliance with diagnostic follow-up evaluations. Only 35% of women with abnormal CBEs received further evaluations, primarily due to patient reticence. In the one round of screening conducted in 1996–1997, 151,168 women were offered CBE, 8% refused, 3,479 had abnormal CBEs, 1,293 had further testing, and 1,220 completed diagnostic workups. Of those completing diagnostic workups, 34 had breast cancer. This translates to sensitivity of 25.6% (34/133) and positive predictive value of 1.0% (34/3479). These values are considerably lower than reported in other studies and are influenced by high loss to follow-up. Mortality data were not reported.

A large population based trial has been ongoing at Tata Memorial Hospital in Mumbai, India since 1998.^76^ This randomized controlled trial was designed to evaluate low-technology methods for detecting common cancers in women. The study compares the efficacy of CBE, BSE, and health education conducted every 24 months versus health education alone for women living in the slums of Mumbai. A total of 152,239 participants ranging in age from 35–64 years have been randomly assigned according to 20 geographic residential areas. Examinations and education are performed by trained female health workers who underwent 5 months of training prior to the study; specifics of the training have not yet been described. In addition, women in the intervention group also receive visual cervical inspection for cervical cancer. Women in the intervention group will receive 4 rounds of screening and thereafter 8 years of surveillance for cancer incidence and mortality. As of 2004, the third intervention round was underway.

The Cairo Breast Screening Trial is currently underway at the Italian Hospital in Cairo, Egypt.77 A pilot study conducted in Cairo from May 2000 to June 2002, involving 5,000 women ages 35–64, was extended into this randomized trial of 10,000 women. The objective of the trial is to evaluate CBE and BSE in reducing mortality and morbidity in a defined geographical area of Cairo. As with the pilot study, trained social workers recruit women to the study by visiting their homes. Study participants are then invited to attend a primary health clinic for CBE as well as BSE instruction. Breast examinations are performed by female physicians who have been specially trained for 2 months prior to the study; the training technique was not specified in the report. To date, 10,000 women have been randomly assigned by cluster, however, results are not expected for several more years. In the pilot study, 4,116 women were invited to the health center for CBE, 2,481 attended, and of these 20 (8/1,000) were diagnosed with breast cancer. No mortality data were collected.

## Key Question 1c. Does BSE practice decrease breast cancer mortality?

### Summary

Although monthly BSE has been widely recommended to women for over 70 years, there have been few randomized controlled trials studying the effect of BSE on mortality. Preliminary results from trials in Russia and Shanghai were reviewed for the 2002 USPSTF report,2 and final results have since been published (Table 6). The Russian trial indicated that despite a significant increase in the number of cases of breast cancer detected when BSE instruction was provided, there was no reduction in all-cause mortality.57 The Shanghai trial showed no significant difference in breast cancer mortality as a result of BSE instruction.78 Three new meta-analyses of published trials and nonrandomized studies of BSE, which all include the Russian and Shanghai trials, also indicate no significant differences in breast cancer mortality between BSE and control groups.

### Detailed Findings

The effect of BSE on all-cause mortality in St. Petersburg, Russia, a community without routine mammography screening, was evaluated in a trial that met criteria for fair quality. In this trial, 123,748 women were assigned to receive either BSE training or no training on the basis of cluster randomization procedures determined by outpatient clinic.57 Women between the ages of 40–64 years were enrolled from 1985–1989. Breast cancer diagnoses were tracked until 1994 and mortality data were recorded through 2001. BSE instruction was provided by physicians and nurses who took a 3-hour training course prior to instructing groups of 5–20 women. In addition, a CBE was performed and the BSE method reviewed with each woman in the intervention group at annual clinic visits. Compliance with monthly BSE dropped considerably in the intervention group. Within 4 years of study onset only 18% of women reported performing monthly BSE, thus a BSE refresher session was incorporated every 3 years. Despite this, only 58% of women continued to practice monthly BSE. The relative risk for all-cause mortality for women randomly assigned to BSE was 1.07 (95% CI, 0.88–1.29). Breast cancer mortality for the 2 groups was not reported.

Various publications of this trial report different numbers. In the most recent publication, the total number of women enrolled in the study was reported as 123,748 (58,985 intervention and 64,763 control), whereas previous reports indicated 120,310 (60,221 intervention and 60,089 control), and 122,471 (57,712 intervention and 64,759 control).57, 79, 80 There is no explanation for these differing numbers. In addition, the number of women with benign biopsies and the number of women diagnosed with breast cancer do not add up to the number listed as having diagnostic biopsies in one of the key figures of the publication.57

A trial in Shanghai, China began in 1988 to evaluate whether instruction in BSE reduces breast cancer mortality.78 This trial met criteria for good quality. It included women factory employees in Shanghai between the ages of 31–64 years at the time of enrollment. Participants were assigned to receive either BSE instruction with periodic reinforcement versus no information on breast cancer screening (this group received instruction on low back injury prevention) on the basis of cluster randomization procedures determined by factory. BSE instruction was provided by trained former factory medical workers. It consisted of information on breast anatomy and cancer and teaching a 3-step BSE technique. At 1 and 3 years after initial instruction, reinforcement instruction sessions were provided. These included watching a video of BSE technique and practicing BSE under supervision by the trained medical workers. Additionally, women practiced supervised BSE at 1, 3, 6, and 9 months after initial instruction for the first year and every 6 months for the remaining 4 years. Only 10% of women attended fewer than 8 sessions. Actual practice of BSE by participants was not monitored.

In 11 years of follow-up, the rate of breast cancer was 6.5/1,000 women in the intervention group and 6.7/1,000 in the control group. The number of women considered to have died from breast cancer was equal in both groups (135/132,979 and 131/133,085, respectively; RR 1.03; 95% CI 0.81–1.31). Women who died of breast cancer were identified from a registry kept by the factory bureau, from records of other ongoing studies that used this trial cohort, and by active follow-up of all women known to have breast cancer. A physician reviewed records to ascertain the cause of death.

Three meta-analyses reviewed trials and observational studies of BSE.54, 81, 82 All 3 included the Russian and Shanghai trials, while 2 of the 3 also included a non-randomized trial from the United Kingdom and cohort and case-control trials. Results indicate no significant differences in breast cancer mortality between BSE and control groups.

## Key Question 2a. What are the harms associated with screening with mammography (film and digital) and MRI?

### MRI and digital mammography

No studies specifically evaluated the adverse effects of MRI or digital mammography when used for breast cancer screening in average-risk women.

### Radiation exposure

No studies directly measured the association between radiation exposure from mammography screening and breast cancer. The prevailing assumption has been that higher doses of high energy radiation induce cancers. Most x-rays are considered low-dose, low-energy radiation, with the mean glandular dose of bilateral, 2-view mammography averaging 7 mGy.83 For women age 40–49 years, yearly mammography screening for one decade with potential additional imaging would expose an individual to approximately 60 mGy, although these levels vary.25 For comparison, the typical breast dose of radiation to treat Hodgkin lymphoma is 21–25 Gy. However, there is concern that high cumulative doses of low energy radiation may induce more cancers in younger women or those with deleterious mutations such as BRCA1 and BRCA2.^84, 85^

A recently published systematic review included various types of studies of radiation exposure, such as radiation therapy, diagnostic radiation, and atomic bomb radiation, as the basis for predicting risk for inducing breast cancer.25 In studies of low-dose exposures, associations were inconsistent, whereas those of high-dose exposures indicated increased risk for breast cancer.25 The relative risks in studies of high-dose exposures ranged from 1.33–11.39 for exposures of 0.3–43.4 Gy, and were worse with higher doses of exposure, younger age at exposure, and longer follow-up.25 A case-control study, published since the systematic review, found that women exposed to diagnostic radiographs for screening or monitoring tuberculosis or pneumonia, or to therapeutic radiation for previous cancer, had increased risks for breast cancer.86

An analysis estimating the net benefits and harms of radiation exposure used data from the National Health Service Breast Screening Programme (NHSBSP) in the United Kingdom.87 In this analysis, assuming a linear dose-response relationship, the ratio of the number of lives saved to fatal breast cancers induced by radiation in women age 50–69 years was estimated at between 58–182.^87^

A recent simulation study designed to estimate the radiation doses received by organs of the body during standard two-view mammography of each breast found that the eye lens and lungs received the highest doses, although they were extremely low (4.4 μGy and 4.8 μGy, respectively).88

### Pain during procedures

Breast compression is used during mammography to create uniform density, reduce breast thickness, and flatten overlying skin and tissues, which contributes to sharper images and reduces the radiation dose. However, compression may add to the discomfort of mammography for some women. A recent systematic review of 22 studies of pain and discomfort associated with mammography indicated that many women experience pain during the procedure (range, 1–77%), but few would consider this a deterrent from future screening.25 In these studies, pain was associated with the stage of the menstrual cycle, anxiety, and the anticipation of pain.25 A recent review of trials of various interventions to reduce pain experienced during screening mammography included 7 studies. One study found that women experienced little pain in both the control and intervention groups, whereas in the other 6 studies the control groups experienced varying levels of pain.89

### Anxiety, distress, and other psychological responses

Studies have shown conflicting results about anxiety, distress, and other psychological responses that result from mammography screening. A systematic review of 54 studies evaluated the adverse psychological effects of mammography screening programs.90 Most were cohort studies, and 24 used validated psychological measurement scales to assess the effects of screening. Studies indicated that women who received clear communication of their negative mammography results had minimal anxiety.90 Results were mixed in studies of women who were recalled for further testing as a result of screening. In several studies, women had persistent anxiety, despite eventual negative results, whereas some showed only transient anxiety.90 Some studies showed no differences between anxiety levels of women who had initial negative screening mammography results and those who had false-positive results.90

A recent systematic review of 23 studies specifically examined the effects of false-positive screening mammography results on women age 40 years or older.91 Twenty-six studies were included: 9 on psychological distress, 11 on anxiety, and 6 on worry. False-positive mammography results had no consistent effect on most woman’s general anxiety and depression but increased breast cancer-specific distress, anxiety, apprehension, and perceived breast cancer risk for some.91

### False-positive and false-negative mammography results, additional imaging, and biopsies

Published data on false-positive and false-negative mammography results, additional imaging, and biopsies that reflect current practice in the United States are limited. False-positive mammography results subject women without cancer to additional imaging and biopsies. The probability of a false-positive screening mammography result was estimated at 0.9–6.5% in a meta-analysis of studies of sensitivity and specificity of mammography published 10 years ago.92 The cumulative risk for false-positive mammography results has been reported as 21–49% after 10 mammography examinations for women in general,93–95 and up to 56% for women age 40–49 years.95

Some women may have negative screening mammography results and be diagnosed with breast cancer shortly thereafter. For these women, screening failed to detect their cancer. Studies vary in how they determine false-negative rates,95 and rapidly progressing interval cancers may sometimes be incorrectly counted as false-negative mammography results depending on the time frame used. Few studies evaluate the effect of negative mammography results. Women stated that they would not delay evaluation of a new abnormal physical finding despite a previous negative mammography result in one survey.96 However, in another study of women with breast cancer, those with screen-detected cancer sought care earlier than women with prior negative mammography results.97

Unpublished data from the BCSC provide additional information on screening outcomes. Data for regularly screened women that are based on results from a single screening round indicate that rates of invasive breast cancer are lowest among women age 40–49 years (2.7 per 1,000 women per screening round) and increase with age (Table 7). Rates of DCIS are also lowest among women age 40–49 years (0.9 per 1,000 women per screening round), increase for women age 50–59 years (1.4 per 1,000 women per screening round), and remain at approximately this level for older women.

Table 7 Age-specific Screening Results from the Breast Cancer Surveillance Consortium

| Age, y
Screening Result | 40–49 | 50–59 | 60–69 | 70–79 | 80–89
Outcomes per Screening Round (per 1,000 screened), n *
False-negative mammography | 1.0 | 1.1 | 1.4 | 1.5 | 1.4
False-positive mammography | 97.8 | 86.6 | 79.0 | 68.8 | 59.4
Additional imaging | 84.3 | 75.9 | 70.2 | 64.0 | 56.3
Biopsy | 9.3 | 10.8 | 11.6 | 12.2 | 10.5
Screen-detected invasive cancer | 1.8 | 3.4 | 5.0 | 6.5 | 7.0
Screen-detected DCIS | 0.8 | 1.3 | 1.5 | 1.4 | 1.5
Yield of Screening per Screening Round, n
Patients undergoing mammography to diagnose 1 case of invasive breast cancer^†^ | 556 | 294 | 200 | 154 | 143
Patients undergoing additional imaging to diagnose 1 case of invasive breast cancer^‡^ | 47 | 22 | 14 | 10 | 8
Patients undergoing biopsy to diagnose 1 case of invasive breast cancer^§^ | 5 | 3 | 2 | 2 | 1.5

* Calculated from Breast Cancer Surveillance Consortium (BCSC) data of regularly screened women based on results from a single screening round. Rates of additional imaging and rates of biopsies may be underestimated due to incomplete capture of these exams by the BCSC.

† 1 per rate of screen detected invasive cancer.

‡ Rate of additional imaging per rate of screen-detected invasive cancer.

§ Rate of biopsy per rate of screen-detected invasive cancer.

Abbreviation: DCIS=ductal carcinoma in situ.

The BCSC data indicate that false-positive mammography results are common in all age groups. The rate is highest among women age 40–49 years (97.8 per 1,000 women per screening round) and declines with each subsequent age decade (Table 7). The rate of false-negative mammography results is lowest among women age 40–49 years (1.0 per 1,000 women per screening round) and increases slightly with subsequent age decades. Additional data about mammography test performance and its relationship with age and screening intervals has been analyzed by the BCSC. These data indicate that sensitivity, recall rates, and cancer detection rates increase as the months since previous mammography increase, whereas specificity decreases.98

In current practice, most women with an initial positive mammography result have additional imaging as a second step in the screening process. Rates of additional imaging and rates of biopsies may be underestimated by the BCSC data because of incomplete capture of these examinations. Rates of additional imaging are highest among women age 40–49 years (84.3 per 1,000 women per screening round) and decrease with age (Table 7). Biopsy rates are lowest among women age 40–49 years (9.3 per 1,000 women per screening round) and increase with age.

To consider the impact of screening, estimates of the numbers of women having mammography, additional imaging, and biopsies in order to diagnose one case of invasive breast cancer were calculated in 2 ways to account for missing values (assuming all women with missing values did not undergo procedures and assuming all did). This analysis does not include records that were unavailable to the BCSC. For every case of invasive breast cancer detected by mammography screening in women age 40–49 years, 556 women have mammography, 46–48 additional imaging, and 5–8 biopsies (Table 7, Figures 3, 4). Numbers decline with age for mammography and additional imaging, and only slightly for biopsies.

Figure 3 Number of Women Undergoing Routine Mammography to Diagnose 1 Case of Invasive Cancer, DCIS, or Either from the Breast Cancer Surveillance Consortium

This figure is a graph depicting the number of women who need to undergo screening to diagnose one case of breast cancer (either invasive cancer or ductal carcinoma in situ [DCIS]). The horizontal axis represents the women’s’ ages in years. The vertical axis represents the number of women screened, and it ranges from 0 to 1,400 in increments of 200. The data points connected by the dotted line correspond to the number of women who need to be screened to diagnose one case of DCIS. The line begins around age 40 with 1,250 women needing to be screened and gradually decreases to 690 women needing to be screened after the age of 70. The data points connected by the unbroken line correspond to the number of women who need to be screened to diagnose one case of invasive breast cancer. The line begins around age 40 with 556 women needing to be screened and gradually decreases to 148 women needing to be screened after the age of 70. The data points connected by the dashed line correspond to the number of women who need to be screened to diagnose either one case of invasive breast cancer or DCIS. The line begins around age 40 with 385 women needing to be screened and gradually decreases to 122 women needing to be screened after the age of 70.

Figure 4 Number of Women Undergoing Additional Imaging and Number Undergoing Biopsy to Diagnose 1 Case of Invasive Cancer from the Breast Cancer Surveillance Consortium

This figure is a graph depicting the number of women who need to undergo additional screening imaging (beyond film mammography) or biopsy to diagnose one case of invasive breast cancer. The horizontal axis represents the women’s’ ages in years. The vertical axis represents the number of women, ranging from 0 to 50 in increments of 10. The data points on the top of the graph connected by the unbroken line correspond to the number of women who need to undergo additional imaging to diagnose one case of invasive breast cancer, assuming any missing values represent women who did not undergo the procedure. The line begins around age 40 with 47 women needing additional imaging and gradually decreases to 9 women needing to have additional imaging to diagnose one more case of invasive cancer after the age of 70. The data points connected by the dashed line on the top of the graph correspond to the number of women who need to undergo additional imaging to diagnose one case of invasive breast cancer, assuming any missing values represent women who did undergo the procedure. The line begins around age 40 with 48 women needing additional imaging and gradually decreases to 10 women needing additional imaging after the age of 70. The data points on the bottom of the graph connected by the unbroken line correspond to the number of women who need to undergo biopsy to diagnose one case of invasive breast cancer, assuming any missing values represent women who did not undergo the procedure. The line begins around age 40 with 5 women needing biopsy and gradually decreases to 2 women needing biopsy after the age of 70. The data points connected by the dashed line on the bottom of the graph correspond to the number of women who need to undergo biopsy to diagnose one case of invasive breast cancer, assuming any missing values represent women who did undergo the procedure. The line begins around age 40 with 8 women needing biopsy and gradually decreases to 2 women needing biopsy after the age of 70.

### Overdiagnosis

Overdiagnosis refers to women receiving a diagnosis of invasive or noninvasive breast cancer who had abnormal findings on screening mammography that were unlikely to become clinically evident during their lifetimes in the absence of screening.55 Although it has been generally acknowledged that overdiagnosis is an adverse outcome of mammography screening, it is difficult to quantify. Studies of overdiagnosis are primarily based on data from screening trials and programs or on modeled data (Table 8).

Table 8 Studies of Breast Cancer Overdiagnosis

| | Rates of Overdiagnosis
Author, Year | Age, y | All Diagnoses | Invasive Cancer | Noninvasive Cancer | Method | Population
de Koning et al, 2006^102^ | 50–74 | 3% of incidence in screened population 8% screen-detected | NR | NR | Microsimulation model | Netherlands
Duffy et al, 2005^104^ | 40–74 | 1% of incidence in screened population | <1% | 1% (upper limit) | Multistate | Swedish Two-county trial
Duffy et al, 2005^104^ | 39–59 | 2% of incidence in screened population | 1.66% | 2% (upper limit) | Multistate | Gothenburg trial
Olsen et al, 2006^103^ | 50–71 | 7.8% of screen-detected, prevalence 0.5% of screen-detected, incidence 4.8% of incidence in screened population | 7.3% prevalence 0.5% incidence | 0.5% prevalence | Multistate | Copenhagen
Paci et al, 2004^101^ | 50–69 | 5% of incidence predicted without screening | 2% | 3% | Corrected for lead time vs. predicted | Florence
Paci et al, 2006^100^ | 50–74 | 4.6% of incidence predicted without screening | 3.20% | 1.40% | Corrected for lead time vs. predicted | Italy
Paci et al, 2006^100^ | 50–54 | 7.40% | NR | NR | Corrected for lead time vs. predicted | Italy
Paci et al, 2006^100^ | 55–59 | −0.60% | NR | NR | Corrected for lead time vs. predicted | Italy
Paci et al, 2006^100^ | 60–64 | 0.70% | NR | NR | Corrected for lead time vs. predicted | Italy
Paci et al, 2006^100^ | 65–69 | 5.70% | NR | NR | Corrected for lead time vs. predicted | Italy
Paci et al, 2006^100^ | 70–74 | 9.70% | NR | NR | Corrected for lead time vs. predicted | Italy
Svendsen et al, 2006^112^ | 50–69 | If overdiagnosis occurred it was limited | NR | NR | Comparison of incidence in screened vs. unscreened | Denmark
Yen et al, 2003^105^ | 40–69 | NR | NR | 37% of DCIS prevalence, 4% incidence | Six state Markov model | Swedish Two-county trial, United Kingdom, Netherlands, Australia, New York
Yen et al, 2003^105^ | 40–49 | NR | NR | 19%, 3% | Six state Markov model | Swedish Two-county trial
Yen et al, 2003^105^ | 50–59 | NR | NR | 23%, 4% | Six state Markov model | Swedish Two-county trial
Yen et al, 2003^105^ | 60–69 | NR | NR | 46%, 6% | Six state Markov model | Swedish Two-county trial
Zackrisson et al, 2006^106^ | 55–69 | 10% of incidence in control (unscreened) group | 7% | 3% | Comparison of incidence in screened vs. unscreened | Malmo trial
Zahl et al, 2004^107^ | 50–69 | NR | 30% incidence in screened population | NR | Changes in age-specific incidence rates associated with the introduction of screening programs | Norway and Sweden

Abbreviations: DCIS=ductal carcinoma in situ; NR=not reported.

A review of 8 randomized controlled trials of mammography screening compared the cumulative incidence of breast cancer in screening and control groups to determine the extent of overdiagnosis.99 In the 5 trials in which the control group was not offered screening, the absolute excess cumulative incidence of invasive and noninvasive breast cancer attributed to overdiagnosis among women randomly assigned to screening mammography ranged from 0.07–0.73 per 1,000 women-years. One trial was still in progress when these rates were reported.99

Eight studies report estimates of overdiagnosis using different methods. An analysis of data from women age 50–74 years with breast cancer compared outcomes before and after implementation of a screening program in Italy.100 Estimates of overdiagnosis were based on a model that assumed the mean sojourn time (time from onset of cancer to presence of symptoms) follows an exponential distribution and approximates lead time (time from screening to presence of symptoms) for screen-detected breast cancer. Using a mean sojourn time of 3.7 years, the rate of overdiagnosis for invasive and noninvasive breast cancer cases was calculated to be 4.6% (95% CI, 2–7%).100 When considered separately, overdiagnosis of invasive cancer cases was 3.2% (95% CI, 1%–6%). In another analysis using this model and data from a screening program in Italy in which roughly 60,000 women between 50–69 were invited for screening, overdiagnosis was estimated to be 5% of the cases diagnosed (2% for invasive cancer separately).101

A microsimulation model was used to estimate breast cancer incidence rates both in the absence of screening and as a consequence of a Dutch screening program.102 This model assumed 80% of women age 50–74 years would be screened every 2 years. It also assumed that 10% of invasive cancers are preceded by screen-detectable DCIS, and that the chance of DCIS progressing to clinically apparent disease is 90%. Estimates for overdiagnosis were 3% of the total breast cancer incidence and 8% of screen-detected cancers.102

An analysis of incidence data from the Swedish Two-County and Gothenburg screening trials used a model to estimate overdiagnosis.103 Both trials randomly assigned women to screening or no screening and control groups were eventually invited to screening at the end of the trials. Data from screen-detected and interval cancers were used to estimate parameters for the model, including annual incidence of preclinical screen-detectable cancers, sojourn time, and screening sensitivity. Overdiagnosis was 3% in the first screening round for the Swedish Two-County trial and 4.2% for the Gothenburg trial, and less than 0.5% for both trials in subsequent rounds.104 Estimates for the upper limit of DCIS overdiagnosis was 15–18% of all DCIS cases.104 In another analysis using a similar model and data from two rounds of a screening program in Denmark, rates of overdiagnosis were 7.8% in the first round and 0.5% in the second round.103

A Markov model was used to estimate the incidence of non-progressive or overdiagnosed DCIS with data from the Swedish Two-County trial and several screening programs.105 Pooling results from the various sources, the annual incidence rate of overdiagnosed DCIS was 1.11 per 100,000. On average, 37% of DCIS cases at prevalence and 4% at incidence screens were determined to be nonprogressive DCIS in this model.105

A comparison of breast cancer incidence rates between women age 55–69 years randomly assigned to screening and controls used data from the Malmo trial. Overdiagnosis was 4.5% (115/2525) of total breast cancer cases, with a 10% higher incidence in the screened group (7% for invasive cancer) 15 years after discontinuing screening.106

An estimate of overdiagnosis based on screening programs in Norway and Sweden was 30% of invasive cancer cases for women age 50–69 years, a much higher level than those described previously.107 This estimate was based on changes in age-specific incidence rates of invasive breast cancer associated with the introduction of screening programs. The difference between increased incidence among women age 50–69 years and decreased incidence among women age 70–74 years was used as the definition of overdiagnosis in this analysis.

## Key Question 2b. What are the harms associated with CBE?

Harms associated with CBE include false-positive results and subsequent diagnostic imaging or procedures, as well as psychological consequences such as anxiety, worry, and depression. The risk of a false-negative CBE and possible delay in breast cancer diagnosis also exists.

In the pilot study for the Cairo Breast Screening Trial of 2,481 women,77 291 women were referred for further testing due to an abnormal CBE. Of these, 80 had diagnostic imaging; 50 underwent diagnostic procedures, including FNA, nipple aspirate, or excisional biopsy; and 55 did not attend a follow-up visit.77 Twenty women were diagnosed with breast cancer (0.8%), and 30 had procedures with benign results (1.2%).

The Philippines CBE study ended prematurely due to poor participant attendance for diagnostic work-ups although false-positive and false-negative results were reported for women who completed them.75 Of the 138,392 women examined, 3,479 had abnormal CBEs and 1,220 completed diagnostic workups. Of these women, 34 (3%) had cancer, 563 (46%) had no detectable abnormalities, and 623 (51%) had biopsy results that were benign.

A community based case-control study of 485 women who received CBE within one year prior to breast cancer diagnosis and within 15 years of breast cancer death revealed that CBE failed to detect breast cancer in 4 out of 5 women.108 These cases may have represented false-negative CBEs or aggressive breast cancers arising between routine examinations.

## Key Question 2c. What are the harms associated with BSE?

Harms resulting from BSE are similar to those with CBE.

In the Russian57 and Shanghai78 trials, more women randomly assigned to BSE had benign biopsy results than women in the control groups (RR 2.05 [95% CI, 1.80–2.33] for women in the Russian trial and 1.57 [95% CI, 1.48–1.68] for women in the Shanghai trial).

A retrospective cohort study of 27,421 women age 40 year or older in the United States indicated that those performing more frequent or longer durations BSEs were more likely than women with less frequent and shorter BSEs to have diagnostic mammography or ultrasonography.109

Contrary to the Russian and Shanghai trials, there was no significant association between BSE and biopsy rates in this study.