# 1 Introduction

## Purpose of Review and Prior USPSTF Recommendation

This systematic evidence review is prepared for the U.S. Preventive Services Task Force (USPSTF) to update its previous recommendation on breast cancer screening for average-risk women.1 In 2002, based on results of a systematic evidence review,2, 3 the USPSTF recommended screening mammography, with or without clinical breast examination (CBE), every 1–2 years for women age 40 years and older. The USPSTF concluded that the evidence was insufficient to recommend for or against routine CBE alone to screen for breast cancer. The USPSTF also concluded that the evidence was insufficient to recommend for or against teaching or performing routine breast self examination (BSE). (See Appendix A1 for abbreviations.)

The USPSTF made additional conclusions about the state of the evidence in 2002 including:

- The relative risk of breast cancer death for women randomized to mammography screening versus no mammography screening based on a meta-analysis of 8 trials was 0.84 (95% credible interval [CrI], 0.77–0.91).
- Older women have a higher risk of developing and dying from breast cancer, but they also have a higher chance of dying from other causes.
- Reductions in breast cancer mortality in studies using mammography alone versus studies using mammography and CBE are comparable. There is no direct evidence that CBE or BSE decreases mortality.
- Mammography sensitivity and specificity are higher than CBE sensitivity and specificity (77–95% and 94–97% versus 40–69% and 88–99%, respectively).
- The positive predictive value of mammography increases with age and with a family history of breast cancer.
- The benefit of regular mammography increases with age, while harms from mammography decrease with age. However, the age at which the benefits outweigh the harms is subjective. Biennial mammography is as effective as annual mammography for women age 50 years or older. Breast cancer progresses more rapidly in women younger than 50, and sensitivity of mammography is lower in this group. A clear advantage of annual mammography screening for women in this age group was not found.
- The majority of abnormal mammography examinations or CBEs are false-positives. Screening may increase the number of women undergoing treatment for lesions that might not pose a threat to their health.

Several evidence gaps were identified including:

- Definitive estimates of the proportion of benefits due to screening before age 50 years cannot be made. The cost-effectiveness of screening women younger than age 50 years is unknown.
- The age at which it is appropriate to cease breast cancer screening is unknown, as are the benefits of screening women older than 69 years.
- No screening trial has examined the benefits of CBE alone compared to no screening. The benefits of CBE as well as possible benefits of BSE are unknown.
- The magnitude of the harms associated with all methods and ages is unclear.
- None of the trials conducted to date has directly addressed the issue of the appropriate screening interval among any age group.

This update focuses on critical evidence gaps that were unresolved at the time of the 2002 recommendation, including the effectiveness of mammography in decreasing breast cancer mortality among average-risk women age 40–49 years and 70 years and older; the effectiveness of CBE and BSE in decreasing breast cancer mortality among women of any age; and harms of screening with mammography, CBE, and BSE. Studies of the cost-effectiveness of screening are described in the Appendix. Performance characteristics of screening methods (e.g., sensitivity and specificity) were previously reviewed and are not included in this update.

## Condition Definition

Breast cancer is a proliferation of malignant cells that arises in the breast tissue, specifically in the terminal ductal-lobular unit. The term “breast cancer” represents a continuum of disease, ranging from noninvasive to invasive carcinoma.4 Screening techniques may detect any of these disease entities as well as noncancerous lesions such as benign breast cysts.

Noninvasive carcinoma consists of epithelial proliferation confined to either the mammary duct, as with ductal carcinoma in situ (DCIS), or to the lobule, as with lobular carcinoma in situ (LCIS). Because noninvasive or in situ lesions do not invade the surrounding stroma, they cannot metastasize. LCIS is generally not considered a precursor lesion for invasive lobular carcinoma, but believed to be a marker for increased risk of invasive ductal or lobular breast cancer development in either breast.5 However, DCIS is thought to be a precursor lesion to invasive ductal carcinoma. DCIS consists of a heterogeneous group of lesions with varying clinical behavior and pathologic characteristics. Common subtypes of DCIS include cribriform, comedo, micropapillary, papillary, and solid.6

Unlike noninvasive lesions, invasive breast cancers invade the basement membrane into the adjacent stroma, and therefore, have metastatic potential. The most common sites of metastasis include adjacent lymph nodes, lung, brain, and bone.4 Approximately 70–80% of invasive breast cancers are invasive or infiltrating ductal carcinoma and approximately 10% are invasive lobular cancers.4 Some other less common histologic subtypes of invasive breast cancer include apocrine, medullary, metaplastic, mucinous, papillary, and tubular.4

## Prevalence and Burden of Disease

Breast cancer is the most frequently diagnosed non-cutaneous cancer and the second leading cause of cancer deaths after lung cancer among women in the United States.7 In 2008, an estimated 182,460 cases of invasive and 67,770 cases of noninvasive breast cancer were diagnosed, and 40,480 women died of breast cancer.8

The incidence of breast cancer increases with age. Based on Surveillance Epidemiology and End Results (SEER) data from 2002–2004, the National Cancer Institute (NCI) estimates that 14.7% of women born in the United States today will develop breast cancer in their lifetimes, 12.3% with invasive disease.9 The probability of a woman developing breast cancer in her forties is 1 in 69, in her fifties 1 in 38, and in her sixties 1 in 27.^10^ Although the incidence rate of breast cancer has increased since the 1970s and 1980s, recent data suggest that it may have stabilized between 2001–2003. Overall, the incidence rate declined by 6.7% between 2002–2003 from 137.3 to 124.2 per 100,000 women.11 Age-adjusted incidence rates for breast cancer also declined each year during 1999–2003.^12^ This trend may be attributed to discontinuation of menopausal hormone therapy,11, 13 and a plateau or decline in use of screening mammography.14

Breast cancer mortality has decreased since 1990 at a rate of 2.3% per year overall.15, 16 Women age 40–50 years had a decline in breast cancer mortality of 3.3% per year. An evaluation of mortality trends from 1990 through 2000 from 7 studies attributed 28–65% of the decline to mammography screening, while the remainder of the decline was due to improved adjuvant treatments.17

## Etiology and Natural History

The etiology of breast cancer is still largely unknown, although it is believed that breast cancer development is due to aberrations in cell cycle regulation. Current research focuses on clarifying the role of both inherited and acquired mutations in oncogenes and tumor suppressor genes and the consequences these mutations may have on the cell cycle, as well as investigating various prognostic biological markers. The contribution external influences, such as environmental exposures, may have on regulatory genes is unclear. Currently, no single environmental or dietary exposure has been found to cause a specific genetic mutation that causes breast cancer. Lifetime exposure to both endogenous and exogenous hormones has been hypothesized to play a role in tumorigenesis and growth. Other potential causes of breast cancer include inflammation and virally mediated carcinogenesis.18

The significance of DCIS as a precursor lesion is unclear. With the widespread use of screening mammography in the United States, nearly 90% of DCIS cases are now diagnosed only on imaging studies, most commonly by the presence of microcalcifications. These represent approximately 23% of all breast cancer cases (not including LCIS).7 Although it is the most common type of noninvasive breast cancer, its natural history is poorly understood.

Whether DCIS in an obligate precursor to invasive ductal cancer, or if both entities derive from a common progenitor cell line is unclear. While some evidence suggests that DCIS and invasive ductal cancer may diverge from common progenitor cells,19 indirect evidence supports the theory of linear progression through stages, from atypical hyperplasia to DCIS to invasive cancer.19 Further evidence supports a hybrid of these two theories. Through an accumulation of genetic changes, atypical hyperplasia progresses to low grade DCIS, followed by high grade DCIS, and from any point in this progression, the step to invasive cancer occurs.20 Consistent with all three theories is evidence from studies in which DCIS coexists with adjacent invasive cancer in pathology specimens, as well as studies showing that at least 50% of local recurrences after treatment for DCIS are invasive cancers.21 In both cases, DCIS and invasive ductal cancer breast tissues frequently share morphological and molecular characteristics, including grade and estrogen receptor status and HER2/neu oncogene expression.21–23

Several recent reviews include older studies of untreated DCIS cases that were diagnosed on retrospective review of previously reported benign biopsy specimens.21, 24, 25 In these studies, untreated DCIS progressed to invasive cancer in 14–53% of cases over mean periods of 8–22 years. In a case series of 775 women diagnosed with DCIS who underwent breast conserving therapy, 66 eventually developed invasive cancer, and 71 developed recurrent DCIS at a mean follow-up of 5.4 years.26

## Risk Factors

Although several risk factors have been associated with breast cancer, most cases occur in women with no specific risk factors other than sex and age. Family history of breast and ovarian cancer are strong risk determinants however, with the number of relatives, closeness of the degree of relationships, and ages of diagnosis of affected family members contributing. For example, two or more relatives with breast or ovarian cancer, a relative with both breast and ovarian cancer, and a relative diagnosed younger than age 50 years all substantially increase risk.27 Hereditary mutations in tumor suppressor genes BRCA1 and BRCA2 increase individual risks for breast cancer 60–85% and may be identified in 5–10% of all breast cancer cases.28

Personal history of noninvasive breast cancer or previous abnormal breast biopsy containing LCIS or atypical ductal or lobular hyperplasia increase risk for invasive breast cancer. Extensive mammographic breast density is also associated with increased risk of breast cancer.29 Endogenous estrogen exposure is associated with increased risk; thus early menarche, late menopause, nulliparity, and obesity are implicated as risk factors. Use of combination postmenopausal hormone therapy (estrogen and progestin) was associated with an increased relative risk for breast cancer compared to placebo in the Women’s Health Initiative (WHI) randomized controlled trial.30

Environmental exposures are believed to increase risk. A history of chest radiation therapy, such as treatment for Hodgkin lymphoma, increases the risk for developing breast cancer.31 However, current approaches may not pose this same magnitude of risk.31 Use of alcohol at levels more than 1–2 drinks per day is also associated with increased breast cancer.30

Empiric models have been developed in attempts to predict risk of developing cancer for individual women (e.g., BRCAPRO, Gail, Claus, and Tyrer-Cuzick).27 All of these models incorporate age and number of first-degree relatives with breast cancer into their calculations, but vary in their complexity. However, these models have been shown to perform better in predicting population risk than in predicting an individual’s risk and it is unclear how to apply these models to screening.27

## Current Clinical Practice

### Screening

Breast cancer has a known asymptomatic phase that can be identified with mammography. Mammography screening is sensitive (77–95%), specific (94–97%), and acceptable to most women.2 Breast cancer can be more effectively treated in an earlier stage than when clinical signs and symptoms present, justifying early detection efforts. Randomized trials of screening mammography demonstrate reduced mortality with screening.2

Screening mammography practices in the United States differ from those in the United Kingdom or Europe. A comparison between outcomes in the United States, using data from the Breast Cancer Surveillance Consortium (BCSC) and the National Breast and Cervical Cancer Early Detection Program, and the United Kingdom, using data from the National Health Service Breast Screening Program, indicated that recall and open surgical biopsy rates were twice as high in the United States while cancer detection rates were similar.32 These outcomes may result from differences in health care delivery systems, organization of screening programs, training and practices of radiologists, quality assurance standards, and malpractice climates.

Mammography is performed using either plain film or digital technologies, although the shift to digital is ongoing. A large comparison study of film and digital mammography was conducted in a screening population of women in the United States and Canada. Results indicated that the overall diagnostic accuracy of digital and film mammography was similar, although digital was more accurate in women under age 50 years, women with radiographically dense breasts, and premenopausal women.33

In the past, contrast enhanced magnetic resonance imaging (MRI) was used to evaluate women already diagnosed with breast cancer. In studies of MRI and mammography in high-risk women without cancer, sensitivities of MRI ranged between 71–100%, and specificities between 81–97%.34–38 The American Cancer Society (ACS) now recommends screening MRI for certain high-risk groups, including women with BRCA1 or BRCA2 mutations, women with greater than 20% lifetime risk of developing breast cancer as defined by risk prediction models based on family history of breast or ovarian cancer, and women who have been treated for Hodgkin lymphoma.39 Use of MRI for screening women at average risk for developing breast cancer is not recommended.39 Currently, there are no studies investigating MRI use in average-risk women and none showing decreased mortality with MRI screening.

The effectiveness of CBE in decreasing breast cancer mortality has been controversial. This procedure is relatively easy and inexpensive, and therefore, an attractive form of screening. However, few studies of effectiveness compare CBE to no intervention, and no studies compare its use in combination with mammography to mammography alone. Sensitivity of CBE ranges from 40–69%, specificity from 88–99%, and positive predictive value from 4–50%, using mammography and interval cancer as the criterion standard.2

The usefulness of BSE in decreasing breast cancer mortality has been recently questioned. Sensitivity of BSE ranges from 12–41% when compared with CBE and mammography and is age dependent. Specificity of BSE remains uncertain. Preliminary results from trials in Russia and China, as well as final results from a non-randomized trial in the United Kingdom indicated no mortality benefit to BSE.2

Strategies for high-risk women differ from those for average-risk women and may include genetic counseling and testing,27, 40 earlier and more frequent mammography, and use of additional modalities such as MRI and ultrasound. These have been evaluated in a separate report for the USPSTF.27

### Diagnosis

If a woman has an abnormal mammographic finding on screening, or a concerning finding on CBE or BSE, additional imaging and biopsy may be recommended. Additional imaging may consist of diagnostic mammography or mammography done with additional or special views (e.g., magnification, spot compression, and additional angles), a targeted breast ultrasound, or breast MRI.41, 42 These additional imaging studies may help classify the lesion identified on screening as a benign or suspicious finding in order to determine the need for tissue sampling.

If tissue sampling is recommended, a biopsy is performed. The type of biopsy is based on the characteristics of the lesion (e.g., palpable versus nonpalpable; solid mass versus microcalcifications), as well as patient and physician preferences. Current biopsy techniques include fine-needle aspiration (FNA), stereotactic core biopsy (for nonpalpable, mammographic lesions), ultrasound-guided or MRI-guided core biopsy, non-image-guided core biopsy (for palpable lesions), incisional biopsy, or excisional biopsy. These techniques vary in the level of invasiveness and amount of tissue acquired, impacting their yield and patient experience. Although more invasive, core biopsies, as well as incisional and excisional biopsies, offer the pathologist a sample with intact cellular architecture, and thereby allow additional pathologic examination of the breast cancer. Testing includes examination of cellular receptors (e.g., estrogen/progesterone receptor, HER2/neu receptor), as well as identification of tumor type and grade.43, 44 This additional information contributes to appropriate treatment planning for a patient who is newly diagnosed with breast cancer, and allows for definitive surgery to be completed with a single-stage procedure.45

### Treatment

Currently, treatment for breast cancer in the United States is often multimodal, requiring a combination of therapies including surgery, chemotherapy, hormonal therapy, and radiation. The contemporary view of breast cancer as a systemic disease has lead to a shift to less radical surgery over time. Large randomized controlled trials conducted in the 1980s found no difference in overall survival between breast conservation therapy (lumpectomy followed by radiation) and mastectomy. These findings supported the use of breast conservation as an acceptable surgical treatment for breast cancer.46 As more knowledge is gained regarding genetic and molecular profiles of individual breast cancers, greater emphasis is being placed on targeted therapy. The goal is to tailor therapy to each particular patient in order to maximize benefits and minimize toxicity.47 Because there are now often multiple options for treatment, patient preferences play a large role in determining the treatment course.

## Screening Recommendations of Other Groups

### Mammography

Most organizations in the United States support the use of mammography for average-risk women age 40 years and older; however, differences include the recommended starting age for screening and the screening interval (Table 1).

Table 1 Breast Cancer Screening Recommendations for Average-Risk Women

| American Academy of Family Physicians (AAFP) | American Cancer Society (ACS) | American College of Obstetricians and Gynecologists (ACOG) | American College of Physicians (ACP)^*^ | American College of Preventive Medicine (ACPM) | American College of Radiology (ACR) | American Medical Association (AMA) | Canadian Task Force on Preventive Health Care (CTFPHC) | National Cancer Institute (NCI) | National Comprehensive Cancer Network (NCCN) | US Preventive Services Task Force (USPSTF) | World Health Organization (WHO)
Mammography
Age 40+, annual | | x | | | | x | x | | | x
Age 40+, every 1–2 years | x | | | | | | | x | x | | x
Age 40–49, every 1–2 years | | | x
Age 50+, annual | | | x
Age 50–69, annual or biennial | | | | | x | | | | | | | x
Age 70+ | | | | | x
MRI
Not recommended for average risk women | | x | | | | | | | | x
CBE
Age 40+, annual | | x | x | | | | | | | x
Periodic evaluation (1–3 years), ages vary | | x | | | | | x | x ages 50–69 | x | x
Insufficient evidence | | | | | | | | | | | x
Not recommended | | | | | | | | | | | | x
BSE
Recommended | | | x | | | | x | | | x
Insufficient evidence | x | x | | | | | | | x | | x
Not recommended | | | | | | | | x | | | | x

* Suggests periodic, individualized screening for women age 40–49 years.

Abbreviations: BSE=breast self examination; CBE=clinical breast examination; MRI=magnetic resonance imaging.

### Clinical Breast Examination

The ACS recommends that women age 20–39 years undergo CBE every 3 years, and annually after age 40.^48^ The NCI states that fair evidence shows that CBE reduces breast cancer mortality.49 The American College of Obstetricians and Gynecologists (ACOG) recommends that all women have CBE annually as part of the physical examination.50 The Canadian Task Force on Preventative Health Care (CTFPHC) recommends CBE for women age 50–69 years and makes no recommendation for or against CBE for women age 40–49 years.51 The World Health Organization (WHO) does not recommend screening by CBE, but states CBE should be offered to women who present to a primary health care center for other medical reasons.52

### Breast Self Examination

Since 2001, several organizations have changed their recommendations about BSE as a routine screening modality. The ACS changed its recommendation to make BSE optional as a screening method.48 The NCI states that teaching BSE does not reduce breast cancer mortality.49 The CTFPHC now recommends against its use, stating there is fair evidence of no benefit and good evidence of harm.53, 54 The WHO advises that national cancer control programs should not recommend screening by BSE.52 ACOG advises that despite a lack of definitive evidence for or against BSE, it can still be recommended.50