# Appendix B Detailed Methods

## Appendix B1. Literature Search Strategies

### Screening

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
Search Strategy:
1 | ((Breast$ or mammary) adj3 (Neoplas$ or tumor$ or cancer$ or carcinom$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2 | (screen$ or (routine$ adj3 (test$ or check$ or diagnos$ or detect$))).mp.
3 | ((clinical$ or physical$) adj3 (exam$ or detect$ or diagnos$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4 | 2 or 3
5 | 1 and 4

Database: EBM Reviews - Cochrane Database of Systematic Reviews
Search Strategy:
1 | ((Breast$ or mammary) adj3 (Neoplas$ or tumor$ or cancer$ or carcinom$)).mp. [mp=title, abstract, full text, keywords, caption text]
2 | (screen$ or (routine$ adj3 (test$ or check$ or diagnos$ or detect$))).mp.
3 | ((clinical$ or physical$) adj3 (exam$ or detect$ or diagnos$)).mp. [mp=title, abstract, full text, keywords, caption text]
4 | 2 or 3
5 | 1 and 4
6 | ((Breast$ or mammary) adj3 (Neoplas$ or tumor$ or cancer$ or carcinom$)).kw.
7 | 1 not 6
8 | 4 and 6

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp Breast Neoplasms/
2 | exp neoplasms/di
3 | exp breast/
4 | 2 and 3
5 | 1 or 4
6 | exp mass screening/
7 | (screen$ or (routine$ adj3 (test$ or check$ or diagnos$ or detect$))).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
8 | 6 or 7
9 | 5 and 8
10 | exp Physical Examination/
11 | exp Breast/
12 | exp Breast Neoplasms/
13 | 11 or 12
14 | 10 and 13
15 | exp Mammography/
16 | 9 and 14
17 | 9 and 15
18 | exp Mortality/
19 | mo.fs.
20 | 18 or 19
21 | 16 and 20
22 | 17 and 20
23 | 21 or 22
24 | limit 23 to (humans and english language)
25 | limit 24 to (guideline or meta analysis or randomized controlled trial)
26 | (random$ or rct).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
27 | 24 and 26
28 | (meta-analy$ or metaanaly$ or (systematic$ adj10 review$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
29 | 24 and 28
30 | 25 or 27 or 29
31 | 24 not 30

### Digital Mammography

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
Search Strategy:
1 | ((digital$ or computer$) adj7 mammogra$).mp.
2 | from 1 keep 1–37

Database: EBM Reviews - Cochrane Database of Systematic Reviews
Search Strategy:
1 | ((digital$ or computer$) adj7 mammogra$).mp.
2 | from 1 keep 1

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp Breast Neoplasms/
2 | exp neoplasms/di
3 | exp breast/
4 | 2 and 3
5 | 1 or 4
6 | exp mass screening/
7 | (screen$ or (routine$ adj3 (test$ or check$ or diagnos$ or detect$))).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
8 | 6 or 7
9 | 5 and 8
10 | exp Physical Examination/
11 | exp Breast/
12 | exp Breast Neoplasms/
13 | 11 or 12
14 | 10 and 13
15 | exp Mammography/
16 | 9 and 14
17 | 9 and 15
18 | 16 or 17
19 | (digital$ adj7 mammogra$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
20 | exp Image Processing, Computer-Assisted/
21 | exp Mammography/
22 | 20 and 21
23 | 19 or 22
24 | 8 and 23
25 | limit 24 to english language
26 | from 25 keep 1–395

### MRI

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
Search Strategy:
1 | ((Breast$ or mammary) adj3 (Neoplas$ or tumor$ or cancer$ or carcinom$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2 | (mri or magnetic resonance imag$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3 | 1 and 2
4 | from 3 keep 1–29

Database: EBM Reviews - Cochrane Database of Systematic Reviews
Search Strategy:
1 | ((Breast$ or mammary) adj3 (Neoplas$ or tumor$ or cancer$ or carcinom$)).mp. [mp=title, abstract, full text, keywords, caption text]
2 | (mri or magnetic resonance imag$).mp. [mp=title, abstract, full text, keywords, caption text]
3 | 1 and 2
4 | from 3 keep 1–9

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp Breast Neoplasms/
2 | exp neoplasms/di
3 | exp breast/
4 | 2 and 3
5 | 1 or 4
6 | exp mass screening/
7 | (screen$ or (routine$ adj3 (test$ or check$ or diagnos$ or detect$))).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
8 | 6 or 7
9 | 5 and 8
10 | exp Physical Examination/
11 | exp Breast/
12 | exp Breast Neoplasms/
13 | 11 or 12
14 | 10 and 13
15 | exp Mammography/
16 | 9 and 14
17 | 9 and 15
18 | 16 or 17
19 | exp Magnetic Resonance Imaging/
20 | 5 and 19
21 | 8 and 20
22 | from 21 keep 1–232

### DCIS

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp Carcinoma, Intraductal, Noninfiltrating/
2 | exp Breast Neoplasms/
3 | 1 and 2
4 | overdiagno$.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
5 | over-diagno$.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
6 | (overtreat$ or over-treat$).mp.
7 | exp Diagnostic Errors/
8 | exp Mass Screening/
9 | exp mammography/
10 | 8 or 9
11 | 3 and 7 and 10
12 | 4 or 5 or 6
13 | 3 and 12
14 | from 13 keep 1–22

### Adverse Effects

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
Search Strategy:
1 | exp mammography/
2 | mammogra$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3 | exp physical examination/
4 | ((physical$ or clinical$ or manual$) adj3 exam$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5 | exp mass screening/
6 | screen$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7 | 1 or 2 or 3 or 4 or 5 or 6
8 | exp breast/
9 | exp breast diseases/di, ep
10 | (breast$ or mammar$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
11 | 8 or 9 or 10
12 | 7 and 11
13 | ((advers$ adj3 effect$) or harm$ or contraindicat$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
14 | ae.fs.
15 | 13 or 14
16 | 12 and 15
17 | exp Mammography/ae, ct [Adverse Effects, Contraindications]
18 | exp Physical Examination/ae, ct
19 | exp Mass Screening/ae, ct [Adverse Effects, Contraindications]
20 | 17 or 18 or 19
21 | 11 and 20
22 | exp Diagnostic Errors/
23 | (overtest$ or overdiagnos$ or over-test$ or over-diagnos$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
24 | (false$ adj2 (result$ or positiv$ or negativ$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
25 | (observer$ adj3 bias$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
26 | (diagnos$ adj3 (error$ or mistak$ or incorrect$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
27 | 22 or 23 or 24 or 25 or 26
28 | 12 and 27
29 | exp “Wounds and Injuries”/ci, et [Chemically Induced, Etiology]
30 | exp Stress, Psychological/
31 | exp Prejudice/
32 | exp Stereotyping/
33 | (anxiet$ or anxious$ or fear$ or discriminat$ or unfair$ or prejudic$ or stigma$ or stereotyp$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
34 | 29 or 30 or 31 or 32 or 33
35 | 12 and 34
36 | 16 or 21 or 28 or 35
37 | from 36 keep 1–240

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp mammography/
2 | exp physical examination/
3 | exp mass screening/
4 | 1 or 2 or 3
5 | exp breast/
6 | exp breast diseases/di, ep
7 | 5 or 6
8 | 4 and 7
9 | exp Mammography/ae, ct [Adverse Effects, Contraindications]
10 | exp Physical Examination/ae, ct
11 | exp Mass Screening/ae, ct [Adverse Effects, Contraindications]
12 | 9 or 10 or 11
13 | 7 and 12
14 | exp Diagnostic Errors/
15 | (overtest$ or overdiagnos$ or over-test$ or over-diagnos$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
16 | 14 or 15
17 | 8 and 16
18 | exp “Wounds and Injuries”/ci, et [Chemically Induced, Etiology]
19 | exp Stress, Psychological/
20 | exp Prejudice/
21 | exp Stereotyping/
22 | 18 or 19 or 20 or 21
23 | 8 and 22
24 | 13 or 17 or 23
25 | limit 24 to english language
26 | limit 25 to (meta analysis or randomized controlled trial)
27 | exp Evaluation Studies/
28 | Comparative Study.pt.
29 | exp Epidemiologic Studies/
30 | 27 or 28 or 29
31 | 25 and 30
32 | 26 or 31
33 | from 32 keep 1–319

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp mammography/
2 | exp physical examination/
3 | exp mass screening/
4 | 1 or 2 or 3
5 | exp breast/
6 | exp breast diseases/di, ep
7 | 5 or 6
8 | 4 and 7
9 | exp Mammography/ae, ct [Adverse Effects, Contraindications]
10 | exp Physical Examination/ae, ct
11 | exp Mass Screening/ae, ct [Adverse Effects, Contraindications]
12 | 9 or 10 or 11
13 | 7 and 12
14 | exp Diagnostic Errors/
15 | (overtest$ or overdiagnos$ or over-test$ or over-diagnos$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
16 | misdiagnos$.mp. [mp=title, original title, abstract, name of substance word, subject heading word]
17 | (false$ adj (positiv$ or negativ$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
18 | ((incorrect$ or false$ or wrong$ or bias$ or mistake$ or error$ or erroneous$) adj3 (result$ or finding$ or test$ or diagnos$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
19 | ((inappropriat$ or unnecess$ or unneed$) adj3 (treat$ or surg$ or therap$ or regimen$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
20 | (observ$ adj3 bias$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
21 | 14 or 15 or 16 or 17 or 18 or 19 or 20
22 | 8 and 21
23 | exp “Wounds and Injuries”/ci, et [Chemically Induced, Etiology]
24 | exp Stress, Psychological/
25 | exp Prejudice/
26 | exp Stereotyping/
27 | 23 or 24 or 25 or 26
28 | 8 and 27
29 | 13 or 22 or 28
30 | limit 29 to english language
31 | limit 30 to (meta analysis or randomized controlled trial)
32 | exp Evaluation Studies/
33 | Comparative Study.pt.
34 | exp Epidemiologic Studies/
35 | 32 or 33 or 34
36 | 30 and 35
37 | 31 or 36
38 | limit 30 to yr= “2000 – 2007”
39 | from 38 keep 1–391

### Cost

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
Search Strategy:
1 | ((Breast$ or mammary) adj3 (Neoplas$ or tumor$ or cancer$ or carcinom$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2 | (screen$ or (routine$ adj3 (test$ or check$ or diagnos$ or detect$))).mp.
3 | ((clinical$ or physical$) adj3 (exam$ or detect$ or diagnos$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4 | (cost or costs or costing or economic$ or financial$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5 | 1 and (2 or 3) and 4
6 | from 5 keep 1–86

Database: EBM Reviews - Cochrane Database of Systematic Reviews
Search Strategy:
1 | ((Breast$ or mammary) adj3 (Neoplas$ or tumor$ or cancer$ or carcinom$)).mp. [mp=title, abstract, full text, keywords, caption text]
2 | (screen$ or (routine$ adj3 (test$ or check$ or diagnos$ or detect$))).mp.
3 | ((clinical$ or physical$) adj3 (exam$ or detect$ or diagnos$)).mp. [mp=title, abstract, full text, keywords, caption text]
4 | (cost or costs or costing or economic$ or financial$).mp. [mp=title, abstract, full text, keywords, caption text]
5 | 1 and (2 or 3) and 4
6 | from 5 keep 1–97

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp Breast Neoplasms/
2 | exp neoplasms/di
3 | exp breast/
4 | 2 and 3
5 | 1 or 4
6 | exp mass screening/
7 | (screen$ or (routine$ adj3 (test$ or check$ or diagnos$ or detect$))).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
8 | 6 or 7
9 | 5 and 8
10 | exp Physical Examination/
11 | exp Breast/
12 | exp Breast Neoplasms/
13 | 11 or 12
14 | 10 and 13
15 | exp Mammography/
16 | 9 and 14
17 | 9 and 15
18 | 16 or 17
19 | exp “Costs and Cost Analysis”/
20 | 18 and 19
21 | limit 20 to english language
22 | from 21 keep 1–376

## Appendix B2. Search Results by Key Question

## Appendix B3. List of Excluded Studies

### Wrong population, including high risk

Berg WA, Blume JD, Cormack JB, et al. (2008). Combined screening with ultrasound and mammography vs mammography alone in women at elevated risk of breast cancer. JAMA.
Boetes C. (2002). The evaluation of women with familial risk of breast cancer. J Exp Clin Cancer Res.
Bordas P, Jonsson H, Nystrom L, et al. (2004). Early breast cancer deaths in women aged 40–74 years diagnosed during the first 5 years of organised mammography service screening in north Sweden. Breast.
Buseman S, Mouchawar J, Calonge N, et al. (2003). Mammography screening matters for young women with breast carcinoma: evidence of downstaging among 42–49-year-old women with a history of previous mammography screening. Cancer.
Claus EB, Stowe M, Carter D, et al. (2003). The risk of a contralateral breast cancer among women diagnosed with ductal and lobular breast carcinoma in situ: data from the Connecticut Tumor Registry. Breast.
Gilbert FJ. (2005). Should we use MRI to screen women at high-risk of breast cancer?. Cancer Imaging.
Joensuu H, Lehtimaki T, Holli K, et al. (2004). Risk for distant recurrence of breast cancer detected by mammography screening or other methods. JAMA.
Lalonde L, David J, Trop I. (2005). Magnetic resonance imaging of the breast: current indications. Can Assoc Radiol J.
Lash TL, Fox MP, Buist DSM, et al. (2007). Mammography surveillance and mortality in older breast cancer survivors. J Clin Oncol.
Leach MO, Boggis CRM, Dixon AK, et al. (2005). Screening with magnetic resonance imaging and mammography of a UK population at high familial risk of breast cancer: a prospective multicentre cohort study (MARIBS). Lancet.
Lehman CD, Gatsonis C, Kuhl CK, et al. (2007). MRI evaluation of the contralateral breast in women with recently diagnosed breast cancer. New Eng J Med.
MARIBS Study Group. (2005). Screening with magnetic resonance imaging and mammography of a UK population at high familial risk of breast cancer: A prospective multicentre cohort study. Lancet.
Narod SA, Lubinski J, Ghadirian P, et al. (2006). Screening mammography and risk of breast cancer in BRCA1 and BRCA2 mutation carriers: a case-control study. Lancet Oncol.
Nelson HD, Huffman LH, Fu R, et al. (2005). Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: Systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med.
Rijnsburger AJ, Essink-Bot ML, van Dooren S, et al. (2004). Impact of screening for breast cancer in high-risk women on health-related quality of life. Br J Cancer.
Sim LSJ, Hendriks JHCL, Fook-Chong SMC. (2004). Breast ultrasound in women with familial risk of breast cancer. Ann Acad Med Singapore.
Tilanus-Linthorst MM, Obdeijn IM, Bartels KC, et al. (2000). First experiences in screening women at high risk for breast cancer with MR imaging. Breast Cancer Res Treat.
Walter LC, Eng C, et al. (2001). Screening mammography for frail older women: what are the burdens?. J Gen Intern Med.
Warnberg F, Casalini P, Nordgren H, et al. (2002). Ductal carcinoma in situ of the breast: a new phenotype classification system and its relation to prognosis. Breast Cancer Res Treat.
Warren R. (2001). Screening women at high risk of breast cancer on the basis of evidence. Eur J Radiol.

### Wrong intervention

Belkic K. (2004). Current dilemmas and future perspectives for breast cancer screening with a focus on optimization of magnetic resonance spectroscopic imaging by advances in signal processing. Isr Med Assoc J.
Lindfors KK, O’Connor J, Parker RA. (2001). False-positive screening mammograms: effect of immediate versus later work-up on patient stress. Radiology.
Warren R, Allgood P, Hunnam G, et al. (2004). An audit of assessment procedures in women who develop breast cancer after a negative result. J Med Screen.
Wirfalt E, Vessby B, Mattisson I, et al. (2004). No relations between breast cancer risk and fatty acids of erythrocyte membranes in postmenopausal women of the Malmo Diet Cancer cohort (Sweden). Eur J Clin Nutr.

### Wrong outcome

Anderson TJ, Waller M, Ellis IO, et al. (2004). Influence of annual mammography from age 40 on breast cancer pathology. Human Pathol.
Bartella L, Liberman L, Morris EA, et al. (2006). Nonpalpable mammographically occult invasive breast cancers detected by MRI. Am J Roentgenol.
Birdwell RL, Bandodkar P, Ikeda DM. (2005). Computer-aided detection with screening mammography in a university hospital setting. Radiology.
Burani R, Caimi F, Maggioni C, et al. (2005). Quality assessment of the mammographic screening programme in the Azienda Sanitaria locale Provincia Milano 1 -- analysis of interval cancers and discussion of possible causes of diagnostic error. Radiol Med (Torino).
Cupples TE, Cunningham JE, Reynolds JC. (2005). Impact of computer-aided detection in a regional screening mammography program. Am J Roentgenol.
Elmore JG, Nakano CY, Koepsell TD, et al. (2003). International variation in screening mammography interpretations in community-based programs. J Natl Cancer Inst.
Evans AJ, Kutt E, Record C, et al. (2006). Radiological findings of screen-detected cancers in a multi-centre randomized, controlled trial of mammographic screening in women from age 40 to 48 years. Clin Radiol.
Evans AJ, Pinder SE, Ellis IO, et al. (2001). Screen detected ductal carcinoma in situ (DCIS): overdiagnosis or an obligate precursor of invasive disease?. J Med Screen.
Feigin KN, Keating DM, Telford PM, et al. (2006). Clinical breast examination in a comprehensive breast cancer screening program: contribution and cost. Radiology.
Fitzgibbon ML, Gapstur SM, Knight SJ. (2003). Mujeres felices por ser saludables: a breast cancer risk reduction program for Latino women. Prev Med.
Flegg KM, Rowling YJ. (2000). Clinical breast examination. Aust Fam Physician.
Galinsky D, Kisselgoff D, Sella T, et al. (2005). Effect of breast magnetic resonance imaging on the clinical management of breast cancer. Isr Med Assoc J.
Giorgi Rossi P, Camilloni L, Mantellini P, et al. (2007). Breast cancer diagnostic methods: screen-detected and clinical cases. Tumori.
Goscin CP, Berman CG, Clark RA. (2001). Magnetic resonance imaging of the breast. Cancer Control.
Gur D, Wallace LP, Klym AH, et al. (2005). Trends in recall, biopsy, and positive biopsy rates for screening mammography in an academic practice. Radiology.
Hadi N, Sadeghi-Hassanabadi A, Talei AR, et al. (2002). Assessment of a breast cancer screening programme in Shiraz, Islamic Republic of Iran. East Mediterr Health J.
Kessar P, Perry N, Vinnicombe SJ, et al. (2002). How significant is detection of ductal carcinoma in situ in a breast screening programme?. Clin Radiol.
Khoo LA, Taylor P, Given-Wilson RM. (2005). Computer-aided detection in the United Kingdom National Breast Screening Programme: Prospective study. Radiology.
Kim do Y, Moon WK, Cho N, et al. (2007). MRI of the breast for the detection and assessment of the size of ductal carcinoma in situ. Korean J Radiol.
Kinkel K, Vlastos G. (2001). MR imaging: breast cancer staging and screening. Semin Surg Oncol.
Kolb TM, Lichy J, Newhouse JH. (2002). Comparison of the performance of screening mammography, physical examination, and breast US and evaluation of factors that influence them: An analysis of 27,825 patient evaluations. Radiology.
Law J, Faulkner K. (2002). Concerning the relationship between benefit and radiation risk, and cancers detected and induced, in a breast screening programme. Br J Radiol.
Leach MO, Eeles RA, Turnbull LW, et al. (2002). The UK national study of magnetic resonance imaging as a method of screening for breast cancer (MARIBS). J Exp Clin Cancer Res.
Menell JH, Morris EA, Dershaw DD, et al. (2005). Determination of the presence and extent of pure ductal carcinoma in situ by mammography and magnetic resonance imaging. Breast J.
Morris EA. (2003). Screening for breast cancer with MRI. Semin Ultrasound CT MR.
Moss S, Thomas I, Evans A, et al. (2005). Randomised controlled trial of mammographic screening in women from age 40: results of screening in the first 10 years. Br J Cancer.
Oestreicher N, White E, Lehman CD, et al. (2002). Predictors of sensitivity of clinical breast examination (CBE). Breast Cancer Res Treat.
Olsen AH, Jensen A, Njor SH, et al. (2003). Breast cancer incidence after the start of mammography screening in Denmark. Br J Cancer.
Ostbye T, Greenberg GN, Taylor DH, et al. (2003). Screening mammography and Pap tests among older American women 1996–2000: results from the Health and Retirement Study (HRS) and Asset and Health Dynamics Among the Oldest Old (AHEAD). Ann Fam Med.
Paajanen H, Kyhala L, Varjo R, et al. (2006). Effect of screening mammography on the surgery of breast cancer in Finland: a population-based analysis during the years 1985–2004. Am Surg.
Park BW, Kim SI, Kim MH, et al. (2000). Clinical breast examination for screening of asymptomatic women: the importance of clinical breast examination for breast cancer detection. Yonsei Med J.
Pisano ED, Gatsonis C, Hendrick E, et al. (2005). Diagnostic performance of digital versus film mammography for breast-cancer screening. N Engl J Med.
Smith-Bindman R, Chu PW, Miglioretti DL, et al. (2003). Comparison of screening mammography in the United States and the United Kingdom. JAMA.
Warren R, Duffy S. (2000). Interval cancers as an indicator of performance in breast screening. Breast Cancer.
Warren RML, Crawley A. (2002). Is breast MRI ever useful in a mammographic screening programme?. Clin Radiol.
Warren RML, Pointon L, Caines R, et al. (2002). What is the recall rate of breast MRI when used for screening asymptomatic women at high risk?. Magn Reson Imaging.
Weaver DL, Rosenberg RD, Barlow WE, et al. (2006). Pathologic findings from the Breast Cancer Surveillance Consortium: population-based outcomes in women undergoing biopsy after screening mammography. Cancer.
Zabicki K, Colbert JA, Dominguez FJ, et al. (2006). Breast cancer diagnosis in women <= 40 versus 50 to 60 years: Increasing size and stage disparity compared with older women over time. Ann Surg Oncol.
Zotov V, Shyyan R, Program PBCA. (2003). Introduction of breast cancer screening in Chernihiv Oblast in the Ukraine: report of a PATH Breast Cancer Assistance Program experience. Breast J.

### Wrong study design or no original data for meta-analysis

Aberle DR, Chiles C, Gatsonis C, et al. (2005). Imaging and cancer: research strategy of the American College of Radiology Imaging Network. Radiology.
Allen MW, Hendi P, Schwimmer J, et al. (2000). Decision analysis for the cost effectiveness of sestamibi scintimammography in minimizing unnecessary biopsies. Q J Nucl Med.
Anttila A, Koskela J, Hakama M. (2002). Programme sensitivity and effectiveness of mammography service screening in Helsinki, Finland. J Med Screen.
Badgwell BD, Giordano SH, Duan ZZ, et al. (2008). Mammography before diagnosis among women age 80 years and older with breast cancer. J Clin Oncol.
Baig S, Ali TS. (2006). Evaluation of efficacy of self breast examination for breast cancer prevention: a cost effective screening tool. Asian Pac J Cancer Prev.
Bailar JC, MacMahon B. (1997). Randomization in the Canadian National Breast Screening Study: a review for evidence of subversion. CMAJ.
Baines CJ. (2005). Are there downsides to mammography screening?. Breast J.
Bancej C, Decker K, Chiarelli A, et al. (2003). Contribution of clinical breast examination to mammography screening in the early detection of breast cancer. J Med Screen.
Barratt A, Howard K, Irwig L, et al. (2005). Model of outcomes of screening mammography: Information to support informed choices. BMJ.
Barton MB. (2005). Breast cancer screening. Benefits, risks, and current controversies. Postgrad Med.
Beaman JM, Goldie DJ, Smith PA, et al. (2000). Reporting of screening results. J Med Screen.
Berg AO, Allan J, Woolf S. (2003). The mammography dilemma. Ann Intern Med.
Berg WA. (2007). Beyond standard mammographic screening: mammography at age extremes, ultrasound, and MR imaging. Radiol Clin North Am.
Berry DA, Berry DA. (1998). Benefits and risks of screening mammography for women in their forties: a statistical appraisal. J Natl Cancer Inst.
Berry DA, Inoue L, Shen Y, et al. (2006). Modeling the impact of treatment and screening on U.S. breast cancer mortality: a Bayesian approach. J Natl Cancer Inst.
Blanks RG, Moss SM, McGahan CE, et al. (2000). Effect of NHS breast screening programme on mortality from breast cancer in England and Wales, 1990–8: comparison of observed with predicted mortality. BMJ.
Bonneux L. (2003). Mortality reduction by breast-cancer screening. Lancet.
Boyle P. (2003). Global summit on mammographic screening. Ann Oncol.
Bradbury A, Olopade OI. (2006). The case for individualized screening recommendations for breast cancer. J Clin Oncol.
Briggs W, Ruppert D. (2005). Assessing the skill of yes/no predictions. Biometrics.
Burstein HJ, Polyak K, Wong JS, et al. (2004). Ductal carcinoma in situ of the breast. N Engl J Med.
Carter KJ, Castro F, Kessler E, et al. (2005). Simulation of begin and end ages for mammography screening. J Health Qual.
Cates C, Senn S. (2000). Screening mammography re-evaluated. Lancet.
Ciatto S, Houssami N, Ambrogetti D, et al. (2007). Minority report - false negative breast assessment in women recalled for suspicious screening mammography: imaging and pathological features, and associated delay in diagnosis. Breast Cancer Res Treat.
Clark R. (2005). Re: Accuracy of screening mammography interpretation by characteristics of radiologists. J Natl Cancer Inst.
Connolly JL, Boyages J, Schnitt SJ, et al. (1989). In situ carcinoma of the breast. Annu Rev Med.
Cox B. (1997). Variation in the effectiveness of breast screening by year of follow-up. J Natl Cancer Inst.
de Gonzalez BA, Reeves G. (2005). Mammographic screening before age 50 years in the UK: comparison of the radiation risks with the mortality benefits. Br J Cancer.
de Koning HJ. (2003). Mammographic screening: evidence from randomised controlled trials. Ann Oncol.
Djulbegovic B, Hozo I, Lyman GH. (2007). Estimating net benefits and harms of screening mammography in women age 40 to 49 years. Ann Intern Med.
Djulbegovic B, Lyman GH. (2006). Screening mammography at 40–49 years: regret or no regret?. Lancet.
Duffy SW, Smith RA, Gabe R, et al. (2005). Screening for breast cancer. Surg Oncol Clin N Am.
Duffy SW, Tabar L, Smith RA. (2001). Screening for breast cancer with mammography. Lancet.
Elmore JG, Armstrong K, Lehman CD, et al. (2005). Screening for breast cancer. JAMA.
Elmore JG, Barton MB, Moceri VM, et al. (1997). Cumulative risk of a false-positive mammogram over a 10-year period. J Gen Intern Med.
Elmore JG, Reisch LM, Barton MB, et al. (2005). Efficacy of breast cancer screening in the community according to risk level. J Natl Cancer Inst.
Emory TH. (2004). Mammography studies revisited. Minn Med.
Faulkner K. (2005). Mammographic screening: is the benefit worth the risk?. Radiat Prot Dosimetry.
Feig SA. (2004). Adverse effects of screening mammography. Radiol Clin North Am.
Feig SA. (2005). Screening mammography controversies: resolved, partly resolved, and unresolved. Breast J.
Fenton JJ, Elmore JG. (2004). Balancing mammography’s benefits and harms. BMJ.
Feuer EJ. (2006). Modeling the impact of adjuvant therapy and screening mammography on U.S. breast cancer mortality between 1975 and 2000: introduction to the problem. J Natl Cancer Inst.
Freedman DA, Petitti DB, Robins JM. (2004). On the efficacy of screening for breast cancer. Int J Epidemiol.
Gill PG, Farshid G, Luke CG, et al. (2004). Detection by screening mammography is a powerful independent predictor of survival in women diagnosed with breast cancer. Breast.
Goldhirsch A, Colleoni M, Domenighetti G, et al. (2003). Systemic treatments for women with breast cancer: outcome with relation to screening for the disease. Ann Oncol.
Gotzsche PC, Nielsen M. (2006). Screening for breast cancer with mammography. Cochrane Database of Systematic Reviews.
Gotzsche PC, Nielsen M. (2008). Screening for breast cancer with mammography. Cochrane Database of Systematic Reviews.
Gotzsche PC. (2003). Breast cancer screening. International Agency for Research on Cancer (IARC) handbooks of cancer prevention. Vol. 7. Int J Epidemiol.
Gotzsche PC. (2007). Mammographic screening from age 40 years. Lancet.
Gotzsche PC. (2004). On the benefits and harms of screening for breast cancer. Int J Epidemiol.
Gotzsche PC. (2006). Ramifications of screening for breast cancer: overdiagnosis in the Malmo trial was considerably underestimated. BMJ.
Gotzsche PS, Olsen O. (2000). Is screening for breast cancer with mammography justifiable?. Lancet.
Gulbrandsen P. (2002). Update on effects of screening mammography. Lancet.
Habel L, Haque R, Fletcher S, et al. Predictors of recurrence after DCIS: Kaiser Permanente.
Hackshaw A. (2003). EUSOMA review of mammography screening. Ann Oncol.
Harms SE. (2004). Introduction to the International Working Groups on Breast MRI. Breast J.
Harris R. (2005). Effectiveness: the next question for breast cancer screening. J Natl Cancer Inst.
Harris R. (2000). What is the right cancer screening rate?. Ann Intern Med.
Health Council of the Netherlands. (2002). The benefit of population screening for breast cancer with mammography.
Hense HW. (2006). The trade-off between population and individual benefit of screening. Z Arztl Fortbild Qualitatssich.
Houssami N, Cuzick J, Dixon JM. (2006). The prevention, detection, and management of breast cancer. Med J Aust.
Immonen-Raiha P, Kauhava L, Parvinen I, et al. (2005). Mammographic screening reduces risk of breast carcinoma recurrence. Cancer.
Institute of Medicine. Saving women’s lives: Strategies for improving breast cancer detection and diagnosis. book review.
Jatoi I. (2005). MRI in breast cancer management: potential for benefit and harm. Int J Fertil Womens Med.
Jonsson H, Nystrom L, Tornberg S, et al. (2001). Service screening with mammography of women aged 50–69 years in Sweden: effects on mortality from breast cancer. J Med Screen.
Jonsson H, Nystrom L, Tornberg S, et al. (2003). Service screening with mammography. Long-term effects on breast cancer mortality in the county of Gavleborg, Sweden]. Breast.
Jonsson H, Tornberg S, Nystrom L, et al. (2000). Service screening with mammography in Sweden--evaluation of effects of screening on breast cancer mortality in age group 40–49 years. Acta Oncol.
Jonsson H, Tornberg S, Nystrom L, et al. (2003). Service screening with mammography of women aged 70–74 years in Sweden. Effects on breast cancer mortality. Cancer Detect Prev.
Kane KY, Lindbloom EJ, Stevermer JJ. (2000). Does mammography add any benefit to a thorough clinical breast examination (CBE)?. J Fam Pract.
Katschke RW, Schooff M. (2001). Is breast self-examination an effective screening measure for breast cancer?. J Fam Pract.
Kearney AJ. (2006). Increasing our understanding of breast self-examination: women talk about cancer, the health care system, and being women. Qual Health Res.
Kerlikowske K, Grady D, Ernster V. (1995). Benefit of mammography screening in women ages 40–49 years: current evidence from randomized controlled trials. Cancer.
Kerlikowske K, Salzmann P, Phillips KA, et al. (1999). Continuing screening mammography in women aged 70 to 79 years: impact on life expectancy and cost-effectiveness. JAMA.
Kerlikowske K. (1997). Efficacy of screening mammography among women aged 40 to 49 years and 50 to 69 years: comparison of relative and absolute benefit. J Natl Cancer Inst.
Khan A, Newman LA. (2004). Diagnosis and management of ductal carcinoma in situ. Curr Treat Options Oncol.
Klemi PJ, Parvinen I, Pylkkanen L, et al. (2003). Significant improvement in breast cancer survival through population-based mammography screening. Breast.
Kopans DB. (2002). Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality. Cancer.
Kopans DB. (2004). Mammography screening is saving thousands of lives, but will it survive medical malpractice?. Radiology.
Kopans DB. (2004). Re: Decreasing women’s anxieties after abnormal mammograms: a controlled trial. J Natl Cancer Inst.
Kumar AS, Bhatia V, Henderson IC. (2005). Overdiagnosis and overtreatment of breast cancer: rates of ductal carcinoma in situ: a US perspective. Breast Cancer Res.
Kumar G, Redick M, Dixon GD. (2005). New techniques for mammography screening: advantages and limitations. Mo Med.
Lash TL, Fox MP, Buist DS, et al. (2007). Mammography surveillance and mortality in older breast cancer survivors. J Clin Oncol.
Lash TL, Fox MP, Silliman RA. (2006). Reduced mortality rate associated with annual mammograms after breast cancer therapy. Breast J.
Law M, Hackshaw A, Wald N. (2000). Screening mammography re-evaluated. Lancet.
Lawrence W. (2001). Pros and cons of mammographic screening. J Surg Oncol.
Lee CH, Weinreb JC. (2004). The use of magnetic resonance imaging in breast cancer screening. J Am Coll Radiol.
Lee JH, Zuckerman D. (2001). Screening for breast cancer with mammography. Lancet.
Leon A, Verdu G, Cuevas MD, et al. (2001). Study of radiation induced cancers in a breast screening programme. Radiat Prot Dosimetry.
Le-Petross HT. (2006). Breast MRI as a screening tool: the appropriate role. J Natl Compr Canc Netw.
Leung GM, Lam TH, Hedley AJ. (2000). Screening mammography re-evaluated. Lancet.
Mandelblatt J, Schechter CB, Lawrence W, et al. (2006). The SPECTRUM Population Model of the Impact of Screening and Treatment on U.S. Breast Cancer Trends From 1975 to 2000: Principles and Practice of the Model Methods. J Natl Cancer Inst.
Marsden J. (2004). Commentary: does screening mammography lead to breast cancer overdiagnosis?. J Br Menopause Soc.
Marshall T. (2005). Informed consent for mammography screening: modeling the risks and benefits for American women. Health Expect.
McCann J, Treasure P, Duffy S. (2004). Modeling the impact of detecting and treating ductal carcinoma in situ in a breast screening programme. J Med Screen.
Moja L, Compagnoni A, Brambilla C, et al. (2006). Trastuzumab containing regimens for metastatic breast cancer. Cochrane Database of Systematic Reviews.
Moller H, Davies E. (2006). Over-diagnosis in breast cancer screening. BMJ.
Moore W. (2000). Cancer. Keeping abreast. Health Serv J.
Nakhlis F, Morrow M. (2003). Ductal carcinoma in situ. Surg Clin North Am.
Nelson R. (2004). MRI better than mammography for detection of breast cancer?. Lancet Oncol.
Olsen AH, Njor SH, Vejborg I, et al. (2005). Breast cancer mortality in Copenhagen after introduction of mammography screening: cohort study. BMJ.
Olsen O, Gotzsche PC. (2001). Cochrane review on screening for breast cancer with mammography. Lancet.
Olsen O, Gotzsche PC. (2001). Screening for breast cancer with mammography.[update in Cochrane Database Syst Rev. 2006;(4):CD001877; PMID: 17054145]. Cochrane Database of Systematic Reviews.
Olsen O. (2002). Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality. Cancer.
Otto SJ, Fracheboud J, Looman CWN, et al. (2003). Initiation of population-based mammography screening in Dutch municipalities and effect on breast-cancer mortality: a systematic review. Lancet.
Paci E, Coviello E, Miccinesi G, et al. (2008). Evaluation of service mammography screening impact in Italy. The contribution of hazard analysis. Eur J Cancer.
Paci E, Duffy S. (2005). Overdiagnosis and overtreatment of breast cancer: overdiagnosis and overtreatment in service screening. Breast Cancer Res.
Parkin DM, Esteban E, Pisani P, et al. (2002). Breast cancer screening by physical examination: A randomized trial in the Philippines.
Parvinen I, Helenius H, Pylkkanen L, et al. (2006). Service screening mammography reduces breast cancer mortality among elderly women in Turku. J Med Screen.
Pavic D, Koomen MA, Kuzmiak CM, et al. (2004). The role of magnetic resonance imaging in diagnosis and management of breast cancer. Technol Cancer Res Treat.
Plevritis SK, Sigal BM, Salzman P, et al. (2006). A Stochastic Simulation Model of U.S. Breast Cancer Mortality Trends From 1975 to 2000. J Natl Cancer Inst.
Ponzone R, Sismondi P, Baum M. (2002). Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality. Cancer.
Qaseem A, Snow V, Sherif K, et al. (2007). Screening mammography for women 40 to 49 years of age: A Clinical Practice Guideline for the American College of Physicians. Ann Intern Med.
Ramos M, Ferrer S, Villaescusa JI, et al. (2005). Use of risk projection models to estimate mortality and incidence from radiation-induced breast cancer in screening programs. Phys Med Biol.
Rayter Z, Kutt E. (2004). Overdiagnosis of breast cancer in screening. Eur J Surg Oncol.
Retsky M, Demicheli R, Hrushesky W. (2001). Breast cancer screening for women aged 40–49 years: screening may not be the benign process usually thought. J Natl Cancer Inst.
Rich JS, Black WC. (2000). When should we stop screening?. Eff Clin Pract.
Rijnsburger AJ, van Oortmarssen GJ, Boer R, et al. (2004). Mammography benefit in the Canadian National Breast Screening Study-2: a model evaluation. Int J Cancer.
Rodger A. (2002). Is it worth screening women over 70 for breast cancer--or indeed any women?. Med J Aust.
Rollins G. (2002). Teaching breast self-examination in developing countries does not reduce breast cancer deaths. Rep Med Guide Outcomes Res.
Rossi PG, Federici A, Farchi S, et al. (2006). The effect of screening programmes on the treatment of benign breast neoplasms: observations from current practice in Italy. J Med Screen.
Rozenberg S, Liebens F, Ham H. (2000). Screening mammography re-evaluated. Lancet.
Sakorafas GH, Tsiotou AG. (2000). Ductal carcinoma in situ (DCIS) of the breast: evolving perspectives. Cancer Treat Rev.
Sasieni P. (2003). Evaluation of the UK breast screening programmes. Ann Oncol.
Saslow D, Hannan J, Osuch J, et al. (2004). Clinical breast examination: practical recommendations for optimizing performance and reporting. CA. Cancer J Clin.
Scinto JD, Gill TM, Grady JN, et al. (2001). Screening mammography: Is it suitably targeted to older women who are most likely to benefit?. J Am Geriatr Soc.
Senn S. (2001). Screening for breast cancer with mammography. Lancet.
Shen Y, Parmigiani G. (2005). A model-based comparison of breast cancer screening strategies: mammograms and clinical breast examinations. Cancer Epidemiol Biomarkers Prev.
Shen Y, Yang Y, Inoue LYT, et al. (2005). Role of detection method in predicting breast cancer survival: analysis of randomized screening trials. J Natl Cancer Inst.
Skaane P, Kshirsagar A, Stapleton S, et al. (2007). Effect of computer-aided detection on independent double reading of paired screen-film and full-field digital screening mammograms. Am J Roentgenol.
Skegg D. (2001). Breast screening--time for review. N Z Med J.
Smith JA, Andreopoulou E. (2004). An overview of the status of imaging screening technology for breast cancer. Ann Oncol.
Smith RA, Duffy SW, Gabe R, et al. (2004). The randomized trials of breast cancer screening: what have we learned?. Radiol Clin North Am.
Smith RA, Smith RA. (2007). The evolving role of MRI in the detection and evaluation of breast cancer. N Engl J Med.
Spencer DB, Potter JE, Chung MA, et al. (2004). Mammographic screening and disease presentation of breast cancer patients who die of disease. Breast J.
Svartbo B, Bygren LO, Bucht G, et al. (2003). False-negative cases of breast cancer deaths in mammography screening evaluations. Breast J.
Tabar L, Duffy SW, Yen MF, et al. (2002). All-cause mortality among breast cancer patients in a screening trial: support for breast cancer mortality as an end point. J Med Screen.
Tabar L, Vitak B, Chen HH, et al. (2001). Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality. Cancer.
Tabar L, Vitak B, Yen MF, et al. (2004). Number needed to screen: lives saved over 20 years of follow-up in mammographic screening. J Med Screen.
Tabar L, Vitak B, Yen MFA, et al. (2004). Number needed to screen: lives saved over 20 years of follow-up in mammographic screening. J Med Screen.
Tabar L, Yen M-F, Vitak B, et al. (2003). Mammography service screening and mortality in breast cancer patients: 20-year follow-up before and after introduction of screening. Lancet.
Tang P, Hajdu SI, Lyman GH. (2007). Ductal carcinoma in situ: a review of recent advances. Curr Opin Obstet Gynecol.
Taylor R, Morrell S, Estoesta J, et al. (2004). Mammography screening and breast cancer mortality in New South Wales, Australia. Cancer Causes Control.
Thor A. (2004). A revised staging system for breast cancer. Breast J.
Thornton H. (2001). Screening for breast cancer with mammography. Lancet.
Thurfjell MG. (2001). Aspects in mammographic screening. Detection, prediction, recurrence and prognosis. Acta Radiol Suppl.
Trell E, Trell E. (1983). Community-based preventive medical department for individual risk factor assessment and intervention in an urban population. Prev Med.
Vahabi M. (2003). Breast cancer screening methods: a review of the evidence. Health Care Women Int.
van Veen WA, Knottnerus JA. (2002). The evidence to support mammography screening. Neth J Med.
Walter LC, Covinsky KE, Walter LC, et al. (2001). Cancer screening in elderly patients: a framework for individualized decision making. JAMA.
Walter LC, Lewis CL, Barton MB. (2005). Screening for colorectal, breast, and cervical cancer in the elderly: a review of the evidence. Am J Med.
Walter SD. (2003). Mammographic screening: case-control studies. Ann Oncol.
Wang L. (2003). Mammography and beyond: building better breast cancer screening tests. J Natl Cancer Inst.
Weiss NS. (2003). Breast cancer mortality in relation to clinical breast examination and breast self-examination. Breast J.
Wolfe C. (2000). UK study of MRI screening for breast cancer. N0013064519.
Xu W, Vnenchak P, Smucny J. (2000). Screening mammography in women aged 70 to 79 years. J Fam Pract.
Yaffe MJ. (2004). What should the burden of proof be for acceptance of a new breast-cancer screening technique?. Lancet.
Yassin MM, Peel ALG, Thompson WD, et al. (2003). Does screen-detected breast cancer have better survival than symptomatic breast cancer?. Asian J.
Zahl PH, Maehlen J. (2006). Ramifications of screening for breast cancer: definition of overdiagnosis is confusing in follow-up of Malmo trial. BMJ.
Zahl PH. (2004). Overdiagnosis of breast cancer in Denmark. Br J Cancer.
Zappa M, Visioli CB, Ciatto S. (2003). Mammography screening in elderly women: efficacy and cost-effectiveness. Crit Rev Oncol Hematol.

### Development of technology

Anonymous. (2002). Multicentre cancer chemotherapy group randomised trial of cyclical combination chemotherapy in potentially curable breast cancer. UKCCCR National Register of Cancer Trials-B36.
Burrell HC, Evans AJ, Wilson AR, et al. (2001). False-negative breast screening assessment: what lessons can we learn?. Clin Radiol.
Chew I, Tan Y, Tan PH. (2006). Cytology is useful in breast screening: results and long-term follow-up of the Singapore Breast Screening Pilot Project. Cytopathology.
Collins LC, Connolly JL, Page DL, et al. (2004). Diagnostic agreement in the evaluation of image-guided breast core needle biopsies: results from a randomized clinical trial. Am J Surg Pathol.
Destounis SV, DiNitto P, Logan-Young W, et al. (2004). Can computer-aided detection with double reading of screening mammograms help decrease the false-negative rate? Initial experience. Radiology.
Farshid G, Rush G. (2003). The use of fine-needle aspiration cytology and core biopsy in the assessment of highly suspicious mammographic microcalcifications: analysis of outcome for 182 lesions detected in the setting of a population-based breast cancer screening program. Cancer.
Frankenberg D, Kelnhofer K, Bar K, et al. (2002). Enhanced neoplastic transformation by mammography X rays relative to 200 kVp X rays: indication for a strong dependence on photon energy of the RBE(M) for various end points. Radiat Res.
Gennaro G, di Maggio C. (2006). Dose comparison between screen/film and full-field digital mammography. Eur Radiol.
Irwig L, Houssami N, van Vliet C. (2004). New technologies in screening for breast cancer: a systematic review of their accuracy. Br J Cancer.
Morris EA, Liberman L, Dershaw DD, et al. (2002). Preoperative MR imaging-guided needle localization of breast lesions. Am J Roentgenol.
Reddy DH, Mendelson EB. (2005). Incorporating new imaging models in breast cancer management. Curr Treat Options Oncol.
Scheiden R, Sand J, Tanous AM, et al. (2001). Accuracy of frozen section diagnoses of breast lesions after introduction of a national programme in mammographic screening. Histopathology.
Weigel S, Girnus R, Czwoydzinski J, et al. (2007). Digital mammography screening: average glandular dose and first performance parameters. ROFO Fortschr Geb Rontgenstr Nuklearmed.

### Does not address a Key Question

Allgood PC, Duffy SW, Warren R, et al. (2006). Audit of negative assessments in a breast-screening programme in women who later develop breast cancer-implications for survival. Breast.
Anderson TJ, Alexander FE, Lamb J, et al. (2000). Pathology characteristics that optimize outcome prediction of a breast screening trial. British journal of cancer.
Ashikari R, Huvos AG, Snyder RE. (1977). Prospective study of non-infiltrating carcinoma of the breast.
Baines CJ. (2003). Mammography screening: are women really giving informed consent? Countering the counterpoint. J Natl Cancer Inst.
Baker S, Wall M, Bloomfield A. (2005). Breast cancer screening for women aged 40 to 49 years--what does the evidence mean for New Zealand?. N Z Med J.
Banks E, Reeves G, Beral V, et al. (2002). Predictors of outcome of mammography in the National Health Service Breast Screening Programme. J Med Screen.
Barth RJ, Gibson GR, Carney PA, et al. (2005). Detection of breast cancer on screening mammography allows patients to be treated with less-toxic therapy. Am J Roentgenol.
Barton MB, Elmore JG, Fletcher SW. (1999). Breast symptoms among women enrolled in a health maintenance organization: frequency, evaluation, and outcome. Ann Intern Med.
Barton MB, Moore S, Polk S, et al. (2001). Increased patient concern after false-positive mammograms: clinician documentation and subsequent ambulatory visits. J Gen Intern Med.
Barton MB, Morley DS, Moore S, et al. (2004). Decreasing women’s anxieties after abnormal mammograms: a controlled trial. J Natl Cancer Inst.
Bhosle M, Samuel S, Vosuri V, et al. (2007). Physician and patient characteristics associated with outpatient breast cancer screening recommendations in the United States: analysis of the National Ambulatory Medical Care Survey Data 1996–2004. Breast Cancer Res Treat.
Bijker N, Peterse JL, Duchateau L, et al. (2001). Histological type and marker expression of the primary tumour compared with its local recurrence after breast-conserving therapy for ductal carcinoma in situ. Br J Cancer.
Bluman LG, Borstelmann NA, Rimer BK, et al. (2001). Knowledge, satisfaction, and perceived cancer risk among women diagnosed with ductal carcinoma in situ. J Womens Health Gend Based Med.
Bobo JK, Lawson HW, Lee NC. (2003). Risk factors for failure to detect a cancer during clinical breast examinations (United States). Cancer Causes Control.
Bowen DJ, Powers D, Greenlee H. (2006). Effects of breast cancer risk counseling for sexual minority women. Health Care Women Int.
Boyages J, Delaney G, Taylor R. (1999). Predictors of local recurrence after treatment of ductal carcinoma in situ: a meta-analysis. Cancer.
Breen N, Wagener DK, Brown ML, et al. (2001). Progress in cancer screening over a decade: results of cancer screening from the 1987, 1992, and 1998 National Health Interview Surveys. J Natl Cancer Inst.
Buist DSM, Porter PL, Lehman C, et al. (2004). Factors contributing to mammography failure in women aged 40–49 years. J Natl Cancer Inst.
Carney PA, Miglioretti DL, Yankaskas BC, et al. (2003). Individual and combined effects of age, breast density, and hormone replacement thearpy use on the accuracy of screening mammography. Ann Intern Med.
Catalano R, Winett L, Wallack L, et al. (2003). Evaluating a campaign to detect early stage breast tumors in the United States. Eur J Epidemiol.
Catzavelos C. (2000). Part III. The pathobiology of ductal carcinoma in situ. Curr Probl Cancer.
Centers for Disease Control and Prevention. (2006). National breast and cervical cancer early detection program.
Chiarelli AM, Moravan V, Halapy E, et al. (2003). False-positive result and reattendance in the Ontario Breast Screening Program. J Med Screen.
Claus EB, Stowe M, Carter D, et al. (2001). Breast carcinoma in situ: risk factors and screening patterns. J Natl Cancer Inst.
Collins LC, Tamimi RM, Baer HJ, et al. (2005). Outcome of patients with ductal carcinoma in situ untreated after diagnostic biopsy: results from the Nurses’ Health Study. Cancer.
de Gelder R, van As E, Tilanus-Linthorst MMA, et al. (2008). Breast cancer screening: evidence for false reassurance?. Int J Cancer.
Domar AD, Eyvazzadeh A, Allen S, et al. (2005). Relaxation techniques for reducing pain and anxiety during screening mammography. AJR. Am J Roentgenol.
Domenighetti G, D’Avanzo B, Egger M, et al. (2003). Women’s perception of the benefits of mammography screening: population-based survey in four countries.[see comment]. Int J Epidemiol.
Duffy SW, Tabar L, Vitak B, et al. (2003). The relative contributions of screen-detected in situ and invasive breast carcinomas in reducing mortality from the disease. Eur J Cancer.
Duffy SW, Tabar L, Vitak B, et al. (2006). Tumor size and breast cancer detection: what might be the effect of a less sensitive screening tool than mammography?. Breast J.
Erbas B, Provenzano E, Armes J, et al. (2006). The natural history of ductal carcinoma in situ of the breast: a review. Breast Cancer Res Treat.
Ernster VL, Ballard-Barbash R, Barlow WE, et al. (2002). Detection of ductal carcinoma in situ in women undergoing screening mammography. J Natl Cancer Inst.
Farria D, Feig SA. (2000). An introduction to economic issues in breast imaging. Radiol Clin North Am.
Fisher ER, Dignam J, Tan-Chiu E, et al. (1999). Pathologic findings from the National Surgical Adjuvant Breast Project (NSABP) eight-year update of Protocol B-17: intraductal carcinoma. Cancer.
Fisher ER, Sass R, Fisher B, et al. (1986). Pathologic findings from the National Surgical Adjuvant Breast Project (protocol 6). I. Intraductal carcinoma (DCIS). Cancer.
Greene SM, Geiger AM, Harris EL, et al. (2006). Impact of IRB requirements on a multicenter survey of prophylactic mastectomy outcomes. Ann Epidemiol.
Groenendijk RP, Kochen MP, van Engelenburg KC, et al. (2001). Detection of breast cancer after biopsy for false-positive screening mammography. Eur J Surg Oncol.
Hailey BJ, Carter CL, Burnett DR. (2000). Breast cancer attitudes, knowledge, and screening behavior in women with and without a family history of breast cancer. Health Care Women Int.
Hendrick RE, Cutter GR, Berns EA, et al. (2005). Community-based mammography practice: services, charges, and interpretation methods. AJR Am J Roentgenol.
Hofvind S, Skaane P, Vitak B, et al. (2005). Influence of review design on percentages of missed interval breast cancers: retrospective study of interval cancers in a population-based screening program. Radiology.
Hofvind SS, Wang H, Thoresen S. (2003). The Norwegian Breast Cancer Screening Program: re-attendance related to the women’s experiences, intentions and previous screening result. Cancer Causes Control.
Jackson VP. (2002). Screening mammography: controversies and headlines. Radiology.
Jensen A, Rank F, Dyreborg U, et al. (2006). Performance of combined clinical mammography and needle biopsy: a nationwide study from Denmark. Apmis.
Jensen A, Vejborg I, Severinsen N, et al. (2006). Performance of clinical mammography: a nationwide study from Denmark. Int J Cancer.
Jones JL. (2006). Overdiagnosis and overtreatment of breast cancer: progression of ductal carcinoma in situ: the pathological perspective. Breast Cancer Res.
Kerlikowske K, Molinaro A, Cha I, et al. (2003). Characteristics associated with recurrence among women with ductal carcinoma in situ treated by lumpectomy. J Natl Cancer Inst.
Kinsinger LS, Harris R, Qaqish B, et al. (1998). Using an office system intervention to increase breast cancer screening. J Gen Intern Med.
Lampic C, Thurfjell E, Sjoden PO. (2003). The influence of a false-positive mammogram on a woman’s subsequent behaviour for detecting breast cancer. Eur J Cancer.
Li CI, Daling JR, Malone KE, et al. (2005). Age-specific incidence rates of in situ breast carcinomas by histologic type, 1980 to 2001. Cancer Epidemiol Biomarkers Prev.
Lostumbo L, Carbine N, Wallace J, et al. (2006). Prophylactic mastectomy for the prevention of breast cancer. Cochrane Database of Systematic Reviews.
Lostumbo L, Carbine N, Wallace J, et al. (2007). Prophylactic mastectomy for the prevention of breast cancer. Cochrane Database of Systematic Reviews.
Lynge E, Olsen AH, Fracheboud J, et al. (2003). Reporting of performance indicators of mammography screening in Europe. Eur J Cancer Prev.
Mariotto R, Brancato B, Bonetti F, et al. (2007). Real-time reading in mammography breast screening. Radiol Med.
Miller NA, Chapman JA, Fish EB, et al. (2001). In situ duct carcinoma of the breast: clinical and histopathologic factors and association with recurrent carcinoma. Breast J.
Moja L, Brambilla C, Compagnoni A, et al. (2007). Trastuzumab containing regimens for early breast cancer. Cochrane Database of Systematic Reviews.
Morrow M. (1992). Pre-cancerous breast lesions: implications for breast cancer prevention trials. Int J Radiat Oncol Biol Phys.
Morrow M. (1995). The natural history of ductal carcinoma in situ. Implications for clinical decision making. Cancer.
Morrow M. (2004). The certainties and the uncertainties of ductal carcinoma in situ. J Natl Cancer Inst.
Nekhlyudov L, Barton MB, Elmore JG, et al. (2002). Breast self-examination: who teaches it, who is taught, and how often? (United States). Cancer Causes Control.
Nekhlyudov L, Li R, Fletcher SW. (2005). Information and involvement preferences of women in their 40s before their first screening mammogram. Arch Intern Med.
Oboler SK, Prochazka AV, Gonzales R, et al. (2002). Public expectations and attitudes for annual physical examinations and testing. Ann Intern Med.
O’Malley MS, Earp JA, Harris RP. (1997). Race and mammography use in two North Carolina counties. Am J Public Health.
Osborn GD, Gahir JK, Preece K, et al. (2006). Is general practitioner access to breast imaging safe?. Clin Radiol.
Otten JD, Karssemeijer N, Hendriks JH, et al. (2005). Effect of recall rate on earlier screen detection of breast cancers based on the Dutch performance indicators. J Natl Cancer Inst.
Page DL, Dupont WD, Rogers LW, et al. (1995). Continued local recurrence of carcinoma 15–25 years after a diagnosis of low grade ductal carcinoma in situ of the breast treated only by biopsy. Cancer.
Rakovitch E, Franssen E, Kim J, et al. (2003). A comparison of risk perception and psychological morbidity in women with ductal carcinoma in situ and early invasive breast cancer. Breast Cancer Res Treat.
Reisch LM, Barton MB, Fletcher SW, et al. (2000). Breast cancer screening use by African Americans and Whites in an HMO. J Gen Intern Med.
Rolnick SJ, Hart G, Barton MB, et al. (2004). Comparing breast cancer case identification using HMO computerized diagnostic data and SEER data. Am J Manag Care.
Schwartz LM, Woloshin S, Sox HC, et al. (2000). US women’s attitudes to false positive mammography results and detection of ductal carcinoma in situ: cross sectional survey. BMJ.
Sontag L, Axelrod DE. (2005). Evaluation of pathways for progression of heterogeneous breast tumors. J Theor Biol.
Steele WR, Mebane F, Viswanath K, et al. (2005). News media coverage of a women’s health contraversy: how newspapers and TV outlets covered a recent debate over screening mammography. Women Health.
Stomper PC, Margolin FR. (1994). Ductal carcinoma in situ: the mammographer’s perspective. Am J Roentgenol.
Tsikitis VL, Chung MA. (2006). Biology of ductal carcinoma in situ classification based on biologic potential. Am J Clin Oncol.
van de Vijver MJ. (2005). Biological variables and prognosis of DCIS. Breast.
Verbeek ALM, Broeders MJM, et al. (2003). Evaluation of The Netherlands breast cancer screening programme. Ann Oncol.
Vettorazzi M, Stocco C, Chirico A, et al. (2006). Quality control of mammography screening in the Veneto Region. Tumori.
Weir M. (2005). Missed breast cancer: the legal factors. J Law Med.
West CN, Geiger AM, Greene SM, et al. (2005). Race and ethnicity: comparing medical records to self-reports. J Natl Cancer Inst.
Xu JL, Fagerstrom RM, Prorok PC, et al. (2004). Estimating the cumulative risk of a false-positive test in a repeated screening program. Biometrics.
Young RF, Waller JB, Smitherman H. (2002). A breast cancer education and on-site screening intervention for unscreened African American women. J Cancer Educ.

### Treatment-focused

Baxter NN, Virnig BA, Durham SB, et al. (2004). Trends in the treatment of ductal carcinoma in situ of the breast. J Natl Cancer Inst.
Betsill WL, Rosen PP, Lieberman PH, et al. (1978). Intraductal carcinoma. Long-term follow-up after treatment by biopsy alone. JAMA.
Bijker N, Peterse JL, Duchateau L, et al. (2001). Risk factors for recurrence and metastasis after breast-conserving therapy for ductal carcinoma-in-situ: analysis of European Organization for Research and Treatment of Cancer Trial 10853. J Clin Oncol.
Bradley SJ, Weaver DW, Bouwman DL. (1990). Alternatives in the surgical management of in situ breast cancer. A meta-analysis of outcome. Am Surg.
Carrick S, Parker S, Wilcken N, et al. (2006). Single agent versus combination chemotherapy for metastatic breast cancer. Cochrane Database of Systematic Reviews.
Carty NJ, Carter C, Royle GT, et al. (1995). Management of ductal carcinoma in situ of the breast. Ann R Coll Surg Engl.
Cody HS. (2002). Current surgical management of breast cancer. Curr Opin Obstet Gynecol.
Cuncins-Hearn A, Boult M, Babidge W, et al. (2007). National Breast Cancer Audit: ductal carcinoma in situ management in Australia and New Zealand. ANZ J Surg.
Day R, Ganz PA, Costantino JP. (2001). Tamoxifen and depression: more evidence from the National Surgical Adjuvant Breast and Bowel Project’s Breast Cancer Prevention (P-1) Randomized Study. J Natl Cancer Inst.
Early Breast Cancer Trialist’s Collaborative Group. (2006). Multi-agent chemotherapy for early breast cancer. Cochrane Database of Systematic Reviews.
Early Breast Cancer Trialist’s Collaborative Group. (2006). Tamoxifen for early breast cancer. Cochrane Database of Systematic Reviews.
Ernster VL, Barclay J, Kerlikowske K, et al. (1996). Incidence of and treatment for ductal carcinoma in situ of the breast. JAMA.
Esserman L, Sepucha K, Ozanne E, et al. (2004). Applying the neoadjuvant paradigm to ductal carcinoma in situ. Ann Surg Oncol.
Esserman LJ, Wolverton D, Hylton N. (2000). Integration of breast imaging into cancer management. Curr Oncol Rep.
Fan HG, Houede-Tchen N, Yi QL, et al. (2005). Fatigue, menopausal symptoms, and cognitive function in women after adjuvant chemotherapy for breast cancer: 1- and 2-year follow-up of a prospective controlled study. J Clin Oncol.
Fentiman IS. (1989). The treatment of in situ breast cancer. Acta Oncol.
Fisher ER, Leeming R, Anderson S, et al. (1991). Conservative management of intraductal carcinoma (DCIS) of the breast. Collaborating NSABP investigators. J Surg Oncol.
Ford HT, Coombes RC, Gazet JC, et al. (2006). Long-term follow-up of a randomised trial designed to determine the need for irradiation following conservative surgery for the treatment of invasive breast cancer. Ann Oncol/ESMO.
Geiger AM, Yu O, Herrinton LJ, et al. (2005). A population-based study of bilateral prophylactic mastectomy efficacy in women at elevated risk for breast cancer in community practices. Arch Intern Med.
Herrinton LJ, Barlow WE, Yu O, et al. (2005). Efficacy of prophylactic mastectomy in women with unilateral breast cancer: a cancer research network project. J Clin Oncol.
Hetelekidis S, Schnitt SJ, Morrow M, et al. (1995). Management of ductal carcinoma in situ. CA Cancer J Clin.
Hickey BE, Francis D, Lehman MH. (2006). Sequencing of chemotherapy and radiation therapy for early breast cancer. Cochrane Database of Systematic Reviews.
Hickey BE, Francis D, Lehman MH. (2007). Sequencing of chemotherapy and radiation therapy for early breast cancer. Cochrane Database of Systematic Reviews.
Hjoris I, Sand NP, Andersen J, et al. (2000). Myocardial perfusion imaging in breast cancer patients treated with or without post-mastectomy radiotherapy. Radiother Oncol.
Hojris I, Andersen J, Overgaard M, et al. (2000). Late treatment-related morbidity in breast cancer patients randomized to postmastectomy radiotherapy and systemic treatment versus systemic treatment alone. Acta Oncol.
Jensen RA, Page DL. (2003). Ductal carcinoma in situ of the breast: impact of pathology on therapeutic decisions. Am J Surg Pathol.
Julien JP, Bijker N, Fentiman IS, et al. (2000). Radiotherapy in breast-conserving treatment for ductal carcinoma in situ: first results of the EORTC randomised phase III trial 10853. EORTC Breast Cancer Cooperative Group and EORTC Radiotherapy Group. Lancet.
Katz SJ, Lantz PM, Janz NK, et al. (2005). Patient involvement in surgery treatment decisions for breast cancer. J Clin Oncol.
Katz SJ, Lantz PM, Janz NK, et al. (2005). Patterns and correlates of local therapy for women with ductal carcinoma-in-situ. J Clin Oncol.
Latta EK, Tjan S, Parkes RK, et al. (2002). The role of HER2/neu overexpression/amplification in the progression of ductal carcinoma in situ to invasive carcinoma of the breast. Mod Pathol.
Lauridsen MC, Torsleff KR, Husted H, et al. (2000). Physiotherapy treatment of late symptoms following surgical treatment of breast cancer. Breast.
Lewin AA, Cohen A, Abitbol AA, et al. (1992). Conservative surgery and radiation therapy for intraductal carcinoma of the breast. J Fla Med Assoc.
Lundstrom E, Wilczek B, von Palffy Z, et al. (2001). Mammographic breast density during hormone replacement therapy: effects of continuous combination, unopposed transdermal and low-potency estrogen regimens. Climacteric.
Mokbel K, Cutuli B. (2006). Heterogeneity of ductal carcinoma in situ and its effects on management. Lancet Oncol.
Mokbel K. (2003). Current management of ductal carcinoma in situ of the breast. Int J Clin Oncol.
Morrow M, Strom EA, Bassett LW, et al. (2002). Standard for the management of ductal carcinoma in situ of the breast (DCIS). CA Cancer J Clin.
Sanders ME, Schuyler PA, Dupont WD, et al. (2005). The natural history of low-grade ductal carcinoma in situ of the breast in women treated by biopsy only revealed over 30 years of long-term follow-up. Cancer.
Schwartz GF. (2001). The current treatment of ductal carcinoma in situ. Breast J.
Skinner KA, Silverstein MJ. (2001). The management of ductal carcinoma in situ of the breast. Endocr Relat Cancer.
Solin LJ, Fourquet A, Vicini FA, et al. (2005). Long-term outcome after breast-conservation treatment with radiation for mammographically detected ductal carcinoma in situ of the breast. Cancer.
Talamonti MS. (1996). Management of ductal carcinoma in situ. Semin Surg Oncol.
Vicini FA, Recht A. (2002). Age at diagnosis and outcome for women with ductal carcinoma-in-situ of the breast: a critical review of the literature. J Clin Oncol.
Zellars R, Wolff AC. (2003). Local failure and prognostic factors in ductal carcinoma in situ: concentration on recent publications. Curr Opin Obstet Gynecol.

### Wrong age

Castells X, Molins E, Macia F. (2006). Cumulative false positive recall rate and association with participant related factors in a population based breast cancer screening programme. J Epidemiol Community Health.
Hofvind S, Wang H, Thoresen S. (2004). Do the results of the process indicators in the Norwegian Breast Cancer Screening Program predict future mortality reduction from breast cancer?. Acta Oncol.

### Does not break out data by age for meta-analysis

Schootman M, Jeffe D, Reschke A, et al. (2004). The full potential of breast cancer screening use to reduce mortality has not yet been realized in the United States. Breast Cancer Res Treat.
Swedish Organised Service Screening Evaluation Group. (2006). Reduction in breast cancer mortality from the organised service screening with mammography: 1. Further confirmation with extended data. Cancer Epidemiol Biomarkers Prev.
Swedish Organised Service Screening Evaluation Group. (2006). Reduction in breast cancer mortality from the organised service screening with mammography: 2. Validation with alternative analytic methods. Cancer Epidemiol Biomarkers Prev.

### Contextual only

ACOG. (2003). ACOG practice bulletin. Breast cancer screening. Number 42. April 2003. Int J Gynaecol Obstet.
Advisory Committee on Breast Cancer S. (2006). Screening for breast cancer in England: past and future. J Med Screen.
American Cancer Society. (2007). Cancer facts and figures 2007.
Andersen MR, Hager M, Su C, et al. (2002). Analysis of the cost-effectiveness of mammography promotion by volunteers in rural communities. Health education & behavior: the official publication of the Society for Public Health Education.
Baines CJ. (2003). Mammography screening: are women really giving informed consent?. J Natl Cancer Inst.
Barratt AL, Les Irwig M, Glasziou PP, et al. (2002). Benefits, harms and costs of screening mammography in women 70 years and over: a systematic review. Med J Aust.
Barton MB, Harris R, Fletcher SW. (1999). The rational clinical examination. Does this patient have breast cancer? The screening clinical breast examination: should it be done? How?. JAMA.
Baum M. (2004). Commentary: false premises, false promises and false positives--the case against mammographic screening for breast cancer.[comment]. Int J Epidemiol.
Baum M, Tobias JS. (2000). Effect of screening programme on mortality from breast cancer Investment in treatment would be more cost effective. BMJ.
Bech M, Gyrd-Hansen D. (2000). Cost implications of routine mammography screening of women 50–69 years in the county of Funen, Denmark. Health Policy.
Beckett JR, Kotre CJ, Michaelson JS. (2003). Analysis of benefit:risk ratio and mortality reduction for the UK Breast Screening Programme. Br J Radiol.
Bjurstam N, Bjorneld L, Duffy SW, et al. (1997). The Gothenburg breast screening trial: first results on mortality, incidence, and mode of detection for women ages 39–49 years at randomization. Cancer.
Black WC, Haggstrom DA, Welch HG. (2002). All-cause mortality in randomized trials of cancer screening. J Natl Cancer Inst.
Blanchard K, Colbert JA, Puri D, et al. (2004). Mammographic screening: patterns of use and estimated impact on breast carcinoma survival. Cancer.
Bowland L, Cockburn J, Cawson J, et al. (2003). Counselling interventions to address the psychological consequences of screening mammography: a randomised trial. Patient Educ Couns.
Boyd NF, Guo H, Martin LJ, et al. (2007). Mammographic density and the risk and detection of breast cancer. N Engl J Med.
Burnside E, Belkora J, Esserman L. (2001). The impact of alternative practices on the cost and quality of mammographic screening in the United States. Clin Breast Cancer.
Centers for Disease Control and Prevention. (2002). United States cancer statistics. 2002 incidence and mortality.
Chamot E, Perneger TV. (2001). Misconceptions about efficacy of mammography screening: a public health dilemma. J Epidemiol Community Health.
Chen SL, Clark S, Pierce LJ, et al. (2004). An academic health center cost analysis of screening mammography: creating a financially viable service. Cancer.
Chlebowski RT, Hendrix SL, Langer RD, et al. (2003). Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women’s Health Initiative Randomized Trial. JAMA.
Christiansen CL, Wang F, Barton MB, et al. (2000). Predicting the cumulative risk of false-positive mammograms. J Natl Cancer Inst.
Cimons M. (2002). Experts at odds over mammography. Nat Med.
Crandall CJ, Karlamangla A, Huang MH, et al. (2006). Association of new-onset breast discomfort with an increase in mammographic density during hormone therapy. Arch Intern Med.
Cuzick J, Forbes J, Edwards R, et al. (2002). First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet.
Das B, Feuer EJ, Mariotto A. (2005). Geographic association between mammography use and mortality reduction in the US. Cancer Causes Control.
Day NE. (2005). Overdiagnosis and breast cancer screening. Breast Cancer Res.
De Koning HJ. (2000). Breast cancer screening; cost-effective in practice?. Eur J Radiol.
Delaney G, Ung O, Bilous M, et al. (1997). Ductal carcinoma in situ. Part I: Definition and diagnosis. Aust N Z J Surg.
Delaney G, Ung O, Cahill S, et al. (1997). Ductal carcinoma in situ. Part 2: Treatment. Aust N Z J Surg.
Detsky AS, Laupacis A. (2007). Relevance of cost-effectiveness analysis to clinicians and policy makers. JAMA.
Deurloo EE, Muller SH, Peterse JL, et al. (2005). Clinically and mammographically occult breast lesions on MR images: Potential effect of computerized assessment on clinical reading. Radiology.
Duffy SW. (2005). Some current issues in breast cancer screening. J Med Screen.
Duffy SW, McCann J, Godward S, et al. (2006). Some issues in screening for breast and other cancers. J Med Screen.
Duffy SW, Tabar L, Vitak B, et al. (2003). The Swedish Two-County Trial of mammographic screening: cluster randomisation and end point evaluation. Ann Oncol.
Elmore JG, Miglioretti DL, Reisch LM, et al. (2002). Screening mammograms by community radiologists: Variability in false-positive rates. J Natl Cancer Inst.
Ernster VL, Barclay J, Kerlikowske K, et al. (2000). Mortality among women with ductal carcinoma in situ of the breast in the population-based surveillance, epidemiology and end results program. Arch Intern Med.
Evans AJ, Kutt E, Record C, et al. (2007). Radiological and pathological findings of interval cancers in a multi-centre, randomized, controlled trial of mammographic screening in women from age 40–41 years. Clin Radiol.
Farrow JH. (1970). Current concepts in the detection and treatment of the earliest of the early breast cancers. Cancer.
Feig SA. (2002). Current status of screening mammography. Obstet Gynecol Clin North Am.
Feig SA. (2006). Screening mammography: a successful public health initiative. Rev Panam Salud Publica.
Fenton JJ, Rolnick SJ, Harris EL, et al. (2007). Specificity of clinical breast examination in community practice. J Gen Intern Med.
Fenton JJ, Taplin SH, Carney PA, et al. (2007). Influence of Computer-Aided Detection on Performance of Screening Mammography. New Eng J Med.
Fletcher SW, Elmore JG. (2003). Mammographic screening for breast cancer. N Engl J Med.
Freedman GM, Anderson PR, Goldstein LJ, et al. (2003). Routine mammography is associated with earlier stage disease and greater eligibility for breast conservation in breast carcinoma patients age 40 years and older. Cancer.
Ghafoor A, Jemal A, Ward E, et al. (2003). Trends in breast cancer by race and ethnicity.[erratum appears in CA Cancer J Clin. 2004 May –Jun;54(3):181]. CA Cancer J Clin.
Gill KS, Yankaskas BC. (2004). Screening mammography performance and cancer detection among black women and white women in community practice. Cancer.
Gotzsche PC. (2002). Beyond randomized controlled trials: organized mammographic screening substantially reduces breast carcinoma mortality.[comment]. Cancer.
Groenewoud JH, Otten JD, Fracheboud J, et al. (2007). Cost-effectiveness of different reading and referral strategies in mammography screening in the Netherlands. Breast Cancer Res Treat.
Hukkinen K, Vehmas T, Pamilo M, et al. (2006). Effect of computer-aided detection on mammographic performance: experimental study on readers with different levels of experience. Acta Radiol.
Jatoi I, Miller AB. (2003). Why is breast-cancer mortality declining?. Lancet Oncol.
Kauhava L, Immonen-Raiha P, Parvinen I, et al. (2004). Lower costs of hospital treatment of breast cancer through a population-based mammography screening programme. Eur J Public Health.
Kauhava L, Immonen-Raiha P, Parvinen I, et al. (2006). Population-based mammography screening results in substantial savings in treatment costs for fatal breast cancer. Breast Cancer Res Treat.
Kokko R, Hakama M, Holli K. (2005). Follow-up cost of breast cancer patients with localized disease after primary treatment: a randomized trial. Breast Cancer Res Treat.
Kopans DB. (2003). The most recent breast cancer screening controversy about whether mammographic screening benefits women at any age: nonsense and nonscience. AJR.
Kopans DB. (2004). Get the facts straight. J Clin Oncol.
Kriege M, Brekelmans CTM, Boetes C, et al. (2004). Efficacy of MRI and mammography for breast-cancer screening in women with a familial or genetic predisposition.[see comment]. N Engl J Med.
Kuhl CK, Schrading S, Leutner CC, et al. (2005). Mammography, breast ultrasound, and magnetic resonance imaging for surveillance of women at high familial risk for breast cancer. J Clin Oncol.
Lehman CD, Blume JD, Weatherall P, et al. (2005). Screening women at high risk for breast cancer with mammography and magnetic resonance imaging. Cancer.
Lindfors KK, McGahan MC, Rosenquist CJ, et al. (2006). Computer-aided detection of breast cancer: a cost-effectiveness study. Radiology.
Lisby MD. (2004). Screening mammography in women 40 to 49 years of age. Am Fam Physician.
McAlearney AS, Reeves KW, Tatum C, et al. (2005). Perceptions of insurance coverage for screening mammography among women in need of screening. Cancer.
McTiernan A, Martin CF, Peck JD, et al. (2005). Estrogen-plus-progestin use and mammographic density in postmenopausal women: women’s health initiative randomized trial. J Natl Cancer Inst.
Miller AB. (2001). Screening for breast cancer with mammography. Lancet.
Miller AB, Baines CJ, To T. (1998). The Gothenburg breast screening trial: first results on mortality, incidence, and mode of detection for women ages 39–49 years at randomization. Cancer.
Miller AB, To T, Baines CJ, et al. (1997). The Canadian National Breast Screening Study: update on breast cancer mortality. J Natl Cancer Inst.
Morimoto T, Sasa M, Yamaguchi T, et al. (2000). Breast cancer screening by mammography in women aged under 50 years in Japan. Anticancer Res.
Moss S. (1999). A trial to study the effect on breast cancer mortality of annual mammographic screening in women starting at age 40. Trial Steering Group. J Med Screen.
Moss S, Waller M, Anderson TJ, et al. (2005). Randomised controlled trial of mammographic screening in women from age 40: predicted mortality based on surrogate outcome measures. Br J Cancer.
Narod SA. (2001). Re: Canadian national breast screening study-2: 13-year results of a randomized trial in women aged 50–59 years. J Natl Cancer Inst.
National Cancer Institute. Cancer control research.
National Center for Health Statistics. (2005). Health, United States, 2005 With chartbook on trends in the health of Americans.
National Conference of State Legislatures. (2006). Breast and cervical cancer update.
Neeser K, Szucs T, Bulliard JL, et al. (2007). Cost-effectiveness analysis of a quality-controlled mammography screening program from the Swiss statutory health-care perspective: Quantitative assessment of the most influential factors. Value Health.
Nystrom L. (2000). How effective is screening for breast cancer?. BMJ.
Oestreicher N, Lehman CD, Seger DJ, et al. (2005). The incremental contribution of clinical breast examination to invasive cancer detection in a mammography screening program. AJR. American Journal of Roentgenology.
Ohnuki K, Kuriyama S, Shoji N, et al. (2006). Cost-effectiveness analysis of screening modalities for breast cancer in Japan with special reference to women aged 40–49 years. Cancer Sci.
Oluwole SF, Ali AO, Adu A, et al. (2003). Impact of cancer screening program on breast cancer stage at diagnosis in a medically underserved urban community. J Am Coll Surg.
Orel SG, Schnall MD. (2001). MR imaging of the breast for the detection, diagnosis, and staging of breast cancer.[see comment]. Radiology.
Plevritis SK. (2000). A framework for evaluating the cost-effectiveness of MRI screening for breast cancer. Eur Radiol.
Plevritis SK, Ikeda DM. (2002). Ethical issues in contrast-enhanced magnetic resonance imaging screening for breast cancer. Top Magn Reson Imaging.
Port ER, Park A, Borgen PI, et al. (2007). Results of MRI screening for breast cancer in high-risk patients with LCIS and atypical hyperplasia. Ann Surg Oncol.
Qaseem A, Snow V, Sherif K, et al. (2007). Screening Mammography for Women 40 to 49 Years of Age: A Clinical Practice Guideline from the American College of Physicians. Ann Intern Med.
Randal J. (2000). After 40 years, mammography remains as much emotion as science. J Natl Cancer Inst.
Ransohoff DF, Harris RP. (1997). Lessons from the mammography screening controversy: can we improve the debate?. Ann Intern Med.
Ringash J. (2001). Preventive health care, 2001 update: screening mammography among women aged 40–49 years at average risk of breast cancer. CMAJ.
Rubin E, Mennemeyer ST, Desmond RA, et al. (2001). Reducing the cost of diagnosis of breast carcinoma: impact of ultrasound and imaging-guided biopsies on a clinical breast practice. Cancer.
Sampalis FS, Denis R, Picard D, et al. (2003). International prospective evaluation of scintimammography with (99m)technetium sestamibi. Am J Surg.
Schell MJ, Yankaskas BC, Ballard-Barbash R, et al. (2007). Evidence-based target recall rates for screening mammography. Radiology.
Smith RA, Saslow D, Sawyer KA, et al. (2003). American Cancer Society guidelines for breast cancer screening: Update 2003. CA: Cancer J Clin.
Spelic DC. (2003). Dose and image quality in mammography: trends during the first decade of MQSA.
Stefanick ML, Anderson GL, Margolis KL, et al. (2006). Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA.
Stout NK, Rosenberg MA, Trentham-Dietz A, et al. (2006). Retrospective cost-effectiveness analysis of screening mammography. J Natl Cancer Inst.
Summaries for Patients. (2002). Summaries for patients. Mammograms in women age 40 to 49: results of the Canadian Breast Cancer Screening study.[original report. Ann Intern Med.
Tabar L, Chen HH, Fagerberg G, et al. (1997). Recent results from the Swedish Two-County Trial: the effects of age, histologic type, and mode of detection on the efficacy of breast cancer screening. J Natl Cancer Inst.
Tabar L, Dean PB. (2003). Mammography and breast cancer: the new era. Int J Gynaecol Obstet.
Tabar L, Smith RA, Duffy SW. (2002). Update on effects of screening mammography. Lancet.
Taplin SH, Ichikawa L, Yood MU, et al. (2004). Reason for late-stage break cancer: Absence of screening or detection, or breakdown in follow-up?. J Natl Cancer Inst.
Tosteson AN, Stout NK, Fryback DG, et al. (2008). Cost-effectiveness of digital mammography breast cancer screening. Ann Intern Med.
Veronesi U, Boyle P, Goldhirsch A, et al. (2005). Breast cancer. Lancet.
Wai ES, D’Yachkova Y, Olivotto IA, et al. (2005). Comparison of 1- and 2-year screening intervals for women undergoing screening mammography. Br J Cancer.
Wang H, Karesen R, Hervik A, et al. (2001). Mammography screening in Norway: results from the first screening round in four counties and cost-effectiveness of a modeled nationwide screening. Cancer Causes Control.
Warren R, Hayes C, Pointon L, et al. (2006). A test of performance of breast MRI interpretation in a multicentre screening study. Magn Reson Imaging.
Weir HK, Thun MJ, Hankey BF, et al. (2003). Annual report to the nation on the status of cancer, 1975–2000 featuring the uses of surveillance data for cancer prevention and control. J Natl Cancer Inst.

### Non-English language

Alimoglu E, Alimoglu MK, Kabaalioglu A, et al. (2004). [Mammography-related pain and anxiety]. Tan¿sal ve giri¿imsel radyoloji : T¿bbi Goruntuleme ve Giri¿imsel Radyoloji Derne¿i yay¿n organ¿.
Golder WA. (2001). [Magnetic resonance imaging of the breast: costs and efficiency]. Onkologie.
Wobbes T. (2005). [MRI for breast disease diagnosis; an asset, but the proper place has to be determined first]. Ned Tijdschr Geneeskd.

### Covered by included papers or previous USPSTF report

Alexander FE. (1997). The Edinburgh Randomized Trial of Breast Cancer Screening. J Natl Cancer Inst.
Alexander FE, Anderson TJ, Brown HK, et al. (1994). The Edinburgh randomised trial of breast cancer screening: results after 10 years of follow-up. Br J Cancer.
Alexander FE, Anderson TJ, Brown HK, et al. (1999). 14 years of follow-up from the Edinburgh randomised trial of breast-cancer screening. Lancet.
Andersson I, Aspegren K, Janzon L, et al. (1988). Mammographic screening and mortality from breast cancer: the Malmo mammographic screening trial. BMJ.
Andersson I, Janzon L. (1997). Reduced breast cancer mortality in women under age 50: updated results from the Malmo Mammographic Screening Program. J Natl Cancer Inst. Monographs.
Andersson I, Janzon L, Sigfusson BF, et al. (1985). Mammographic breast cancer screening--a randomized trial in Malmo, Sweden. Maturitas.
Aro AR, Pilvikki Absetz S, van Elderen TM, et al. (2000). False-positive findings in mammography screening induces short-term distress - breast cancer-specific concern prevails longer. Eur J Cancer.
Berglund G, Nilsson P, Eriksson KF, et al. (2000). Long-term outcome of the Malmo preventive project: mortality and cardiovascular morbidity. J Intern Med.
Bjurstam N, Bjorneld L, Duffy SW, et al. (1997). The Gothenburg Breast Cancer Screening Trial: preliminary results on breast cancer mortality for women aged 39–49. J Natl Cancer Inst.
Dullum JR, Lewis EC, Mayer JA. (2000). Rates and correlates of discomfort associated with mammography. Radiology.
Elwood JM, Cox B, Richardson AK, et al. (1993). The effectiveness of breast cancer screening by mammography in younger women. Online J Curr Clin Trials.
Feig SA, Hendrick RE, Feig SA, et al. (1997). Radiation risk from screening mammography of women aged 40–49 years. J Natl Cancer Inst.
Frisell J, Eklund G, Hellstrom L, et al. (1991). Randomized study of mammography screening--preliminary report on mortality in the Stockholm trial. Breast Cancer Res Treat.
Frisell J, Lidbrink E. (1997). The Stockholm Mammographic Screening Trial: Risks and benefits in age group 40–49 years. J Natl Cancer Inst.
Frisell J, Lidbrink E, Hellstrom L, et al. (1997). Followup after 11 years--update of mortality results in the Stockholm mammographic screening trial. Breast Cancer Res Treat.
Harris R. (1997). Variation of benefits and harms of breast cancer screening with age. J Natl Cancer Inst.
Hendrick RE, Smith RA, Rutledge JH, et al. (1997). Benefit of screening mammography in women aged 40–49 a new meta-analysis of randomized controlled trials. J Natl Cancer Inst.
Hislop TG, Harris SR, Jackson J, et al. (2002). Satisfaction and anxiety for women during investigation of an abnormal screening mammogram. Breast Cancer Res Treat.
Kosters JP, Gotzsche PC. (2003). Regular self-examination or clinical examination for early detection of breast cancer. The Cochrance Database of Systematic Reviews.
Lampic C, Thurfjell E, Bergh J, et al. (2001). Short- and long-term anxiety and depression in women recalled after breast cancer screening. Eur J Cancer.
Larsson LG, Andersson I, Bjurstam N, et al. (1997). Updated overview of the Swedish Randomized Trials on Breast Cancer Screening with Mammography: age group 40–49 at randomization. J Natl Cancer Inst.
McCann J, Stockton D, Godward S. (2002). Impact of false-positive mammography on subsequent screening attendance and risk of cancer. Breast Cancer Res.
Miller AB, Baines CJ, To T, et al. (1992). Canadian National Breast Screening Study: 1. Breast cancer detection and death rates among women aged 40 to 49 years. CMAJ.
Miller AB, Baines CJ, To T, et al. (1992). Canadian National Breast Screening Study: 2. Breast cancer detection and death rates among women aged 50 to 59 years. CMAJ.
Millis RR, Thynne GS, Millis RR, et al. (1975). In situ intraduct carcinoma of the breast: a long term follow-up study. Br J Surg.
Nystrom L, Rutqvist LE, Wall S, et al. (1993). Breast cancer screening with mammography: overview of Swedish randomised trials. Lancet.
O’Sullivan I, Sutton S, Dixon S, et al. (2001). False positive results do not have a negative effect on reattendance for subsequent breast screening. J Med Screen.
Roberts MM, Alexander FE, Anderson TJ, et al. (1990). Edinburgh trial of screening for breast cancer: mortality at seven years. Lancet.
Rosen PP, Braun DW, Kinne DE, et al. (1980). The clinical significance of pre-invasive breast carcinoma. Cancer.
Semiglazov VF, Moiseenko VM, Semiglazov VF, et al. (1987). Breast self-examination for the early detection of breast cancer: a USSR/WHO controlled trial in Leningrad. Bull World Health Organ.
Semiglazov VF, Moiseyenko VM, Bavli JL, et al. (1992). The role of breast self-examination in early breast cancer detection (results of the 5-years USSR/WHO randomized study in Leningrad). Eur J Epidemiol.
Semiglazov VF, Moiseyenko VM, Manikhas AG, et al. (1999). Interim results of a prospective randomised study of self-examination for early detection of breast cancer. Vopr Onkol.
Semiglazov VF, Sagaidak VN, Moiseyenko VM, et al. (1993). Study of the role of breast self-examination in the reduction of mortality from breast cancer The Russian Federation/World Health Organization Study. Eur J Cancer.
Shapiro S, Venet W, Strax P, et al. (1988). Current results of the breast cancer screening randomized trial: the Health Insurance Plan (HIP) of greater New York study.
Shapiro S, Venet W, Strax P, et al. (1985). Selection, follow-up, and analysis in the Health Insurance Plan Study: a randomized trial with breast cancer screening. Natl Cancer Inst Monogr.
Smart CR, Hendrick RE, Rutledge JH, et al. (1995). Benefit of mammography screening in women ages 40 to 49 years. Current evidence from randomized controlled trials. Cancer.
Tabar L, Fagerberg CJ, Gad A, et al. (1985). Reduction in mortality from breast cancer after mass screening with mammography. Randomised trial from the Breast Cancer Screening Working Group of the Swedish National Board of Health and Welfare. Lancet.
Tabar L, Fagerberg G, Duffy SW, et al. (1989). The Swedish two county trial of mammographic screening for breast cancer: recent results and calculation of benefit. J Epidemiol Community Health.
Tabar L, Vitak B, Chen HH, et al. (2000). The Swedish Two-County Trial twenty years later. Updated mortality results and new insights from long-term follow-up. Radiol Clin North Am.
Tabar L, Vitak B, Chen HH, et al. (1999). Update of the Swedish Two-County Trial of breast cancer screening: histologic grade-specific and age-specific results. Swiss Surg.
Thomas DB, Gao DL, Self SG, et al. (1997). Randomized trial of breast self-examination in Shanghai: methodology and preliminary results. J Natl Cancer Inst.
Van Dijck JA, Verbeek AL, Beex LV, et al. (1996). Mammographic screening after the age of 65 years: evidence for a reduction in breast cancer mortality. Int J Cancer.
Vorherr H. (1984). Pathobiology of breast cancer--treatment implications. Eur J Obstet Gynecol Reprod Biol.

## Appendix B4. U.S. Preventive Services Task Force Quality Rating Methodology for Randomized Controlled Trials and Observational Studies1

### Randomized Controlled Trials (RCTs) and Cohort Studies

#### Criteria

- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intension-to-treat analysis for RCTs

#### Definition of ratings based on above criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.

Poor: Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

### Case Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variable

#### Definition of ratings based on criteria above

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.

Poor: Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

##### REFERENCE

1 Harris RP, Helfand M, Woolf SH, et al. (2001). Current Methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med.

## Appendix B5. Quality Rating Methodology for Systematic Reviews1–3

1. Comprehensiveness of sources/search strategy used:
  a. Were search terms reported?
  b. Was the search comprehensive (Medline, search reference lists and/or experts)?
  c. Were the search terms applicable?
2. Standard appraisal of included studies:
  a. Were inclusion/exclusion criteria reported?
  b. Are criteria valid?
3. Quality/validity assessment:
  a. Were criteria for validity/quality assessment explicit and applied to all studies?
  b. Were quality criteria appropriate (e.g. criteria appropriate for study design)?
4. Analysis/synthesis:
  a. Were methods used to combine studies reported?
  b. Were studies that were combined similar to one another (e.g. appropriate to combine, similar patient populations etc)?
5. Validity of conclusions:
  a. Were conclusions supported by the data?
6. Recency and relevance:
  a. Is the study recent and relevant to scope?

### REFERENCES

1 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med.
2 National Institute for Health and Clinical Excellence. (2006). The Guidelines Manual.
3 Oxman AD, Guyatt GH. (1991). Validation of an index of the quality of review articles. J Clin Epidemiol.

## Appendix B6. Details of the Meta-analysis

The meta-analysis is an update of the previous 2002 meta-analysis that includes results from published trials of mammography screening for women age 39–49 years reporting reduction in breast cancer mortality. With the addition of only 1 new data point, the meta-analysis for the update was less extensive than the 2002 meta-analysis. We did not update the model for relative risk and length of follow-up (the two-level hierarchical model). We conducted similar updates for other age groups for context.

As with the original 2002 meta-analysis, we estimated the model by using a Bayesian data analytic framework but this time using the BRugs package in R.1,2 BRugs is an R interface to OpenBUGS, the successor to WinBUGS. The R code to create the dataset is below.

# R code to create dataset

study <- c(‘Age’, ‘CNBSS-1’, ‘HIP’, ‘Gothenburg’, ‘Stockholm’, ‘Malmo’, ‘Kopparberg’, ‘Ostergotland’)

y.int <- c(105, 105, 64, 34, 34, 53, 22, 31)

n.int <- c(53884, 25214, 13740, 11724, 14303, 13568, 9582, 10285)

py.int <- c(578390, 282606, 192360, NA, 203000, 184000, 124566, 172000)

y.cntl <- c(251, 108, 82, 59, 13, 66, 16, 30)

n.cntl <- c(106956, 25216, 13740, 14217, 8021, 12279, 5031, 10459)

py.cntl <- c(1149380, 282575, 192360, NA, 117000, 160000, 65403, 176000)

n <- 10000

rate.int <- n * y.int/n.int

rate.cntl <- n * y.cntl/n.cntl

rr <- rate.int/rate.cntl

rd <- rate.int-rate.cntl

nns <- 1/((y.cntl/n.cntl) - (y.int/n.int))

dataset <- data.frame(

study,

y.int, n.int, py.int, rate.int,

y.cntl, n.cntl, py.cntl, rate.cntl,

rr, rd, nns

)

# Save dataset for BRugs to use

dataset.bugs <- cbind(y.int, n.int, y.cntl, n.cntl)

colnames(dataset.bugs) <- c(“y.int”, “n.int”, “y.cntl”, “n.cntl”)

bugsData(data.frame(dataset.bugs), fileName=“dataset.bugs”, digits = 5)

constants <- cbind(nrow(dataset.bugs))

colnames(constants) <- c(“n”)

bugsData(data.frame(constants), fileName=“constants.bugs”, digits = 1)

The model assumes that the number of deaths from each study come from a binomial distribution with the probability parameter of α for the control group and α + β for the screening group. A random component, σ z_i_, is added to both probability parameters to allow for the random effect of the study _i_. Noninformative prior probability distributions were used.

# BUGS model

# This model is saved in a text file named “model.bugs”

model;

{

for(i in 1 : n) {

z[i] ~ dnorm(0, 1)

logit(p.int[i]) <- alpha + beta + sigma * z[i]

logit(p.cntl[i]) <- alpha + sigma * z[i]

y.int[i] ~ dbin(p.int[i], n.int[i])

y.cntl[i] ~ dbin(p.cntl[i], n.cntl[i])

}

alpha ~ dnorm(−5.0, 1.0E-1)

beta ~ dnorm(0.0, 1.0E-1)

sigma ~ dnorm(0.5, 1.0E-1) I(0,)

}

Four separate Markov chains with overdispersed initial values were used for estimation. A burn-in of 10,000 draws was used to initialize the chains and was checked for convergence.

# Check the model and load the dataset

modelCheck(“model.bugs”)

modelData(“constants.bugs”)

modelData(“dataset.bugs”)

# Compile the model with 4 MCMC chains

modelCompile(numChains=4)

# Generate overdispersed initial values

modelGenInits()

# Keep MCMC samples of parameters alpha, beta, and sigma

samplesSet(“alpha”)

samplesSet(“beta”)

samplesSet(“sigma”)

# Thin samples so only 1000 draws are left

samplesSetThin(10000/(1000/getNumChains()))

# Generate 10,000 burn-in draws

modelUpdate(10000)

samplesHistory(“*”, thin=samplesGetThin())

The convergence of the parameter estimation was assessed and deemed adequate from the 10,000 burn-in draws. Next, we generated 100,000 draws from the four chains. These draws were thinned to yield a sample of 1,000 uncorrelated estimates from the posterior distributions.

# Clear samples from the previous burn-in

samplesClear(“*”)

# Keep MCMC samples of parameters alpha, beta, and sigma

samplesSet(“alpha”)

samplesSet(“beta”)

samplesSet(“sigma”)

# Thin samples so only 1000 draws are left

samplesSetThin(100000/(1000/getNumChains()))

modelUpdate(100000)

samplesHistory(“*”, thin=samplesGetThin())

# Check correlation of the thinned samples

for (i in 1:getNumChains()) {

samplesAutoC(“*”, i, thin=samplesGetThin())

}

# Check the probability distribution of the parameters

samplesDensity(“*”, thin=samplesGetThin())

# Output sample estimates to an R object

brugs.nodes <- samplesHistory(“*”, thin=samplesGetThin(), plot=FALSE)

After the model was estimated and the samples were thinned, sample rates per 10,000 women screened with mammography and control participants were calculated from the estimates of alpha and beta. Sample relative risk, risk difference, and number needed to invite to screening were calculated from the sample rates.

# Assign parameter samples to separate R vectors

alpha <- as.vector(brugs.nodes$alpha)

beta <- as.vector(brugs.nodes$beta)

sigma <- as.vector(brugs.nodes$sigma)

# Rate calculations

# Note: this produces 1000 samples for each rate, RR, RD, and NNS

n <- 10000

rate1 <- n * exp(alpha+beta)/(1+exp(alpha+beta))

rate2 <- n * exp(alpha)/(1+exp(alpha))

rr <- rate1/rate2

rd <- rate1 - rate2

nns <- n/(rate2 - rate1)

From the 1,000 thinned posterior samples, point estimates (mean) and 95% credible intervals (2.5 and 97.5 percentiles) for relative risk, risk difference, and number needed to invite to screening were calculated.

# Define R function; it will be used a number of times

brugs.nodesummary <- function(x, name) {

Samples <- length(x)

Mean <- mean(x)

SD <- sd(x)

MCMC.error <- sd(x)/sqrt(length(x))

Median <- median(x)

P.025 <- quantile(x, prob=c(0.025))

P.975 <- quantile(x, prob=c(0.975))

nodesummary <- data.frame(cbind(Samples, Mean, Median, P.025, P.975, SD, MCMC.error))

rownames(nodesummary) <- name

colnames(nodesummary) <- c(“Samples”, “Mean”, “Median”, “P.025”, “P.975”, “SD”, “MCMC.error”)

data.frame(nodesummary)

}

# Call defined function brugs.nodesummary

print(brugs.nodesummary(alpha, “alpha”))

print(brugs.nodesummary(beta, “beta”))

print(brugs.nodesummary(sigma, “sigma”))

print(brugs.nodesummary(rate1, “rate1”))

print(brugs.nodesummary(rate2, “rate2”))

print(brugs.nodesummary(rr, “rr”))

print(brugs.nodesummary(rd, “rd”))

print(brugs.nodesummary(nns, “nns”))

The pooled number needed to invite to screening could be misleading if the baseline risk of mortality is appreciably varied between studies. 3 One recommendation to accommodate this is to apply the pooled relative risk estimate to a range of control rates and then calculate number needed to invite to screening. The pooled rate of mortality among the control groups of our studies was estimated to be 35.5 deaths per 10,000 women (95% CrI, 25.1–48.3). The range of mortality rates among the control groups was 16.2 to 59.7 per 10,000 women. Applying the pooled relative risk estimate of 0.85 to the high end of the mortality rate range (59.7) yields a number needed to invite to screening estimate of 1,116 per 10,000 women. Applying the pooled relative risk estimate of 0.85 to the low end of the mortality rate range (16.2) yields a number needed to invite to screening estimate of 4,115 per 10,000 women. This range 1,116 to 4,115 per 10,000 women is within the 95% CrI we report for number needed to invite to screening that we estimated from the posterior distributions of our mortality rate estimates. Alternatively, the bounds of our 95% CrI to number needed to invite to screening correspond to a range of control group mortality rates of 10.5 to 71.8 per 10,000 women, a range beyond that seen in the studies included in our analysis.

### REFERENCES

1 R Development Core Team. (2006). R: A Language and Environment for Statistical Computing.
2 Thomas A, O’Hara B, Ligges U, Sturtz S. (2006). Making BUGS Open. R News.
3 Smeeth L, Haines A, Ebrahim S. (1999). Numbers needed to treat derived from meta-analyses – sometimes informative, usually misleading. BMJ.

## Appendix B7. Breast Cancer Surveillance Consortium Methods

### Breast Cancer Surveillance Consortium

In 1994 the National Cancer Institute (NCI) established the Breast Cancer Surveillance Consortium (BCSC) to study breast cancer screening practices in the United States, with the recognition that results from controlled clinical trials of mammography may differ from the results of community screening practices. Each of the Consortium’s seven research sites collects population-based screening and diagnostic mammography data and links it to state cancer registries. Sites include the Carolina Mammography Registry (North Carolina), Group Health Cooperative (Seattle), New Hampshire Mammography Network, San Francisco Mammography Registry, Vermont Breast Cancer Surveillance System, Colorado Mammography Project, and New Mexico Mammography Project. In five of the states, mammography data is also linked to pathology registries, which include benign as well as malignant outcomes. A comparison of women represented in the BCSC against 2000 Census data shows that Consortium sites are located in counties that contain slightly more than 5% of the U.S. population, and represent the population in important sociodemographic respects.1

Currently, the Consortium’s database contains information on 6,000,000 mammography examinations, 2,017,869 women, and 74,000 breast cancer cases.2 Detailed information on the distribution of key variables, mammographic data, characteristics of cases, and screening performance, among others, are detailed on the BCSC website: http://breastscreening.cancer.gov/data/

BCSC data include screening as well as diagnostic mammography. Screening mammography examinations are those designated as such by the ordering provider or radiologist, and not performed within 9 months of a previous one. Diagnostic mammography examinations are those indicated as such when ordered, or by the radiologist, or those performed for a woman reporting breast symptoms. Mammography information includes breast density, BI-RADS score, and recommendations for further imaging or work-up. In addition, prior to each mammography examination, a woman fills out a questionnaire which includes demographic as well as previous mammography information. Each mammography examination is given an initial BI-RADs score which categorizes it as “positive” or “negative.” In our analysis, an initial score of 0, 4, 5, or 3 with immediate work-up is considered positive, whereas a score of 1, 2 or 3 with short-term interval work-up (3–6 months) is negative. Additional imaging, such as such as magnification, ultrasound, compression or repeat views, or a diagnostic procedure is linked to screening mammography if done within 60 days of mammography.

In this report, we included BCSC data from 2000–2005 to examine the 1) frequency of additional imaging and biopsy procedures resulting from positive screening mammography, 3) potential adverse effects of mammography screening, and 4) relative incidence of DCIS and invasive cancers detected by mammography screening. Information for women under age 40 years or who have a history of breast augmentation or previous breast cancer diagnosis has been excluded.

#### REFERENCES

1 National Cancer Institute. (2004). Breast Cancer Surveillance Consortium: Evaluating Screening Performance in Practice. NIH Publication No. 04–5490.
2 National Cancer Institute. (2007). Breast Cancer Surveillance Consortium Fact Sheet.

## Appendix B8. Expert Reviewers of the Draft Report

Helen J. Barr, MD

Director, Division of Mammography Quality and Radiation Programs, Center for Devices and Radiological Health, U.S. Food and Drug Administration, Rockville, Maryland

Nancy N. Baxter, MD, PhD, FRCSC, FACRS

Division of General Surgery, University of Toronto St. Michael’s Hospital, Toronto, Canada

Donald A. Berry, PhD

Head, Division of Quantitative Sciences, Professor and Frank T. McGraw Memorial Chair for Cancer Research, Chairman, Department of Biostatistics, University of Texas, MD Anderson Cancer Center

Stephen W. Duffy, BSc, MSc, CStat

Centre for Epidemiology, Mathematics and Statistics, Wolfson Institute of Preventive Medicine, London, United Kingdom

Suzanne W. Fletcher, MD

Department of Ambulatory Care and Prevention, Harvard Medical School and Harvard Pilgrim Health Care, Boston, United States

Ronald G. Kaczmarek, MD, MPH

Center for Devices and Radiological Health, Food and Drug Administration, Rockville, Maryland

Linda S. Kinsinger, MD, MPH

Director of the National Center for Prevention, Department of Veterans Affairs, Austin, Texas

Barnett S. Kramer, MD

Director, Office of Disease Prevention, National Institutes of Health

Herschel W. Lawson, MD, FACOG

Senior Medical Advisor, Division of Cancer Prevention and Control, Centers for Disease Control and Prevention, Atlanta, Georgia

Anthony B. Miller, MD

Professor Emeritus and Head, Division of Clinical Epidemiology, German Cancer Research Centre, Heidelberg, Germany

Jacqueline W. Miller, MD

National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia

Eugenio Paci, MD

Unit of Clinical and Descriptive Epidemiology, Centre for Study and Prevention of Cancer, Florence, Italy

Philip C. Prorok, PhD

Division of Cancer Prevention, National Cancer Institute, Bethesda, Maryland

Lisa C. Richardson, MDnnn

Medical Officer, Centers for Disease Control and Prevention, Atlanta, Georgia

Robert C. Smith, MD, PhD

United States Food and Drug Administration