# Appendix A1 Acronyms and Abbreviations

ACOG: American College of Obstetricians and Gynecologists
ACS: American Cancer Society
AHRQ: Agency for Healthcare, Research, and Quality
BCSC: Breast Cancer Surveillance Consortium
BI-RADS: Breast Imaging Reporting and Data System
BSE: Breast Self Examination
CBE: Clinical Breast Examination
CI: Confidence Interval
CTFPHC: Canadian Task Force on Preventative Health Care
CrI: Credible Interval
DCIS: Ductal carcinoma in situ
EBCN: European Breast Cancer Network
EPC: Evidence-based Practice Center
EUREF: European Reference Organisation for Quality Assured Breast Screening and Diagnostic Services
EUSOMA: European Society of Mastology
FNA: Fine Needle Aspiration
LCIS: Lobular carcinoma in situ
MRI: Magnetic Resonance Imaging
NCI: National Cancer Institute
NHSBSP: UK National Health Service Breast Screening Programme
NNI: Number Needed to Invite to Screen
NNS: Number Needed to Screen
NR: Not reported
QALY: Quality-adjusted life-year
RR: Relative Risk
SEER: Surveillance Epidemiology and End Results
SES: Socioeconomic Status
USD: US Dollar
USPSTF: US Preventive Services Task Force
WHI: Women’s Health Initiative
WHO: World Health Organization