# 3 Results

## Literature Search Results

Searches yielded 4,088 citations (Appendix IV), from which we identified relevant analyses of emerging risk factors from 64 cohorts (Table 3). CRP, homocysteine, and lipoprotein(a) were evaluated in many of the cohorts. Conversely, EBCT, IMT, and periodontal disease were studied in the fewest settings and in few, if any, of the best-known and largest cohorts used in cardiovascular epidemiology.

The analyses summarized in Table 3 vary substantially with respect to validity and applicability. The strongest evaluations were those in cohorts that had been followed for 10 years or more and that had complete evaluations for traditional risk factors prior to initiation of treatment for hyperlipidemia or hypertension. Most evaluations were weaker in that subjects were followed for less time or had incomplete evaluations that did not measure all relevant Framingham risk factors at the time of inception.

## Key Question 1. Impact of Using Novel Risk Markers

We found no direct evidence from randomized trials that stratification of asymptomatic adults using novel risk markers leads to reduced incidence of CHD events compared with the use of Framingham risk factors alone.

## Key Question 2. Prediction of CHD Events

What novel risk markers accurately predict cardiovascular events independent of Framingham risk factors? What is the added predictive value of novel risk markers? When data were available, this section also addresses KQ 2b, “At what frequency does application of these novel risk markers significantly change the 10-year risk of cardiovascular events based on traditional risk factors alone?”

### Ankle-brachial index

The ankle-brachial index (ABI) is an indicator of peripheral arterial disease (PAD) – atherosclerotic disease involving large arteries of the lower extremity. The ABI is determined by measuring the systolic blood pressure at the ankle, based on palpation or ultrasound measurement of the dorsalis pedis pulse, and dividing this by the systolic blood pressure measured in the arm. An ABI < 0.9 is the cutoff point commonly used to indicate possible significant compromise of lower extremity arterial blood flow. In the Framingham cohort, the principal risk factors for CAD events, i.e., hyperlipidemia, hypertension, and smoking, were found to be equally good as predictors of incident PAD.36

We found no evidence that ABI independently predicts the risk of CHD events (fatal and nonfatal MI) in individuals who have no history of CHD and do not have symptomatic PAD. We reviewed 514 abstracts and evaluated 18 potentially relevant papers in detail. All papers were excluded with the most common reason being inclusion of subjects in the study who had CAD, based on electrocardiogram (ECG) findings, self-reported angina, coronary angiography or a history of stroke. Other reasons for exclusion were: 1) CAD events were not reported as an endpoint, 2) subjects included persons with symptomatic PAD, 3) statistical analyses did not include adjustment for Framingham risk factors, 4) the study was a cross-sectional analysis of prevalent, rather than incident disease, based on baseline study data, and 5) ABI was used as a covariate in an analysis of another candidate CVD risk factor to adjust for the presence of subclinical disease.

### White blood cell count

Elevated WBC count is an indicator of cellular response to inflammation. An advantage of the white blood cell count as a potential screening tool for CHD is the availability of a standardized, reproducible assay. A disadvantage is that an elevated WBC count may not be a specific indicator for CHD. Sources other than an atherosclerotic coronary artery, such as atherosclerosis in other arteries, as well as systemic inflammation and local infections (e.g., gingivitis, prostatitis, bronchitis, urinary tract infections, or gastric inflammation) may result in elevated WBC levels.16 A high WBC count has been strongly associated with smoking, an established risk factor for CHD, as well as other CHD risk factors including hypertension and low HDL cholesterol.37, 38

A meta-analysis published in 1998 compared the results of 19 prospective cohort studies of WBC count and CHD.24 Fourteen studies were population-based, and 5 studies were conducted in patients with preexisting CHD. Most studies adjusted for smoking, blood pressure, and obesity, and several also adjusted for fibrinogen. To limit the potential of publication bias and inadequate adjustment for potential confounders among small studies, the meta-analysis combined data from 7 large studies that each involved more than 400 cases and adjusted at a minimum for age, gender, and smoking. The combined RR comparing the top third of WBC count (mean 8.4 × 1000/mm^3^) with the bottom third (5.6 × 1000/mm3) was 1.4 (95% CI 1.3–1.5), and there was no significant heterogeneity between studies. The result was similar to the overall risk ratio in all 19 studies (1.5, 95% CI 1.4–1.6). These analyses cannot be compared directly with the findings of the current review, however, because they included subjects with preexisting vascular disease, as well as studies that we rated poor in quality.39, 40

In our review, the literature search for WBC count yielded 245 citations, from which we identified 10 cohort studies reported in 11 publications39–49 and one nested case-control study50 that examined the WBC count as a predictor of CHD events (Evidence Table 1). Two studies that adjusted for all Framingham risk factors was rated good-quality,42, 49, while 5 were rated fair, 45–48, 50 and 3 were rated poor-quality 39, 40, 44 Five studies were limited by incomplete adjustment for diabetes and other FRFs.44–47, 50 Other limitations include small sample size and limited duration of followup.46

The evidence that WBC count independently predicts CHD events was inconclusive. Among the fair and good-quality studies, WBC emerged as an independent predictor of CHD adjusting for smoking and other risk factors in some reports43, 45, 47, 48, 50 but not in others.41, 42, 46, 48, 49

The relationship between WBC count and CHD events also varied with the timing of the assessment of endpoints. For example, an older, fair-quality cohort study reported conflicting results in analyses conducted at different time points. After a median follow-up of 13.9 years, one analysis of the NHANES cohort reported significantly elevated CHD risk associated with WBC among white men (RR 1.31, 95%CI 1.07–1.61) and women (HR 1.31, 95%CI 1.05–1.63), comparing a WBC count of >8.1 with <6.6 × 1000/mm3.^43^ The analysis adjusted for age, smoking, blood pressure, total cholesterol, and history of diabetes. Among blacks in the study, a statistically significant increase in CHD incidence was detected at age 45–64, adjusted for age, sex, and smoking: RR 2.05, 95% CI 1.01–4.17. A significant association among blacks did not occur at age 65–74, however, a subsequent analysis of the cohort after 18 years of follow-up found no association: HR 1.01 (95% CI 0.85–1.20) comparing the highest to the lowest tertile of WBC count and adjusting for age, race, gender, smoking, blood pressure, total cholesterol, and diabetes.49 Analyses of another good-quality cohort study at separate time points found no association between total WBC count and CHD risk, adjusted for race and all Framingham risk factors after 5 and 10 years of follow-up, respectively.41, 42

### Fasting glucose

In 1997, the American Diabetes Association (ADA) published criteria that rely primarily on fasting glucose (FG) values for the diagnosis and classification of diabetes mellitus. The 1997 ADA criteria defined a new class of glucose disturbance called impaired fasting glucose (IFG) that refers to a metabolic stage intermediate between normal glucose homeostasis and diabetes.51 This stage included individuals with FG levels ≥110 mg/dL but < 126 mg/dL. A FG concentration of 109 mg/dL was chosen as the upper limit of normal because above this level, acute phase insulin secretion is lost in response to intravenous administration of glucose and is associated with a progressively greater risk of developing micro- and macrovascular complications.51 The ADA subsequently redefined the range for IFG as 100–125 mg/dL.52

A fair-quality systematic review53 included six studies of FG, published between 1979–1996.^54–59^ From the combined data, the study determined that a FG of 110 mg/dL was associated with a relative risk of cardiovascular events of 1.33 (95% CI 1.06–1.67) compared with the reference FG of 75 mg/dL. However, only two57, 59 of the studies in the meta-regression analyzed the incidence of fatal and non-fatal CHD events. The remaining studies analyzed mortality only and did not meet the inclusion criteria for the current report.

For our review, the literature search for FG yielded 147 citations, from which we identified 8 cohort studies (representing 10 cohorts), including 2 that occurred in the previous review (Evidence Table 2).57–64 The mean duration of follow-up ranged from 3 to 17 years. The mean age at baseline ranged from 47 to 68 years. Five studies excluded subjects with diabetes based on medical history58, 60, 63 or based on a FG level greater than 126 mg/dL.57, 61 Two studies included subjects with a history of diabetes but analyzed them separately.59, 62 Subjects with baseline CVD or CHD were excluded in all studies but one59 that adjusted for baseline CHD as a confounder. Hard CHD events were the outcome of interest in all studies but two that additionally included soft CHD (angina, intermittent claudication) and other CVD outcomes (stroke, transient ischemic attack).60, 63

The cohort studies ranged in size from 445 to 13,446 subjects. The categorization of FG values varied among studies. Two studies defined impaired FG using the 1997 ADA criteria of 110–125 mg/dL.60, 64 One study analyzed FG dichotomously at a threshold of 103 mg/dL.57 Another study analyzed two thresholds of FG separately: 103 mg/dL and 110 mg/dL.61 Other studies assessed FG in continuous increments63, 64 or in groups of increasing FG. 58, 62 Overall, FG did not appear to be a strong independent predictor of incident CHD after adjustment for traditional Framingham risk factors. The 2 best-quality cohort studies 62, 63 had mixed results. One found a weak association between FG and CHD after 4 years of follow-up, reporting a hazard ratio of 1.088 per 13 mg/dL increase in FG (95%CI 1.02–1.16) adjusted for Framingham risk score.63 The other study found no association with increasing FG after 4–7 years of follow-up.62

Two studies were rated good-quality62, 63, 6 were rated fair-quality,53, 58–61, 64 and 1 was rated poor-quality.57 Limitations of studies include small numbers of cases relative to the number of adjusting variables or fasting glucose categories60 and incomplete adjustment for Framingham risk factors.57, 59

Among fair-quality studies, no significant increased risk of CHD comparing FG 110–125 with < 110 mg/dL was found after 6 years of follow-up,60 and no trend with increasing FG appeared after 3–7 years followup59, 62 or after 9.5 years.58 A poor-quality study that adjusted only for age and gender similarly found no association comparing FG 103–125 with ≤103 mg/dL after 17 years of follow-up.57 A fair-quality study among people with hypertension reported an adverse synergistic interaction between glucose and total cholesterol (TC) that magnified CHD risk associated with TC. Among subjects with FG >103 mg/dL in this study, the adjusted hazard ratio was 2.46 (95% CI 1.26–4.77) comparing TC 200–259 with <200 mg/dL. Among subjects with FG <103 mg/dL, the adjusted HR was 0.89 (0.61–1.29).61

### Periodontal disease

Some estimates indicate that approximately 75% of adults in the US have periodontal disease and of those, approximately 20–30% have severe forms.65–67 Periodontal disease is associated with measures of chronic inflammation such as elevated fibrinogen and CRP levels 68–70. The common measures of periodontal disease in our review include bone loss, pockets, inflammation/gingivitis, and tooth loss or self report of tooth loss or periodontal disease.

We reviewed 126 abstracts and identified 9 studies conducted in 7 cohorts71–78 The studies were conducted in North America and Finland, and included from 175 to 170,000 men and women (Evidence Table 3). Follow-up ranged between 5 and 21 years. Periodontal disease was defined (and diagnosed) differently among the studies. Some studies employed dental examinations and radiographs and others relied on self report. Cardiovascular and CHD outcomes also were defined differently among the studies. Although our focus in this review is on CHD outcomes, we analyzed studies that used a broader range of endpoints. Three studies were rated good- quality73, 74, 76 and 5 were fair-quality.71, 72, 75, 77, 78 Periodontal disease based on either self report or dental examinations was evaluated in 6 studies.71–74, 77, 78 Five studies showed increased risk of CHD in association with baseline periodontal disease71–73, 75, 77 and 2 showed no association74, 78 although one study found an increased risk that was not statistically significant (RR 1.5) among women.78 When these studies were combined in meta-analysis, the summary estimate of risk ratio was 1.24 (95% CI 1.01–1.51) for any CHD or CVD event as shown in Figure 3. In subgroup analyses, the association with CHD was increased with female gender, longer follow-up times, and in studies based on dental exam rather than self-report (Figure 4).

Figure 3

Study Characteristics and Risk Ratios of CHD Associated with Different Categories of Periodontal Disease

This figure shows, in table form, the study characteristics and risk ratios (RRs) of coronary heart disease (CHD) associated with different categories of periodontal disease. The first category of studies used periodontitis as a risk factor. In the Morrison 1999 study, the outcome was CHD death, there were 2,297 subjects (both male and female), the risk factor measurement was a dental exam, the study quality was fair, the length of follow-up was 21 years, and the RR was 1.37, with a 95% confidence interval (CI) of 0.80 to 2.35. In the Tuominen 2003 study, the outcome was CHD death, there were 2,518 male subjects and 2,392 female subjects, the risk factor measurement was dental exam, the study quality was fair, the follow-up was 12 years, and the RR (95% CI) was 1.00 (0.61–1.63) for men and 1.18 (0.60–2.31) for women. In the Beck 1996 study, the outcome was CHD event, there were 1,221 male subjects, the risk factor measurement was dental exam, the study quality was fair, the follow-up was 18 years, and the RR (95% CI) was 3.10 (1.30–7.40). In the DeStefano 1993 study, the outcome was CHD event, there were 5,041 subjects (both male and female), the risk factor measurement was dental exam, the study quality was good, the follow-up was 14 years, and the RR (95% CI) was 1.25 (1.06–1.48). In the Ajwani 2003 study, the outcome was cardiovascular disease (CVD) death, there were 175 subjects (both male and female), the risk factor measurement was dental exam, the study quality was fair, the follow-up was 5 years, and the RR (95% CI) was 2.28 (1.03–5.05). In the Howell 2001 study, the outcome was CVD event, there were 22,037 male subjects, the risk factor measurement was self report, the study quality was fair, the follow-up was 12 years, and the RR (95% CI) was 1.01 (0.88–1.15). The RR (95% CI) for all of these studies combined was 1.24 (1.01–1.51). The next category of studies used having only 10 or less teeth as a risk factor. In the Morrison 1999 study, the outcome was CHD death, there were 3,330 subjects (both male and female), the risk factor measurement was dental exam, the study quality was fair, the follow-up was 21 years, and the RR (95% CI) was 1.90 (1.17–3.10). In the DeStefano 1993 study, the outcome was CHD event, there were 5,398 subjects (both male and female), the risk factor measurement was dental exam, the study quality was good, the follow-up was 14 years, and the RR (95% CI) was 1.23 (1.05–1.44). In the Hung 2004 study, the outcome was CHD event, there were 41,407 male subjects and 58,974 female subjects, the risk factor measurement was self report, the study quality was good, the follow-up was 12 years for men and 20 years for women, and the RR (95% CI) was 1.36 (1.11–1.67) for men and 1.64 (1.31–2.05) for women. In the Ajwani 2003 study, the outcome was CVD death, there were 175 subjects (both male and female), the risk factor measurement was dental exam, the study quality was fair, the follow-up was 5 years, and the RR (95% CI) was 1.46 (0.69–3.09). The RR (95% CI) for all of these studies combined was 1.41 (1.22–1.63). The last category of studies used gingivitis as a risk factor. In the Morrison 1999 study, the outcome was CHD death, there were 3,921 subjects (both male and female), the risk factor measurement was dental exam, the study quality was fair, the follow-up was 21 years, and the RR (95% CI) was 1.82 (1.21–2.68). In the DeStefano 1993 study, the outcome was CHD event, there were 5,537 subjects (both male and female), the risk factor measurement was dental exam, the study quality was good, the follow-up was 14 years, and the RR (95% CI) was 1.05 (0.88–1.26). The RR (95% CI) for these two studies combined was 1.35 (0.79–2.30). An image to the right of the table plots each RR on a graph.

Figure 4

Risk Ratios of CHD Associated with Periodontal Disease, by Selected Characteristics

This figure shows, in table form, the risk ratios (RRs) of coronary heart disease (CHD) associated with periodontal disease according to selected study characteristics. The first characteristic is study outcome. For those studies in which the outcome was CHD or cardiovascular disease (CVD) death, the RR was 1.28, with a 95% confidence interval (CI) of 0.94 to 1.73. For those studies in which the outcome was CHD or CVD event, the RR (95% CI) was 1.34 (1.08–1.66). The second characteristic is subject gender. For those studies in which the subjects were male, the RR (95% CI) was 1.23 (0.92–1.64). For those studies in which the subjects were female, the RR (95% CI) was 1.59 (1.28–1.96). For those studies in which the subjects were both male and female, the RR (95% CI) was 1.31 (1.08–1.59). The third characteristic is length of study follow-up. For those studies in which the subjects were followed for 15 years or less, the RR (95% CI) was 1.19 (1.02–1.40). For those studies in which the subjects were followed for more than 15 years, the RR (95% CI) was 1.67 (1.27–2.20). The fourth characteristic is method of risk factor measurement. For those studies in which the risk factor (periodontal disease) was measured by dental exam, the RR (95% CI) was 1.39 (1.19–1.62). For those studies in which the risk factor was self reported, the RR (95% CI) was 1.30 (0.96–1.76). The fifth and last characteristic is study quality. For those studies rated as good quality, the RR (95% CI) was 1.35 (1.06–1.72). For those studies rated as fair quality, the RR (95% CI) was 1.30 (0.97–1.74). An image to the right of the table plots each RR on a graph.

Gingivitis as a measure of periodontal disease was evaluated in 2 studies 73, 77 and both showed or suggested elevated rates of CHD death among individuals with baseline gingivitis. When combined in meta-analysis the summary estimate was 1.35 (95% CI 0.79–2.30). Bone loss was an important risk factor for subsequent CHD with 2 studies showing statistically significant relative risks from 1.36–1.90.^72, 76^

Four studies71, 73, 76, 77 including the Health Professional Follow-up, Nutrition Canada and the NHANES-1 studies, found that tooth loss made an independent contribution to the prediction of CHD events; one fair quality study suggested increased risk but was not statistically significant.71 When these 4 studies were combined in meta-analysis, the summary estimate for all CHD/CVD events was 1.41 (95% CI 1.22–1.63) indicating a 41% increased risk of CHD or CVD events among individuals with 0–10 teeth at baseline.(Figure 3)

### Carotid intima media thickness

Several simple non-invasive measures of non-cardiac atherosclerosis have been investigated as risk factors or predictors of CVD. Carotid IMT, as measured by carotid ultrasound, has been shown to be associated with traditional CVD risk factors41, 79 and is a marker of systemic atherosclerosis as assessed from pathology. Carotid IMT is also a predictor of stroke 80–82 and has strong correlations with CHD risk factors.

To assess the value of carotid IMT as a predictor of coronary events, we identified 6 population-based longitudinal studies in asymptomatic persons followed for the development of CHD (Evidence Table 4).79, 83–87 Two of the studies were from the same cohort.84, 87 We used the more recent of the two.87 The reports from 2 of the 5 cohorts had no adjustment for other risk factors and were rated poor-quality.79, 83 The remaining cohorts included men and women aged 42 or older, ranged between approximately 1,300 to 16,000 individuals, and were conducted in the US41, 86 and in the Netherlands.84, 87

Carotid IMT persisted as an independent risk factor in the 3 cohorts after full or partial adjustment for Framingham risk factors. The relative risks or hazard ratios ranged from 1.19– 3.80 for various degrees of carotid IMT (mm) or a composite score of carotid IMT or plaque. In subsequent analysis of data from the Atherosclerosis Risk in Communities (ARIC) cohort, adding carotid IMT scores to a risk prediction equation based on Framingham risk factors slightly improved the prediction of subsequent CHD among healthy adults, particularly men.41

### Electron beam computed tomography

EBCT can be used to quantify calcification of the coronary arteries into a CAC score. Coronary calcification is known to correlate with atherosclerotic burden.88–90 Coronary calcification increases with age and, on average, is more extensive in men than women.

A meta-analysis published in 2003 analyzed 4 longitudinal studies26 of asymptomatic adults. The follow-up periods ranged from 32 to 43 months; during follow-up 39 cardiac deaths and 71 nonfatal infarctions were observed in 3,970 subjects. Three of these studies were conducted in patients who were self-referred or referred by a physician to an EBCT facility.29, 91, 92 These 3 studies had other flaws: none of them adjusted for the Framingham risk factors, and, in two, outcome assessment was not blinded. The fourth, a population-based prospective cohort study from the South Bay Heart Watch,28 adjusted statistically for most of the Framingham risk factors and used blinded adjudication of outcomes. All 4 studies found that a high CAC score was associated with a higher risk of CAD events (RRs of 1, 2.1, 4.2, and 7.2 for CAC score categories of 0, 1–100, 101–400, and >400, respectively.) However, the estimates were much lower for the South Bay Heart Watch (RRs 1.0; 1.7, 95%CI 1.1–2.6; 2.3, 95%CI 1.1–4.7; 2.8, 95%CI 1.2–6.8 for CAC score categories of 0, 1–100, 101–400, and >400, respectively) than for the 3 other studies. None of the studies attempted to assess the added predictive value of CAC scores among intermediate-risk individuals.

Our literature search for EBCT yielded 167 citations, from which we identified 9 prospective cohort studies that met inclusion criteria,29, 91–98 of which all but one93 met further criteria for meta-analysis (Figure 5). We conducted a meta-analysis that included several studies published since 2003, and focused on a subset of studies that used valid methods and were applicable to intermediate-risk individuals in the general population. Specifically, good-quality studies: (a) were population-based, (b) measured risk factors rather than using proxies ascertained by questionnaires, (c) assessed outcomes in a blinded fashion, (e) adjusted for all traditional risk factors (blood pressure, age, sex, smoking, diabetes, and cholesterol). Publications from 3 cohort studies met these criteria.95, 96, 98 We also compared the relative risk ratios for good-quality studies to those for 4 fair-quality29, 92, 94, 97 and 1 poor-quality study.91

Figure 5

Study Characteristics and Risk Ratio of CHD Associated with Coronary Artery Calcium(CAC) Score Categories

This figure shows, in table form, the study characteristics and risk ratios (RRs) of coronary heart disease (CHD) associated with different categories of coronary artery calcium (CAC) scores. The first category is a CAC score of 1 to 100. In the Greenland 2004 study, the study quality was good, the outcome was major CHD event, there were 1,020 subjects, 90% of which were male, the length of follow-up was 6.3 years, the annual rate of major CHD events for the entire cohort was 0.82%, the risk factor (CAC score) was obtained by measurement, and the RR was 1.50, with a 95% confidence interval (CI) of 0.74 to 3.05. In the Taylor 2005 study, the study quality was good, the outcome was CHD event, there were 1,627 male subjects, the follow-up was 3 years, the annual event rate was 0.18%, the risk factor was obtained by measurement, and the RR (95% CI) was 8.91 (2.21–35.90). In the Vliegenthart 2005 study, the study quality was good, the outcome was major CHD event, there were 1,795 subjects, 42.5% of which were male, the follow-up was 3.3 years, the annual event rate was 0.70%, the risk factor was obtained by measurement, and the RR (95% CI) was 4.47 (1.71–11.71). In the Kondos 2003 study, the study quality was fair, the outcome was major CHD event in the 4,151 male subjects and CHD event in the 1,484 female subjects, the follow-up was 3.1 years, the annual event rate was 0.40% in men and 0.10% in women, the risk factor was obtained from patient history, and the RR (95% CI) was 2.20 (1.18–4.10) in men and 1.99 (1.02–3.86) in women. In the LaMonte 2005 study, the study quality was fair, the outcome was major CHD event, there were 6,835 male subjects and 3,911 female subjects, the follow-up was 3.5 years, the annual event rate was 0.26% in men and 0.14% in women, the risk factor was obtained from patient history, and the RR (95% CI) was 4.23 (1.96–9.14) in men and 2.59 (1.10–6.09) in women. In the Raggi 2001 study, the study quality was fair, the outcome was major CHD event, there were 676 subjects, 51% of which were male, the follow-up was 2.7 years, the annual event rate was 1.60%, the risk factor was obtained by patient history, and the RR (95% CI) was 2.50 (1.60–3.91). In the Wong 2000 study, the study quality was fair, the outcome was cardiovascular disease (CVD) event, there were 926 subjects, 79% of which were male, the follow-up was 3.3 years, the annual event rate was 0.30%, the risk factor was obtained by patient history, and the RR (95% CI) was 1.92 (0.38–9.73). In the Arad 2000 study, the study quality was poor, the outcome was CHD event, there were 1,172 subjects, 71% of which were male, the follow-up was 3.6 years, the annual event rate was 0.20%, the risk factor was obtained by patient history, and the RR (95% CI) was 4.50 (2.61–7.77). The RR (95% CI) for all of the fair- to good-quality studies combined (i.e., all except for Arad 2000) was 2.56 (1.96–3.35). The RR (95% CI) for all of these studies combined was 2.82 (2.14–3.72). The second category is a CAC score of 101 to 400. The characteristics for each study remain the same as reported in the first category. In the Greenland 2004 study the RR (95% CI) was 2.21 (1.32–3.96). In the Vliegenthart 2005 study the RR (95% CI) was 9.97 (2.27–43.79). In the Kondos 2003 study the RR (95% CI) was 6.07 (1.47–25.13) in men and 5.39 (1.06–27.23) in women. In the LaMonte 2005 study the RR (95% CI) was 4.23 (1.96–9.14) in men and 2.59 (1.10–6.09) in women. In the Raggi 2001 study the RR (95%) was 8.91 (3.05–26.04). In the Wong 2000 study the RR (95%) was 5.70 (1.63–19.90). In the Arad 2000 study the RR (95%) was 14.1 (5.39–36.75). The RR (95% CI) for all of the fair- to good-quality studies combined (i.e., all except for Arad 2000) was 5.35 (3.13–9.16). The RR (95% CI) for all of these studies combined was 6.30 (3.60–11.03). The third and last category is a CAC score of greater than 400. The characteristics for each study remain the same as reported in the first category. In the Greenland 2004 study the RR (95% CI) was 3.70 (1.63–8.37). In the Vliegenthart 2005 study the RR (95% CI) was 18.0 (2.80–115.1). In the Kondos 2003 study the RR (95% CI) was 11.7 (1.69–81.50) in men and 9.85 (1.08–85.48) in women. In the LaMonte 2005 study the RR (95% CI) was 4.23 (1.96–9.14) in men and 2.59 (1.10–6.09) in women. In the Raggi 2001 study the RR (95%) was 15.6 (4.06–60.16). In the Wong 2000 study the RR (95%) was 0.57 (1.03–40.10). In the Arad 2000 study the RR (95%) was 26.0 (7.97–84.98). The RR (95% CI) for all of the fair- to good-quality studies combined (i.e., all except for Arad 2000) was 8.01 (4.81–13.33). The RR (95% CI) for all of these studies combined was 10.6 (6.11–18.48). An image to the right of the table plots each RR on a graph.

Characteristics of these studies are summarized in Evidence Table 5. For the 7 fair or good-quality studies29, 92, 94–96 combined in a meta-analysis, pooled relative risks (95% CIs) were 2.56 (1.96, 3.35); 5.35 (3.13, 9.16); and 8.01 (4.81, 13.33) for CAC scores of 1–100, 101–400, and >400, respectively (Figure 5). Estimates of the effect of CAC scores varied widely. Estimates from the good-quality studies were substantially lower than those for fair-quality and poor-quality studies (Figure 6), but were still substantial.

Figure 6

Subgroup Analysis of Risk Ratio of CHD Associated with Coronary Artery Calcium CAC) Score Categories

This figure shows, in table form, the risk ratios (RRs) of coronary heart disease (CHD) associated with coronary artery calcium (CAC) score, according to selected study characteristics. The first category of CAC score is 1 to 100. In this category, the first characteristic is study outcome. For those studies in which the outcome was major CHD event, the RR was 2.55, with a 95% confidence interval (CI) of 1.92 to 3.38. For those studies in which the outcome was CHD or cardiovascular disease (CVD) event, the RR (95% CI) was 2.96 (1.17–7.47).The second characteristic is annual rate of major CHD events for the entire cohort. For those studies in which the annual event rate was less than 0.5%, the RR (95% CI) was 2.72 (1.90–3.90). For those studies in which the annual event rate was greater than 0.5%, the RR (95% CI) was 2.40 (1.46–3.96). The third characteristic is subject gender. For those studies in which the subjects were male, the RR (95% CI) was 3.63 (1.80–7.32). For those studies in which the subjects were female, the RR (95% CI) was 2.22 (1.30–3.72). For those studies in which the subjects were both male and female, the RR (95% CI) was 2.36 (1.60–3.47). The fourth and final characteristic is study quality. For those studies rated as good quality, the RR (95% CI) was 3.46 (1.23–9.71). For those studies rated as fair quality, the RR (95% CI) was 2.50 (1.90–3.29). For those studies rated as poor quality, the RR (95% CI) was 4.50 (2.61–7.77). The second category of CAC score is 101 to 400. The first characteristic is study outcome. For those studies in which the outcome was major CHD event, the RR (95% CI) was 5.59 (2.81–11.2). For those studies in which the outcome was CHD or CVD event, the RR (95% CI) was 5.58 (2.07–15.0).The second characteristic is annual event rate. For those studies in which the annual event rate was less than 0.5%, the RR (95% CI) was 6.44 (3.48–11.9). For those studies in which the annual event rate was greater than 0.5%, the RR (95% CI) was 5.10 (1.67–15.6). The third characteristic is subject gender. For those studies in which the subjects were male, the RR (95% CI) was 8.43 (3.25–21.8). For those studies in which the subjects were female, the RR (95% CI) was 5.04 (1.74–14.6). For those studies in which the subjects were both male and female, the RR (95% CI) was 5.05 (2.14–11.9). The fourth and final characteristic is study quality. For those studies rated as good quality, the RR (95% CI) was 3.97 (0.94–16.8). For those studies rated as fair quality, the RR (95% CI) was 6.98 (4.09–11.9). For those studies rated as poor quality, the RR (95% CI) was 14.1 (5.39–36.8). The third and final category of CAC score is greater than 400. The first characteristic is study outcome. For those studies in which the outcome was major CHD event, the RR (95% CI) was 9.35 (4.61–18.9). For those studies in which the outcome was CHD or CVD event, the RR (95% CI) was 8.92 (2.53–31.5).The second characteristic is annual event rate. For those studies in which the annual event rate was less than 0.5%, the RR (95% CI) was 11.5 (5.13–26.0). For those studies in which the annual event rate was greater than 0.5%, the RR (95% CI) was 8.41 (2.73–26.0). The third characteristic is subject gender. For those studies in which the subjects were male, the RR (95% CI) was 17.8 (4.93–64.4). For those studies in which the subjects were female, the RR (95% CI) was 8.72 (2.10–36.2). For those studies in which the subjects were both male and female, the RR (95% CI) was 7.87 (3.46–17.9). The fourth and final characteristic is study quality. For those studies rated as good quality, the RR (95% CI) was 6.48 (1.48–28.5). For those studies rated as fair quality, the RR (95% CI) was 12.5 (6.24–25.1). For those studies rated as poor quality, the RR (95% CI) was 26.0 (7.97–85.0). An image to the right of the table plots each RR on a graph.

The 3 good-quality, population-based cohort studies also showed increasing adjusted relative risks for hard coronary events as CAC scores increased. One of these, conducted in 1,029 subjects (mean age, 65.7 years) in the South Bay Heart Watch cohort, had an average follow-up of 75 months.95 The investigators calculated Framingham risk scores and then stratified by CAC scores. In the 10–15% and 16–20% Framingham groups, respectively, 17/257 subjects and 26/383 subjects had a coronary death or MI within 75 months. The raw frequency of events for these combined groups is shown below in Table 4. Compared to subjects who had a CAC score of zero, patients who had higher CAC scores had significantly higher risk of having a CHD event. The investigators calculated hazard ratios separately for the 10–15% and 15–20% groups. All hazard ratios were statistically significant for subjects whose baseline 10-year risk was 15–20%. In this group, the HRs (95% CI) for CAC scores of 1–100, 101–300, and >300 were 5.3 (1.1–25.0), 6.2 (1.2–31.8), and 8.9 (1.9–41.8), respectively. For subjects whose baseline 10-year risk was 10–15%, the hazard ratios (95%CIs) were 3.2 (0.6–17.7), 6.2 (1.0–37.0), and 17.6 (3.7–83.0). Study participants with a baseline Framingham score of 10–15% and CAC scores above 300 had a projected 10-year event rate in the range of a high-risk group, that is, a >20% 10-year risk.

Table 4

Frequency of Events in Framingham 10-20% Risk Group by CAC Score

CAC score | Number of events/Number of patients
0 | 7/195
1–100 | 12/223
101–300 | 8/104
>300 | 16/118

Abbreviation: CAC=coronary artery calcification.

The second good-quality study followed 1795 asymptomatic participants (mean age, 71 years; range, 62 to 85 years) in the Rotterdam Coronary Calcification Study, a sub-study of the Rotterdam study for a mean of 3.3 years.96 Patients with previous coronary disease were excluded, but 2.8% of subjects had a history of stroke. Unlike most other studies, the authors categorized CAC results into the following 4 categories: 0 to 100, 101 to 400, 401 to 1000, and 1000. Compared to the lowest group, the multivariate-adjusted relative risk for CHD events was 2.7 (95% CI, 1.0 to 7.7) for calcium scores of 101 to 400, 4.1 (95% CI, 1.3 to 11.6) for calcium scores of 401 to 1000, and 8.1 (95% CI, 2.9 to 22.3) for calcium scores >1000. The investigators also computed the additional value of CAC after computing a Framingham risk score. Because they partitioned the subjects into 2 groups—10-year risk > 20% and 10-year risk<20%—the study does not provide an estimate of the additional value of CAC in intermediate-risk individuals. CAC improved prediction in both groups. Compared with the reference category (subjects with a calcium score of 0 to 100 and a 10-year Framingham risk score< 20%), relative risks of CHD were 3.2 for a calcium score of 101 to 1000 and 8.7 for a calcium score>1000.

A third good-quality study, from the Prospective Army Coronary Calcium (PACC) Project, provided information about a younger, lower-risk cohort followed for 3 years.98 In this sample of 2000 individuals (mean age 43 years), the prevalence of coronary calcium was 22.4% of men and 7.9% of women. Only 9 CHD events were observed; all in men. Coronary calcium was associated with an 11.8-fold increased risk for incident CHD (p=0.002) in a Cox model controlling for the Framingham risk score. This result pertains primarily to low-risk rather than intermediate-risk individuals and was not included in our meta-analysis. Nevertheless, it indicates that CAC measurement may be of particular value in younger individuals who are low-risk by traditional measures.

The Saint Francis Heart Study, a population-based study of 4903 asymptomatic persons age 50 to 70 years (mean age 59), also examined the value of CAC scores when used in addition to the Framingham risk score.93 The report concerns 4613 participants who completed a follow-up evaluation 4.3 years after inception. Among intermediate-risk individuals, the 2^nd^ and 3^rd^ terciles of CAC scores were associated with approximately 2 times and 5 times higher risk of CHD events, respectively. This finding was presented in a graph without actual numbers or statistical testing. Moreover, as reported in the article, the event rate includes revascularization as an endpoint.^a^

a The author agreed to provide the data required to include the study in the meta-analysis.

Several limitations of the evidence regarding EBCT can be noted. First, as shown in Table 3, EBCT has been evaluated in fewer of the major epidemiologic cohorts than some other novel risk factors. The reason is that, while stored tissue samples from subjects can be used to test retrospectively for serum tests such as CRP, there is no way to obtain a calcium score retrospectively. For this reason, data on EBCT are relatively sparse; follow-up periods relatively short, compared with those for studies of CRP, homocysteine, and other blood tests; and Framingham risk factors are not measured as completely as they were in the larger, older cohort studies. Moreover, because the test cannot be evaluated in longer-term studies such as Framingham and the Nurses Health Study, most of the studies had too few “hard” CHD events to conduct a complete analysis of risk factors.

The American College of Cardiology Foundation (ACCF) and AHA recently released a report on EBCT and its use in primary prevention of CHD. This report states that CAC scoring may be an appropriate means of risk stratifying those of intermediate-risk as determined by the Framingham risk score. Their study, like ours, identify several key prospective cohort studies that best address the use of CAC scoring by EBCT in an asymptomatic, intermediate-risk population – a group most likely to benefit from more aggressive primary prevention and the population central to our study’s question. Greenland, et. al, and Vliegenthart et. al. had high quality scores in the ACCF/AHA report and in ours and form the primary basis for recommendations. (Taylor et. al. also had a high quality rating but observes a low-risk, rather than intermediate-risk cohort.) We concluded, however, that several features of this key literature limit recommending the implementation of CAC scoring by EBCT into clinical practice at this time.

First, self-selection bias likely existed in the Rotterdam Study since only 61% of eligible individuals invited to participate actually formed the study group. The South Bay Heart Watch cohort may also have been self-selected since only 5023 individuals responded to 100,000 letters of invitation.

Second, the cohorts of the Rotterdam Study and the South Bay Heart Watch may not be representative of an intermediate-risk group as determined by the Framingham score. In the Rotterdam Study, the ability of CAC scoring to add predictive value was evaluated in those with a 10-year Framingham risk of >20% or ≤20%. The subset with a Framingham risk ≤20% could include a substantial number of individuals of low-risk, i.e., a 10-year Framingham risk score of ≤10%. Therefore, it is difficult to generalize this study’s results to an intermediate-risk population - a group most likely to benefit from improved risk stratification and aggressive primary prevention.

In the South Bay Heart Watch, the annual event rate for the group with a projected 10-year risk of 16–20% was only 1%. That is, the Framingham risk score significantly underestimated risk in this group, possibly due to small sample size. The sparse number of events particularly limited conclusions regarding those deemed high risk by the CAC score (≥300) and intermediate risk by the Framingham score. Eight of 41 patients with a CAC score ≥300 and a Framingham risk score of 11–15% experienced MI or coronary death – a 20% event rate. However, 8 of 77 participants with a CAC score ≥300 and Framingham risk score of 16–20% had MI or coronary death – an 11% event rate. The small number of events and the inability of the Framingham risk score to differentiate risk in those with a Framingham risk score of 11–15% as compared to 16–20% regardless of CAC score raise concerns about the validity of these findings.

In summary, in two good-quality, applicable, population-based prospective studies, higher CAC scores were associated with a higher risk of CHD events over 2 to 4 years of follow-up. The RRs were large but not statistically significant for CAC scores in the range 101–400 (3.97, 95% CI 0.94 to 16.8) but were statistically significant for the groups with CAC scores of 1–100 (3.46, 95% CI 1.23 to 9.71) and > 400 (6.48, 95% CI 1.48 to 28.5.) Results from a good-quality study in middle-aged men support the conclusion that CAC adds independent information to the Framingham risk score. Older cohort studies appear to overestimate the independent effect of CAC scores. The studies on EBCT were limited by participant self-selection and sparse data on individuals at intermediate risk by the Framingham risk score.

### Homocysteine

The role of plasma homocysteine in vascular disease has been studied extensively in the last 4–5 decades.99 Interest in homocysteine as a causal factor was spurred by the observation that over 50% of children with the genetic disorder homocystinuria die of premature vascular disease,100, 101 and strategies which reduce homocysteine levels in these children reduce vascular event rates.101, 102 In addition, in humans, non-human primates, and mammals, elevations of homocysteine are associated with several physiologic abnormalities which might explain increased vascular risk.103, 104

In humans, severe elevations of homocysteine may occur because of rare inborn errors of metabolism. Moderate elevations may occur because of less severe genetic mutations associated with enzyme abnormalities in the metabolic pathway involving folate and homocysteine. Elevations of homocysteine also result from inadequate dietary intake of folate and vitamins B6 and B12. In the US, mild elevations occur in 5–30% of the population and epidemiologic studies have shown that over 50 % of US adults are not consuming enough folate to keep their homocysteine levels low.105–107

Prior meta-analyses have shown that mild to moderate elevations of homocysteine are associated with a slight increase in CHD risk.108–110 However, these meta-analyses have been limited by the inclusion of cross-sectional studies, studies conducted among patients with known CHD, and case control studies conducted among survivors of CHD events. Furthermore, because elevated homocysteine levels are also associated with known CHD risk factors, such as hypertension,108 male sex,111 renal dysfunction,112 and smoking,108 prior meta-analyses are limited by the inclusion of studies with insufficient adjustment for factors that might confound the relationship between CHD and elevated homocysteine levels. Thus, these meta-analyses have provided less than definitive answers to the question of whether elevations of homocysteine might explain a portion of CHD in individuals of average CHD risk based on traditional risk factors. For many of these reasons, as well as a lack of primary prevention studies showing reduced risk of CHD with treatment of elevated homocysteine, screening for elevated homocysteine levels in the general adult population has not been recommended by major health care organizations such as the USPSTF.

For this review, 31 publications of homocysteine were considered for inclusion.14, 113–141, 258 Of these, 24 cohorts were included (Evidence Tables 6 & 7). Some of these were not used in our meta-analysis (Figure 7) because either the outcome studies could not be clearly attributed to CHD, or data were included in another publication (see Evidence Tables 6 & 7 for details). When these studies were combined in a random effects meta-analysis the estimated relative risk for total CHD associated with each 5 μmol/L increase in homocysteine was 1.18 (95% CI 1.10–1.26) for all studies combined and 1.21 (95% CI 1.10–1.32) for studies in which individuals with prevalent CHD were explicitly excluded from the cohort (Figure 7). This relationship was similar for men and women. The increase in risk was consistent in all subgroup analyses including evaluations by age, length of follow-up, study quality, gender and type of study. None of the studies attempted to evaluate the impact of homocysteine as an independent risk factor in intermediate-risk subjects.

Figure 7

Study Characteristics and Risk Ratio of CHD Associated with Every 5 μmol Increase of Homocysteine

This figure shows, in table form, the study characteristics and risk ratios (RRs) of coronary heart disease (CHD) associated with each 5 μmol/L increase in homocysteine level. The first category of studies excluded subjects with a history of CHD or cardiovascular disease (CVD) at baseline. In the Stampter 1992 study, the study outcome was CHD event, there were 542 male subjects, a nested case control (NCC) study design was used, the study quality was good, the length of follow-up was 7 years, and the RR was 2.08, with a 95% confidence interval (CI) of 1.17 to 3.68. In the Alfthan 1994 study, the outcome was CHD event, there were 460 subjects (both male and female), an NCC study design was used, the study quality was fair, the follow-up was 9 years, and the RR (95% CI) was 1.00 (0.64–1.56) in women and 1.00 (0.72–1.39) in men. In the Amesen 1995 study, the outcome was CHD event, there were 600 subjects (both male and female), an NCC study design was used, the study quality was fair, the follow-up was 4 years, and the RR (95% CI) was 1.41 (1.07–1.88). In the Evans 1997 study, the outcome was CHD event, there were 732 male subjects, an NCC study design was used, the study quality was good, the follow-up was 14 years, and the RR (95% CI) was 0.94 (0.65–1.34). In the Folsom 1998 study, the outcome was CHD event, there were 769 subjects (both male and female), an NCC study design was used, the study quality was good, the follow-up was 3 years, and the RR (95% CI) was 1.22 (0.52–2.88). In the Wald 1998 study, the outcome was CHD event, there were 1,335 male subjects, an NCC study design was used, the study quality was fair, the follow-up was 8.7 years, and the RR (95% CI) was 1.41 (1.20–1.65). In the Knekt 2001 study, the outcome was CHD event, there were 1,020 subjects (both male and female), an NCC study design was used, the study quality was good for female subjects and fair for male subjects, the follow-up was 13 years, and the RR (95% CI) was 0.64 (0.22–1.83) for women and 0.78 (0.44–1.39) for men. In the de Bree 2003 study, the outcome was CHD event, there were 939 subjects (both male and female), an NCC study design was used, the study quality was good, the follow-up was 10.3 years, and the RR (95% CI) was 1.03 (0.83–1.28). In the Lind 2003 study, the outcome was CHD event, there were 482 male subjects, an NCC study design was used, the study quality was fair, the follow-up was 17 years, and the RR (95% CI) was 1.10 (0.86–1.41). In the Shai 2004 study, the outcome was CHD event, there were 695 female subjects, an NCC study design was used, the study quality was good, the follow-up was 8 years, and the RR (95% CI) was 1.35 (0.83–2.18). In the Voutilainen 2004 study, the outcome was CHD event, there were 1,229 male subjects, a cohort study design was used, the study quality was fair, the follow-up was 7.8 years, and the RR (95% CI) was 0.89 (0.34–2.38). In the Zylberstein 2004 study, the outcome was CHD event, there were 1,368 female subjects, a cohort study design was used, the study quality was fair, the follow-up was 24 years, and the RR (95% CI) was 1.22 (1.05–1.41). In the Bostom 1999 study, the outcome was CVD event, there were 1,933 subjects (both male and female), a cohort study design was used, the study quality was good, the follow-up was 11.5 years, and the RR (95% CI) was 1.40 (1.13–1.73). In the Ridker 2000 study, the outcome was CVD event, there were 366 female subjects, an NCC study design was used, the study quality was good, the follow-up was 3 years, and the RR (95% CI) was 1.46 (0.82–2.62). In the Vollset 2001 study, the outcome was CVD event, there were 4,766 subjects (both male and female; ages 65 to 67 years old), a cohort study design was used, the study quality was fair, the follow-up was 4.1 years, and the RR (95% CI) was 1.58 (1.07–2.34). In the Nurk 2002 study, the outcome was CVD event, there were 12,288 subjects (both male and female; ages 40 to 42 years old), a cohort study design was used, the study quality was fair, the follow-up was 5.3 years, and the RR (95% CI) was 1.02 (0.75–1.38). The RR (95% CI) of these studies combined was 1.21 (1.10–1.32). The second category of studies did not explicitly exclude subjects with a history of CHD or CVD at baseline. In the Stehower 1998 study, the outcome was CHD event, there were 878 male subjects, a cohort study design was used, the study quality was fair, the follow-up was 9 years, and the RR (95% CI) was 1.07 (0.98–1.17). In the Bots 1999 study, the outcome was CHD event, there were 757 subjects (both male and female), an NCC study design was used, the study quality was good, the follow-up was 2.7 years, and the RR (95% CI) was 1.28 (0.99–1.65). In the Fallon 2001 study, the outcome was CHD event, there were 1,560 male subjects, an NCC study design was used, the study quality was good, the follow-up was 10 years, and the RR (95% CI) was 1.09 (0.91–1.32). In the Sacco 2004 study, the outcome was CHD event, there were 2,939 subjects (both male and female), a cohort study design was used, the study quality was good, the follow-up was 4 years, and the RR (95% CI) was 1.15 (0.72–1.84). The RR (95% CI) of these studies combined was 1.09 (1.01–1.18). The RR (95% CI) of all the studies combined was 1.18 (1.10–1.26). An image to the right of the table plots each RR on a graph.

The good-quality studies adjusted for all or nearly all of the risk factors that make up the Framingham risk score. Study quality did not explain differences observed among the studies. A sensitivity analysis determined that the meta-analytic results were similar when poor studies were included in the model (OR 1.19, 95% CI 1.12 to 1.27).

In women, all studies showed either a statistically significant14, 124, 141 association between higher homocysteine levels and CHD events or an elevated risk estimate that did not reach statistical significance.114, 115, 118 When combined in meta-analysis, the estimated relative risk among studies including women for each 5 μmol/L increase in homocysteine was 1.21 (1.06–1.37) (Figure 8).

Figure 8

Risk Ratio of CHD Associated With Every 5 μmol/L Increase of Homocysteine, by Selected Characteristics

This figure shows, in table form, the risk ratios (RRs) of coronary heart disease (CHD) associated with each 5 μmol/L increase in homocysteine level, according to selected study characteristics. The first characteristic is study outcome. For those studies in which the outcome was myocardial infarction (a subgroup of major CHD event), the RR was 1.19, with a 95% confidence interval (CI) of 1.07 to 1.31. For those studies in which the outcome was CHD event, the RR (95% CI) was 1.16 (1.07–1.25). For those studies in which the outcome was cardiovascular event, the RR (95% CI) was 1.32 (1.09–1.60). The second characteristic is subject gender. For those studies in which the subjects were male, the RR (95% CI) was 1.13 (1.00–1.27). For those studies in which the subjects were female, the RR (95% CI) was 1.21 (1.06–1.37). For those studies in which the subjects were both male and female, the RR (95% CI) was 1.24 (1.11–1.39). The third characteristic is length of study follow-up. For those studies in which the subjects were followed for less than 5 years, the RR (95% CI) was 1.39 (1.20–1.62). For those studies in which the subjects were followed for 5 to 10 years, the RR (95% CI) was 1.13 (1.02–1.26). For those studies in which the subjects were followed for more than 10 years, the RR (95% CI) was 1.13 (1.00–1.28). The fourth characteristic is the number of adjustments made for Framingham risk factors. For those studies which adjusted for all seven of the Framingham risk factors, the RR (95% CI) was 1.25 (1.11–1.41). For those studies which adjusted for only four to six of the Framingham risk factors, the RR (95% CI) was 1.14 (1.03–1.26). The fifth characteristic is study quality. For those studies rated as good quality, the RR (95% CI) was 1.19 (1.06–1.34). For those studies rated as fair quality, the RR (95% CI) was 1.17 (1.06–1.29). For those studies rated as poor quality, the RR (95% CI) was 1.26 (1.11–1.43). The sixth and last characteristic is type of study design. For those studies using a nested case control design, the RR (95% CI) was 1.18 (1.06–1.30). For those studies using a cohort design, the RR (95% CI) was 1.18 (1.06–1.33). An image to the right of the table plots each RR on a graph.

One of the limitations of this review is that the outcomes measured varied by study. In an attempt to determine whether the relationship between homocysteine and subsequent CHD varied by outcome, we stratified the studies by the type of event and showed no difference in findings—that is, all outcomes, including MI, total CHD, and CVD were positively associated with baseline HC levels. The combined estimates for each of these outcomes are shown in Figure 8.

Prior evaluations of the homocysteine literature found a disparity in results between case control studies, which have tended to show higher relative risks, and cohort studies, which have shown either no elevation in risk or more moderate risk associated with elevated homocysteine when compared to case control studies. In the current review we evaluated whether study type was associated with a significantly different relative risk as observed in previous meta-analyses. As shown in Figure 8, there was no difference between the relative risk estimates for nested case control studies and the cohort studies included in this review.

Finally, to determine whether baseline homocysteine levels are associated with short or long term risk, we stratified the studies included in this review by length of follow-up. Among the studies with follow-up of less than 5 years the summary risk ratio was 1.39 (95% CI 1.20–1.62) and among studies of longer duration (>10 years) the risk ratio was 1.13 (95% CI 1.00–1.28).

Our review shows a relatively consistent association between elevated homocysteine levels and CHD that is independent of traditional risk factors. This association held in all subgroups and in widely varying cohorts. The relationship between higher levels of homocysteine and CHD we have identified may be due to unrecognized confounding by factors associated with homocysteine and CHD which explain the observed relationship. We have attempted to control for confounding by only including studies of fair or better quality in our meta-analyses but we recognize that it is plausible, even with excellent control of confounding by known CHD risk factors that the observed association between higher homocysteine levels and CHD may be due to unrecognized confounding. One approach to understanding this possibility is reviewing the number of confounders adjusted for in each study and attempting to quantify the potential confounders that were not adjusted for in the included studies multivariable analyses. In our review, we found little evidence of differences in relative risk estimates between studies with many adjustments for confounders compared with fewer adjustments. One of the greatest limitations of observational studies, even of the very best quality, is that they cannot completely adjust for confounders. The possibility of unrecognized confounding is supported by the fact that elevations of homocysteine are associated with other important risk factors for CHD such as hypertension,142, 143 smoking,143 microalbuminuria,144 physical activity,143 and male sex.143 While most studies adjusted for traditional risk factors, most did not adjust for renal dysfunction which has been shown to be a confounder in several studies.145, 146 However, the Framingham analysis134, as well as the Rotterdam117 and Gothenburg studies141 found no change in relative risk estimates when measures of renal function were added to the multivariable models.

There are several limitations of this review. First, we relied on only published data which may be biased towards publishing positive findings. We evaluated this with a funnel plot which did not suggest publication bias. Second, since we only used published data, the outcomes evaluated were not standardized between studies. For example, some studies evaluated only MI as an outcome and others evaluated several CHD outcomes. The similarity between the relative risk estimates identified for each outcome suggests that the outcomes were sufficiently similar to combine in meta-analysis. In addition, we relied on each study’s definition of the outcome. Third, studies reported their findings variably making it difficult to identify either a dose response or thresh-hold effect, but relatively easy to identify that in most cohorts, individuals with higher homocysteine levels had worse CHD outcomes when compared to those with lower levels.

Another limitation is that ascertainment of outcomes differed in each study. Some studies relied on population registries and others self-report. We tried to account for this potential source of error in our quality ratings and reduce this problem by only including fair or better quality studies in this review. We believe our quality review would be more likely to miss random error in outcome assessment than systematic error which would result in underestimating the association between homocysteine and CHD. Furthermore, because all included studies were prospective and homocysteine levels measured long before the outcomes occurred, it is very unlikely that bias in assigning the outcome is important in our findings.

There are several strengths of this review. First, we used only data from population-based prospective cohort studies. All individuals had homocysteine levels measured at baseline and were followed forward in time for the development of CHD. While this does not allow us to determine whether homocysteine is a causal risk factor or a marker of risk, it does reduce the problem of determining cause and effect that is associated with cross sectional studies. The population based nature of the cohorts substantially improves generalizability of the findings which is of great importance when considering public health and prevention guidelines that are applied broadly in a population. Another strength of this review is that we quality rated all of the studies and eliminated those of poor quality (five studies) where the findings could only be viewed as of questionable validity. Even when these findings were included in the review and meta-analysis, the association between homocysteine levels and CHD was similar.

### Lipoprotein(a)

The Lp(a) lipoprotein was discovered by Berg in 1963.^147^ Lp(a) is a cholesterol-rich plasma lipoprotein particle, the structure and composition of which closely resemble LDL. The distinguishing feature of Lp(a) is the presence of an additional large glycoprotein known as apolipoprotein-a (apo[a]), which is linked by a disulfide bridge to apolipoprotein B-100, the sole protein of LDL. Apo(a) has a high sequence homology (75–90%) with plasminogen148 and may competitively interfere with plasminogen action in fibrinolysis, promoting development of lipid-rich plaques that are more prone to rupture than more fibrous lesions.149–152 This suggests that Lp(a) may contribute to the thrombotic and atherogenic aspects of CHD. A plasma Lp(a) threshold of 30 mg/dL has been linked to increased CVD risk in men.153, 154

Lp(a) synthesis is under strong genetic control, and the serum Lp(a) concentrations of children aged 7–24 months correlate strongly with their parents’ and siblings’ serum Lp(a) concentrations.155 Differences in Lp(a) by nationality and ethnic group have been observed. Median Lp(a) values in Black Americans were approximately 3-fold higher than in White Americans (21.5 vs. 6.1 in Black vs. White men; 23.9 vs. 6.4 in women), and while the distribution of Lp(a) in Whites was highly skewed (median 3.7, mean 6.9), the skewness was much less pronounced in Blacks (median 11.6, mean 13.0).156 Native American Indians have low concentrations of Lp(a), and only a small percentage (1.7%–7.4%) have Lp(a) >30 mg/dL.157

There is little correlation between Lp(a) and traditional CHD risk factors. Increased age was associated with elevated Lp(a) level in some studies.158–160 Smoking appears to be unrelated to Lp(a) level.158, 159, 161, 162 The relationship between Lp(a) and LDL cholesterol is inconsistent, even among studies that corrected for the estimated contribution of Lp(a) cholesterol to LDL cholesterol.158–162 Diabetes, blood pressure, and HDL cholesterol do not appear to be consistently associated with Lp(a) levels.

Twelve cohort studies reported in 18 publications,41, 163–179 nine nested case-control studies reported in nine publications,149, 162, 180–186 and two meta-analyses187, 188 met the inclusion criteria for this review. Thirteen studies included only men,162, 165, 167, 170, 172, 176, 178, 181–184, 186, 189 six included both men and women,171, 173–175, 177, 185, and two studies included women only.164, 179 Subjects’ race was 97–100% White in all but one study.41

The studies analyzed Lp(a) using various quantitative comparisons, and the results shown compare the highest to the lowest quantile of Lp(a) in each study (Evidence Table 8). Overall, 10 of the studies reported a statistically significant association between Lp(a) and CHD risk: three of five good-quality studies, and seven of 13 fair studies. Six studies dichotomized Lp(a) at various thresholds, of which five studies reported a significant association with CHD risk. Using a threshold of 20 mg/dL, two studies reported elevated RRs of 2.7 (95% CI 1.4–5.2)178 and 6.76 (95%CI 2.1–21.7).180 At a threshold of 30 mg/dL, three other studies reported elevated RRs of 2.0 (p=0.0001) in men,170 1.9 in men (95%CI 1.2–2.9),165 and 1.61 in women (95%CI 1.13–2.29).164

Three of four studies that compared various levels of Lp(a) with a reference of ≤3 mg/dL reported elevated and statistically significant RRs. These RRs (95% CI) were 7.2 (1.3–39.8) for Lp(a) >13.4 mg/dL,184 1.81 (1.02–3.19) for Lp(a) between 15.6 and 34.8 mg/dL,183 1.9 (1.1–3.3) for Lp(a) >26.3 mg/dL, 176 2.08 (95%CI 1.2–3.6) at ≥34.9 mg/dL183, and 1.47 (95% CI 1.21–1.79) at >44 mg/dL.179 Four studies that analyzed various continuous increments of Lp(a) reported mixed results. Of two studies that assessed risk per 1-SD increase in Lp(a), one found a positive association (RRs of 1.15 in men, 1.17 in women, p<0.01)177, and another found no association (RR 0.93, 95% CI 0.73–1.18).175 A third study found an association of small magnitude: RR 1.0003 per 0.1 mg/dL increase in Lp(a) (p=0.01),162 and a fourth study found no association per 1-unit increase of Lp(a) on a logarithmic scale.174 Four other studies categorized Lp(a) in groups that could not be directly compared with other studies, and reported null associations with CHD risk,167, 172, 173, 186 although one such study detected a statistically significant trend of increasing risk with increasing quintile of Lp(a).172

Variation in sample handling and storage methods, and a lack of standardization of commercial assays, present limitations to the direct comparison of Lp(a) studies. A previous meta-analysis found that storage temperature was strongly associated with variability in Lp(a) analysis in a meta-analysis.187 Much of the inaccuracy of commercial Lp(a) determinations results from the use of techniques sensitive to apo(a) size.190 A study by Kronenberg concluded that small apo(a) isoforms were more susceptible to degradation than large apo(a) isoforms.191 The Enzyme-linked immunosorbent assay (ELISA) has been reported to underestimate the concentration of Lp(a) containing small apo(a) isoforms.192 Studies that compared the ELISA and immunoradiometric assay (IRMA) methods reported conflicting levels of agreement between the two assays.181, 193

In the current review, six studies assayed Lp(a) in fresh sera.164, 165, 171–173, 178 Other studies assayed Lp(a) in samples that were frozen at temperatures ranging from −20C to −130C, for periods ranging from <1 year to 20 years.162, 167, 170, 174–176, 179–186, 189 Studies quantified Lp(a) using electrophoresis, immunoradiometric assays, or turbimetric assays, and defined categories of Lp(a) in a range of quantitative and qualitative increments. Positive findings were reported in four164, 165, 173, 178 of six studies that used fresh sera, and in 7^162, 170, 176, 177, 179, 180, 183^ of 14 studies that measured Lp(a) in frozen samples. No pattern in effect size emerged among studies that stored frozen sera for increasing lengths of time. Two studies used an immunoturbimetric assay that measured Lp(a) independently of apolipoprotein(a) isoform size in samples that had been frozen in liquid nitrogen (−130 to −180C) for an unspecified duration, and found mixed results.186, 194 One study was conducted in women enrolled in a trial comparing aspirin, vitamin E, and placebo, and was rated good-quality,194 while the other was a fair-quality nested case-control study that included only men.186 Among women, Lp(a) >44 mg/dL was significantly associated with increased CHD risk compared with Lp(a) <3.50 mg/dL (OR 1.47, 95% CI 1.21–1.79), and there was a statistically significant trend with increasing Lp(a) quintile (p<0.001).194 The analysis adjusted for CRP, current hormone use, and body mass index, and randomized treatment group, in addition to Framingham risk factors, but found a significant interactive effect with LDL-C. In the study among men, no association or trend emerged.186 The analysis did not adjust for all Framingham risk factors, specifically TC, LDL, and HDL.

We conducted a meta-analysis of 16 good- and fair-quality studies that excluded subjects with a history of CHD at baseline, and could be combined based on standardized Lp(a) levels and found that Lp(a) ≥30 mg/dL was associated with an increased risk ratio of 1.57 (95% CI 1.31–1.88) compared with Lp(a) < 30 mg/dL (Figure 9). Two fair-quality studies178, 180 were excluded from this analysis because the studies used a cut-off of 20 mg/dL, and did not report sufficient data to standardize the risk ratio at 30 mg/dL. A sensitivity analysis that included these additional studies had a similar combined result: 1.65 (95% CI 1.38–1.98). There was significant heterogeneity, however, across studies (p<0.001). The pooled estimate was similar among men and women, and tended to be higher in studies with longer follow-up times (Figure 10). The heterogeneity was not explained by the other study level variables, such as study design or degree of adjustment for confounders (Figure 10). None of the studies assessed whether Lp(a) adds to CHD risk specifically in intermediate-risk subjects.

Figure 9

Study Characteristics and Risk Ratio of CHD Associated with Lipoprotein(a) (>=30 vs <30 mg/dL)

This figure shows, in table form, the study characteristics and risk ratios (RRs) of coronary heart disease (CHD) associated with elevated lipoprotein(a) levels (≥30 mg/dL). Only studies that explicitly excluded subjects with a history of CHD or cardiovascular disease (CVD) at baseline are included. The first group of studies all used major CHD event as the study outcome. In the Bostom 1994 study, there were 3,103 female subjects, a cohort study design was used, the risk factor was detected by electrophoresis band, the study quality was good, the length of follow-up was 12 years, and the RR was 2.37, with a 95% confidence interval (CI) of 1.48 to 3.80. In the Bostom 1996 study, there were 2,191 male subjects, a cohort study design was used, the risk factor was detected by electrophoresis band, the study quality was good, the follow-up was 15.4 years, and the RR (95% CI) was 1.90 (1.10–3.29). In the Cremer 1997 study, there were 5,639 male subjects, a cohort study design was used, the risk factor was detected by quantitative assessment, the study quality was fair, the follow-up was 10 years, and the RR (95% CI) was 2.82 (2.16–3.68). In the Jauihiainen 1991 study, there were 268 male subjects, a nested case control (NCC) design was used, the risk factor was detected by quantitative assessment, the study quality was fair, the follow-up was 5 years, and the RR (95% CI) was 1.32 (0.82–2.13). In the Luc 2002 study, there were 9,133 male subjects, a cohort design was used, the risk factor was detected by quantitative assessment, the study quality was good, the follow-up was 5 years, and the RR (95% CI) was 1.62 (0.78–3.38). In the Pischon 2005 study, there were 739 male subjects, an NCC design was used, the risk factor was detected by quantitative assessment, the study quality was fair, the follow-up was 6 years, and the RR (95% CI) was 1.34 (0.90–1.99). In the Price 2001 study, there were 783 female subjects and 809 male subjects, a cohort design was used, the risk factor was detected by quantitative assessment, the study quality was fair, the follow-up was 5 years, and the RR (95% CI) was 0.97 (0.62–1.52) in women and 1.19 (0.85–1.67) in men. In the Ridker 1993 study, there were 592 male subjects, an NCC design was used, the risk factor was detected by quantitative assessment, the study quality was fair, the follow-up was 5 years, and the RR (95% CI) was 0.65 (0.22–1.94). In the Schaefer 1994 study, there were 623 male subjects, an NCC design was used, the risk factor was detected by quantitative assessment, the study quality was fair, the follow-up was 8.5 years, and the RR (95% CI) was 1.92 (1.06–3.47). In the Rosengren 1990 study, there were 135 male subjects, an NCC design was used, the risk factor was detected by quantitative assessment, the study quality was fair, the follow-up was 6 years, and the RR (95% CI) was 4.17 (1.41–12.3). The next group of studies all used CHD event as the study outcome. In the Cantin 1998 study, there were 2,156 male subjects, a cohort design was used, the risk factor was detected by quantitative assessment, the study quality was fair, the follow-up was 5 years, and the RR (95% CI) was 1.15 (0.73–1.82). In the Nguyen 1997 study, there were 4,967 male subjects and 4,969 female subjects, a cohort design was used, the risk factor was detected by electrophoresis band, the study quality was fair, the follow-up was 13.9 years in men and 14.1 years in women, and the RR (95% CI) was 1.60 (0.99–2.58) in men and 1.90 (1.27–2.84) in women. In the Salomaa 2002 study, there were 2,240 subjects (both male and female), a cohort design was used, the risk factor was detected by quantitative assessment, the study quality was fair, the follow-up was 6.6 years, and the RR (95% CI) was 0.93 (0.74–1.16). In the Seed 2001 study, there were 2,616 male subjects, a cohort design was used, the risk factor was detected by quantitative assessment, the study quality was fair, the follow-up was 6 years, and the RR (95% CI) was 2.27 (1.09–4.71). In the Sharrett 2001 study, there were 5,432 male subjects and 6,907 female subjects, a cohort design was used, the risk factor was detected by quantitative assessment, the study quality was good, the follow-up was 10 years, and the RR (95% CI) was 1.87 (0.95–3.69) in men and 2.03 (1.00–4.11) in women. In the Suk Danik 2006 study, CVD event was the study outcome, there were 27,791 female subjects, a cohort design was used, the risk factor was detected by quantitative assessment, the study quality was good, the follow-up was 10 years, and the RR (95% CI) was 1.48 (1.29–1.71). The RR (95% CI) for all of the studies combined was 1.57 (1.31–1.88). An image to the right of the table plots each RR on a graph.

Figure 10

Risk Ratio of CHD Associated with Lipoprotein(a) (>=30 vs <30 mg/dL), by Selected Characteristics

This figure shows, in table form, the risk ratios (RRs) of coronary heart disease (CHD) associated with elevated lipoprotein(a) levels (≥30 mg/dL), according to selected study characteristics. The first characteristic is study outcome. For those studies in which the outcome was major CHD event, the RR was 1.63, with a 95% confidence interval (CI) of 1.24 to 2.16. For those studies in which the outcome was CHD event, the RR (95% CI) was 1.51 (1.11–2.05). The second characteristic is method of risk factor detection. For those studies in which the risk factor (lipoprotein[a] level) was detected by electrophoresis band, the RR (95% CI) was 1.93 (1.52–2.43). For those studies in which the risk factor was detected by quantitative assessment, the RR (95% CI) was 1.49 (1.20–1.84). The third characteristic is the number of adjustments made for Framingham risk factors. For those studies which adjusted for all seven of the Framingham risk factors, the RR (95% CI) was 1.80 (1.30–2.48). For those studies which adjusted for only four to six of the Framingham risk factors, the RR (95% CI) was 1.46 (1.18–1.80). The fourth characteristic is subject gender. For those studies in which the subjects were male, the RR (95% CI) was 1.65 (1.31–2.08). For those studies in which the subjects were female, the RR (95% CI) was 1.61 (1.24–2.10). The fifth characteristic is length of follow-up. For those studies in which the subjects were followed for less than 5 years, the RR (95% CI) was 1.18 (0.97–1.45). For those studies in which the subjects were followed for 5 to 10 years, the RR (95% CI) was 1.68 (1.25–2.26). For those studies in which the subjects were followed for more than 10 years, the RR (95% CI) was 1.93 (1.52–2.43). The sixth characteristic is study quality. For those studies rated as good quality, the RR (95% CI) was 1.58 (1.40–1.79). For those studies rated as fair quality, the RR (95% CI) was 1.48 (1.14–1.93). The seventh and last characteristic is type of study design. For those studies using a nested case control design, the RR (95% CI) was 1.50 (1.04–2.17). For those studies using a cohort design, the RR (95% CI) was 1.59 (1.29–1.96). An image to the right of the table plots each RR on a graph.

Two previous meta-analyses of prospective studies of Lp(a) found a positive association between Lp(a) and CHD risk,187, 188 but they differed from the current report by including studies of apolipoprotein(a), and studies that assessed mortality rather than total incidence. One reported a combined risk ratio of 1.7 (95% CI 1.4 to 1.9) comparing the top third of baseline Lp(a) to the bottom third, did not detect significant heterogeneity among studies, and found similar results when grouping studies by sample storage and assay method.188 The other meta-analysis reported a combined ratio of 1.40 (95% CI 1.22–1.57) comparing Lp(a) levels in cases vs. controls, found significant heterogeneity (p<0.001) among studies, and that lower freezer temperatures correlated with a higher point estimate for the Lp(a) case:control ratio.187

### C-reactive protein

CRP, a pentameric protein synthesized in the liver, was identified in 1930 in serum from patients with lobar pneumococcal pneumonia.195 It is a sensitive, nonspecific systemic marker of inflammation and tissue damage that has long been used to monitor inflammation in fever and other conditions. 196 In addition to chronic inflammation, elevated levels of CRP are associated with traditional cardiovascular risk factors and with obesity.197, 198 Whether CRP is involved in the pathogenesis of CVD is unknown.199, 200

The first report of CRP as a predictor of CHD events was published in 1996, from a nested case-control analysis from the Multiple Risk Factor Intervention Trial (MRFIT).201 In that study, smokers with no known cardiac disease who were in quartile 4 of CRP had 4.3 times (95% CI 1.74–10.8) as high a risk of MI or CHD death than those in the lowest quartile after 13 to 17 years of follow-up.

A 1998 meta-analysis of 5 long-term, population-based prospective cohort studies and 2 cohorts of patients with known coronary disease at baseline calculated an odds ratio for coronary events of 1.7 (95% CI 1.4 to 2.1) for hsCRP levels in the top tercile (>2.4 mg/L) vs. the bottom tercile (<1.4 mg/L).24 The only criterion for assessing the quality of each cohort study was a prospective design; another criterion, the number of covariates adjusted for in the analysis, was recorded but not used to select or weight the studies. Two of the 5 population-based cohort studies adjusted only for age, sex, and smoking status.201, 202 In another, from the Physicians Health Study, individuals in the top two CRP^b^ quartiles had 2.5 times as high a risk of MI as individuals in the lowest quartile after adjustment for body-mass index, diabetes, history of hypertension, and parental history of CAD. The investigators did not simultaneously adjust for these factors and serum lipid levels.203

b The assay had a sensitivity of 0.08 μg per milliliter.

An update of this meta-analysis was published in 2000.^204^ In this meta-analysis, the pooled OR for 11 population-based prospective cohort studies was 2.0 (95% CI 1.6 to 2.5). All studies found a positive relationship; in seven studies, the odds ratio was less than 2.0, and in five studies it was 2.0 or higher. Of the six studies added to the analysis since 1998, the best and largest was a nested case-control analysis of middle-aged men (506 cases and 1025 controls) randomly selected from general practice registers in each of 24 British towns.204 Men in the highest tercile of CRP (>2.4 mg/l) were 2.13 (95% CI 1.38 to 3.28) times as likely to have an MI or death from coronary disease as controls after adjustment for age, smoking status, blood pressure, total cholesterol, HDL-C, triglycerides, body mass index, town, and socioeconomic status. An important finding of this study was that adjustment for socioeconomic status reduced the OR from 2.92 (95% CI 2.13 to 4.01) to 2.13 (95% CI 1.38 to 3.28). A second analysis excluding men who had coronary disease at baseline had similar results (OR 2.31, 95% CI 1.42 to 3.76). Another updated meta-analysis was published in 2004.^205^ It included 11 new general-population cohort studies and updated information from one of the 11 cohorts included in the previous update. Older and smaller studies tended to report larger odds ratios. The investigators calculated an overall pooled OR for 22 studies of 1.58 (95% CI 1.48 to 1.68) and one derived from the four largest, more recent studies (1.49, 95% CI 1.37 to 1.62.) Both estimates are much lower than the same authors calculated in the 2000 meta-analysis.

These meta-analysis results support the view that, overall, an elevated hsCRP is associated with a higher risk of CHD events. However, the results are not necessarily useful for making a recommendation about the additional contribution hsCRP would make if used to further refine risk stratification in intermediate-risk individuals. Moreover, the investigators did not systematically assess characteristics of the design or execution of the studies, and in the 2004 update, did not rate the quality of adjustment for potential confounders.

Our approach was guided by these considerations. First, we identified 27 papers from 18 cohorts in North America and Europe that recruited asymptomatic individuals or a combination of asymptomatic individuals and patients with known CHD (Evidence Table 9). Fourteen papers reported cohort studies,206–219 and 13 reported either nested case-control14, 203–205, 220–226 or case-cohort 227, 228 analyses (Evidence Table 10). All but two studies 210, 212 excluded patients with known CHD. When multiple studies were published from a single cohort, we restricted our analyses to the highest quality papers that most closely addressed the questions of the review. Of this group of principal studies, all but one adjusted for at least five of the seven Framingham risk factors,203–205, 207, 209, 210, 212, 216, 218–222, 225–227 and 8 adjusted for all seven factors.207, 216, 218, 220–222, 225, 227 Of the 17 principal studies, nine were rated good-quality 204, 207, 216, 218–222, 227 and eight were rated fair-quality,203, 205, 209, 210, 212, 213, 225, 226 seven were in males only,203, 204, 207, 210, 212, 218, 220 three were in females only,209, 216, 222 and six were in males and females combined.205, 213, 219, 225–227 One study examined two separate cohorts - one of males only and one of females only - and presented analyses of the cohorts separately and combined.221

Higher baseline CRP was associated with incident CHD events in 15 of the 17 studies, with the adjusted RRs ranging from 0.96 to 2.6. In eight studies the association was statistically significant,203–205, 207, 216, 220, 222, 227 and in eight other studies the association was not statistically significant.209, 210, 212, 213, 218, 219, 225, 226 In the study of two separate cohorts,221 CRP was associated with CHD in both cohorts, but was only statistically significant in the cohort of men. Five studies203, 210, 216, 220, 221 showed a statistically significant dose-response relationship between baseline CRP level and incident CHD.

The studies used a variety of cut-points and categories, including CRP as a continuous variable. In our meta-analysis, we standardized CRP levels to the three CDC/AHA-recommended categories (<1.0 mg/dL; 1.0 to 3.0 mg/dL; and >3.0 mg/L), and estimated the relative risk for incident CHD for each of the higher two categories compared with the lowest category. Analysis of all 15 studies (in 16 cohorts) that explicitly excluded CHD at baseline showed a RR of 1.64 (95% CI, 1.41–1.91) for CRP > 3.0 mg/L vs. CRP < 1.0 mg/L (Figure 11), and an RR of 1.27 (95% CI, 1.16–1.40) for CRP between 1.0 mg/L and 3.0 mg/L vs. CRP<1.0 mg/L (Figure 12 ). The relationship between CRP level > 3.0 mg/dL and CHD events persisted in several subgroup analyses (Figure 13).

Figure 11

Study Characteristics and Risk Ratio of CHD Associated with C-Reactive Protein (>3.0 mg/L vs mg/L)

This figure shows, in table form, the study characteristics and risk ratios (RRs) of coronary heart disease (CHD) associated with elevated C-reactive protein levels (>3.0 mg/L). The first category of studies excluded subjects with a history of CHD or cardiovascular disease (CVD) at baseline. In the Danesh 2004 study, the study outcome was major CHD event, there were 5,933 subjects (both male and female), a nested case control (NCC) study design was used, the study quality was fair, the length of follow-up was 19.5 years, and the RR was 1.40, with a 95% confidence interval (CI) of 1.19 to 1.65. In the Danesh 2000 study, the outcome was major CHD event, there were 1,149 male subjects, an NCC study design was used, the study quality was good, the follow-up was 9.5 years, and the RR (95% CI) was 2.70 (1.85–3.95). In the Koenig 2004 study, the outcome was major CHD event, there were 3,435 male subjects, a cohort study design was used, the study quality was good, the follow-up was 6.6 years, and the RR (95% CI) was 2.21 (1.49–3.27). In the Luc 2003 study, the outcome was major CHD event, there were 772 male subjects, an NCC study design was used, the study quality was good, the follow-up was 5 years, and the RR (95% CI) was 1.75 (0.88–3.48). In the Pai 2004 study, the outcome was major CHD event, there were 794 male subjects and 708 female subjects, an NCC study design was used, the study quality was good, the follow-up was 8 years, and the RR (95% CI) was 1.79 (1.14–2.82) in men and 1.53 (0.89–2.63) in women. In the Park 2002 study, the outcome was major CHD event, there were 967 subjects (both male and female), a cohort study design was used, the study quality was fair, the follow-up was 6.4 years, and the RR (95% CI) was 2.02 (0.89–4.57). In the Pradhan 2002 study, the outcome was major CHD event, there were 560 female subjects, an NCC study design was used, the study quality was good, the follow-up was 2.9 years, and the RR (95% CI) was 1.83 (0.88–3.81). In the Ridker 1997 study, the outcome was major CHD event, there were 492 male subjects, an NCC study design was used, the study quality was fair, the follow-up was 8 years, and the RR (95% CI) was 2.75 (1.49–5.07). In the St-Pierre 2005 study, the outcome was major CHD event, there were 1,982 male subjects, a cohort study design was used, the study quality was good, the follow-up was 13 years, and the RR (95% CI) was 0.98 (0.68–1.41). In the van der Meer 2003 study, the outcome was major CHD event, there were 657 subjects (both male and female), an NCC study design was used, the study quality was fair, the follow-up was 4–8 years, and the RR (95% CI) was 1.09 (0.50–2.39). In the Wilson 2005 study, the outcome was major CHD event, there were 4,446 subjects (both male and female), a cohort study design was used, the study quality was good, the follow-up was 8 years, and the RR (95% CI) was 1.22 (0.81–1.84). In the Witherell 2003 study, the outcome was major CHD event, there were 325 subjects (both male and female), an NCC study design was used, the study quality was fair, the follow-up was 5.1 years, and the RR (95% CI) was 2.00 (0.99–4.03). In the Ballantyne 2004 study, the outcome was CHD event, there were 1,348 subjects (both male and female), a case control study design was used, the study quality was good, the follow-up was 6 years, and the RR (95% CI) was 1.72 (1.24–2.39). In the Lawlor 2005 study, the outcome was CHD event, there were 2,723 female subjects, a cohort study design was used, the study quality was fair, the follow-up was 3.5 years, and the RR (95% CI) was 1.15 (0.74–1.81). In the Ridker 2004 study, the outcome was CVD event, there were 15,745 female subjects, a cohort study design was used, the study quality was good, the follow-up was 9 years, and the RR (95% CI) was 1.90 (1.42–2.54). The RR (95% CI) for all of these studies combined was 1.64 (1.41–1.91). The second category of studies did not explicitly exclude subjects with a history of CHD or CVD at baseline. In the Lowe 2001 study, the outcome was major CHD event, there were 1,595 male subjects, a cohort study design was used, the study quality was fair, the follow-up was 6.25 years, and the RR (95% CI) was 1.44 (0.92–2.25). In the Mendall 2000 study, the outcome was major CHD event, there were 1,395 male subjects, a cohort study design was used, the study quality was fair, the follow-up was 13.7 years, and the RR (95% CI) was 1.02 (0.48–2.15). The RR (95% CI) for these two studies combined was 1.32 (0.90–1.93). The RR (95% CI) for all of the studies combined was 1.61 (1.40–1.86). An image to the right of the table plots each RR on a graph.

Figure 12

Risk Ratio of CHD Associated with C-Reactive Protein (1.0 – 3.0 mg/L vs <1.0 mg/L)

This figure shows, in table form, the risk ratios (RRs) of coronary heart disease (CHD) associated with C-reactive protein levels of 1.0–3.0 mg/L. The first category of studies excluded subjects with a history of CHD or cardiovascular disease (CVD) at baseline. In the Ballantyne 2004 study, the RR was 1.31, with a 95% confidence interval (CI) of 0.96 to 1.79. In the Danesh 2000 study, the RR (95% CI) was 1.66 (1.37–2.02). In the Danesh 2004 study, the RR (95% CI) was 1.19 (1.09–1.30). In the Koenig 2004 study, the RR (95% CI) was 1.44 (0.95–2.18). In the Lawlor 2005 study, the RR (95% CI) was 1.04 (0.93–1.15). In the Luc 2003 study, the RR (95% CI) was 1.34 (0.94–1.92). In the Pai 2004 study, the RR (95% CI) was 1.17 (0.69–1.99) in women and 1.60 (1.09–2.34) in men. In the Park 2002 study, the RR (95% CI) was 1.43 (0.95–2.16). In the Pradhan 2002 study, the RR (95% CI) was 1.34 (0.94–1.91). In the Ridker 1997 study, the RR (95% CI) was 1.70 (1.24–2.34). In the Ridker 2004 study, the RR (95% CI) was 1.20 (0.90–1.60). In the St-Pierre 2005 study, the RR (95% CI) was 0.99 (0.83–1.19). In the van der Meer 2003 study, the RR (95% CI) was 1.04 (0.70–1.55). In the Wilson 2005 study, the RR (95% CI) was 1.35 (1.22–1.49). In the Witherell 2003 study, the RR (95% CI) was 1.41 (1.00–1.99). The RR (95% CI) for these studies combined was 1.27 (1.16–1.40). The second category of studies did not explicitly exclude subjects with a history of CHD or CVD at baseline. In the Lowe 2001 study, the RR (95% CI) was 1.20 (0.96–1.50). In the Mendall 2000 study, the RR (95% CI) was 1.01 (0.70–1.46). The RR (95% CI) for these two studies combined was 1.14 (0.94–1.39). The RR (95% CI) for all of the studies combined was 1.25 (1.15–1.37). An image to the right of the table plots each RR on a graph.

Figure 13

Risk Ratio of CHD Associated with C-Reactive Protein, by Selected Characteristics

This figure shows, in table form, the risk ratios (RRs) of coronary heart disease (CHD) associated with C-reactive protein, according to selected study characteristics. The first category of studies includes RRs associated with C-reactive protein levels of 1.0–3.0 mg/L. The first characteristic is study outcome. For those studies in which the outcome was major CHD event, the RR was 1.29, with a 95% confidence interval (CI) of 1.17 to 1.42. For those studies in which the outcome was CHD event, the RR (95% CI) was 1.11 (0.90–1.37). For those studies in which the outcome was cardiovascular disease (CVD) event, the RR (95% CI) was 1.20 (0.90–1.60). The second study characteristic is the number of adjustments made for Framingham risk factors. For those studies which adjusted for all seven of the Framingham risk factors, the RR (95% CI) was 1.20 (1.07–1.34). For those studies which adjusted for only four to six of the Framingham risk factors, the RR (95% CI) was 1.28 (1.13–1.45). The third study characteristic is subject gender. For those studies in which the subjects were male, the RR (95% CI) was 1.32 (1.11–1.57). For those studies in which the subjects were female, the RR (95% CI) was 1.08 (0.98–1.19). For those studies in which the subjects were both male and female, the RR (95% CI) was 1.22 (1.12–1.31). The fourth study characteristic is length of follow-up. For those studies in which the subjects were followed for 5 or less years, the RR (95% CI) was 1.15 (0.95–1.39). For those studies in which the subjects were followed for more than 5 but less than 10 years, the RR (95% CI) was 1.39 (1.27–1.52). For those studies in which the subjects were followed for more than 10 years, the RR (95% CI) was 1.10 (0.96–1.26). The fifth characteristic is study quality. For those studies rated as good quality, the RR (95% CI) was 1.32 (1.15–1.51). For those studies rated as fair quality, the RR (95% CI) was 1.18 (1.07–1.30). The sixth and last characteristic is type of study design. For those studies using a case cohort design, the RR (95% CI) was 1.31 (0.96–1.79).For those studies using a nested case control design, the RR (95% CI) was 1.37 (1.20–1.55). For those studies using a cohort design, the RR (95% CI) was 1.10 (1.01–1.20). The second category of studies includes RRs associated with elevated C-reactive protein levels (more than 3.0 mg/L). The first characteristic is study outcome. For those studies in which the outcome was major CHD event, the RR (95% CI) was 1.61 (1.36–1.90). For those studies in which the outcome was CHD event, the RR (95% CI) was 1.45 (0.99–2.14). For those studies in which the outcome was CVD event, the RR (95% CI) was 1.90 (1.42–2.54). The second study characteristic is the number of adjustments made for Framingham risk factors. For those studies which adjusted for all seven of the Framingham risk factors, the RR (95% CI) was 1.63 (1.35–1.96). For those studies which adjusted for only four to six of the Framingham risk factors, the RR (95% CI) was 1.59 (1.28–1.99). The third study characteristic is subject gender. For those studies in which the subjects were male, the RR (95% CI) was 1.72 (1.29–2.29). For those studies in which the subjects were female, the RR (95% CI) was 1.61 (1.27–2.05). For those studies in which the subjects were both male and female, the RR (95% CI) was 1.45 (1.27–1.65). The fourth study characteristic is length of follow-up. For those studies in which the subjects were followed for 5 or less years, the RR (95% CI) was 1.40 (1.00–1.96). For those studies in which the subjects were followed for more than 5 but less than 10 years, the RR (95% CI) was 1.82 (1.57–2.10). For those studies in which the subjects were followed for more than 10 years, the RR (95% CI) was 1.21 (0.93–1.58). The fifth characteristic is study quality. For those studies rated as good quality, the RR (95% CI) was 1.70 (1.40–2.07). For those studies rated as fair quality, the RR (95% CI) was 1.42 (1.25–1.63). The sixth and last characteristic is type of study design. For those studies using a case cohort design, the RR (95% CI) was 1.72 (1.24–2.39).For those studies using a nested case control design, the RR (95% CI) was 1.78 (1.43–2.20). For those studies using a cohort design, the RR (95% CI) was 1.44 (1.14–1.81). An image to the right of the table plots each RR on a graph.

We also performed a meta-analysis limited to the seven good-quality studies from eight cohorts that estimated the relative risk of incident CHD and adjusted for all Framingham risk score factors or calculated a Framingham risk score,207, 216, 218, 220–222, 227 and obtained similar results. For CRP > 3.0 mg/L vs. < 1.0 mg/L, the RR was 1.66 (95% CI, 1.37–2.02), and for CRP between 1.0 mg/L and 3.0 mg/L vs. CRP < 1.0 mg/L, the RR was 1.22 (95% CI, 1.08–1.38). We excluded from this meta-analysis two fair-quality studies that used all Framingham risk score factors. One of these 2 studies225 adjusted for all Framingham risk score factors, but excluded a large proportion of cases (23%) due to missing data. The other study219 excluded sex from the multivariate analysis after finding no difference in the effect of traditional risk factors between men and women. We conducted a sensitivity analysis to compare the combined RR with and without these 2 studies, and found the results to be comparable. For CRP > 3.0 mg/L vs. < 1.0 mg/L, the RR was 1.58 (95% CI, 1.32–1.88), and for CRP between 1.0 mg/L and 3.0 mg/L vs. CRP < 1.0 mg/L, the RR was 1.20 (95% CI, 1.08–1.33).

Five studies 207, 216, 218, 219, 225 included analyses that compared predictive models using all Framingham risk factors with and without CRP. Three of these studies 207, 216, 219 specifically evaluated subjects of intermediate risk when stratified using the 10-year Framingham risk score, and two 207, 219 of the three measured the c-statistic or the area under the receiver operating characteristic curve (AUC). Results were mixed. Two studies that stratified subjects by Framingham risk scores found that CRP improved discrimination specifically among intermediate-risk individuals. 207, 216 In the Monitoring of Trends and Determinants in Cardiovascular Disease (MONICA) cohort, 207 adding CRP to the Framingham risk score significantly improved discrimination among individuals with an initial 10-year risk of 11–19% (Figure 14). Among those with serum CRP > 3.0 mg/L, some individuals with an initial 10-year risk of 15–19% were reclassified as high-risk, and no subjects with an initial 10-year risk of 11–14% were reclassified as high-risk. In an analysis of data from the Women’s Health Study, 216 CRP was clearly predictive for incident CVD among subjects with 10-year Framingham risk between 10 and 20%. The risk for CVD events was twice as high for those with CRP between 1.0 and 3.0 mg/L or between 3.0 and 10.0 mg/L when compared with those with CRP less than 1.0 mg/L, although confidence intervals were not reported. The negative study, an analysis from the Framingham cohort, found no improvement in discrimination as measured by the c-statistic, but did not assess the effect of adding CRP on reclassification.219

Figure 14

Occurance of a First Coronary Event within 10 Years, Estimated by Cox Proportional Hazards Models in Percentages

This figure has two bar graphs. Each graph depicts the Framingham estimate of 10-year risk for a coronary event based on Cox proportional hazards models. For the bar graph on the left: the horizontal axis contains five categories of the Framingham Risk Score, adjusted for survey: <6%; 6%–10%; 11%–14%; 15%–19%; and ≥20%. The vertical axis is the estimated probability of a first coronary event within 10 years. The axis ranges from 0%–25% in increments of 5%. For the bar graph on the right: the horizontal axis contains five categories of the Framingham Risk Score, adjusted for survey: <6%; 6%–10%; 11%–14%; 15%–19%; and ≥20%. The vertical axis is the estimated probability of a first coronary event within 10 years. The axis ranges from 0%–25% in increments of 5%. The probability for each category of Framingham Risk Score was estimated with a model using three levels of C-reactive protein: <1 mg/L (represented by a light grey bar); 1–3 mg/L (represented by a white bar); and >3 mg/L (represented by a dark grey bar). For each category of Framingham Risk Score a probability value is given on the graph indicating the significance of C-reactive protein in the Cox model.

Several studies that examined the performance of adding CRP to traditional CHD risk factors used the change in the c-statistic, or the area under the receiver operating characteristic curve.207, 218, 219, 225 A risk factor that has a small effect on the c-statistic, however, may be strongly associated with risk in a multiple logistic (or Cox) regression model, and vice versa.229–231 We considered the RR from multivariate adjusted regression analysis in prospective studies to be a better measure of CRP’s value as a marker of risk than tests of discrimination such as the c-statistic. From a clinical perspective, the impact on rates of reclassification from intermediate-risk to other categories of risk is a more meaningful measure of CRP’s value as a marker. A recent publication from the Women’s Health Study232 illustrates that the c-statistic does not agree with this measure of clinical utility. The investigators used data from the Women’s Health Study to develop a new risk scoring system for non-diabetic women, based on Framingham variables and hsCRP. The calculation of a new risk scoring system permitted comparison of the impact of hsCRP relative to that of traditional risk factors (Table 5). In the study, model fit was characterized using the Bayes Information Criterion (BIC), the c-index (a generalization of the c-statistic), and the Hosmer-Lemeshow calibration statistic. The model that included CRP had a lower BIC value (6960.26 with CRP vs. 6969.60 without CRP) and a higher calibration p-value (0.23 vs. 0.039), indicating better model fit. Notably, the c-index did not substantially differ between models with and without CRP (0.815 vs. 0.813). Among those originally classified as intermediate-risk (10% to 20%), 14% were reclassified as low-risk (<10%) and 5% were reclassified as high-risk (>20%). For those reclassified as high-risk, the actual 10-year risk was 19.9%, whereas those who remained intermediate-risk had an actual 10-year risk of 11.5%.

Table 5

Scores for Framingham Risk Facotrs and hsCRP

Points | Total cholesterol (mg/dL) | Age (years) | HDL (mg/dL) | Systolic blood pressure (mm Hg) (treated) | hsCRP (mg/L) | Smoking
−2 | <160 | | 60+ | <120
0 | 160–199 | 45–49 | 50–59 | | 0.5 to <1 | No
1 | | | 40–49 | 120–129 | 1.0 to <3
2 | 200–239 | 50–54 | | | 3.0 to <10
3 | 240–279 | | <40 | 130–139 | 10+
4 | 280+ | 55–59
5 | | | | 140–159 | | Yes

Abbreviations: HDL=high density lipoprotein, hsCRP=high sensitivity c-reactive protein.

## Key Question 2a. Prevalence of Risk Markers among Intermediate-risk Individuals

We sought accurate information about the prevalence of abnormal results of the risk factors in the intermediate-risk target group. We did not examine prevalence for the ABI, WBC, or glucose level because the evidence supporting them as independent risk factors was indeterminate. Of the remaining risk factors, three - CRP, homocysteine, and LP(a) - were measured along with most Framingham risk factors and sociodemographic information in subsets of the NHANES sample, providing accurate population-based prevalence data for the target group. In addition, the 3 population-based studies of hsCRP that stratified patients by Framingham risk score also provided accurate information about the prevalence of high hsCRP levels in the target population.

### Periodontal disease

Estimates of the prevalence of periodontal disease in the general population use varying definitions and, consequently, vary widely.67 Some estimates indicate that 75% of adults have some periodontal disease and of those, approximately 20–30% have severe forms.65–67 An analysis from NHANES has shown the prevalence of periodontitis (23%), gingivitis (30%), and healthy periodontum (34%) and found that periodontitis was more common among people with risk factors for CHD and those who are poorer and less educated.75, 233 In the Nurses Health and Health Professional Follow-up studies, 16% of men and 36% of women had 24 or fewer teeth.76

While these population-based sources indicate that periodontal disease is common, no data are available about its prevalence among intermediate-risk individuals. We also did not find reliable data about the prevalence of periodontal disease among Black-Americans and Hispanic-Americans.

### Carotid intima media thickness

We did not identify reliable data about the prevalence of high carotid IMT among asymptomatic intermediate-risk individuals.

### Electron beam computed tomography

In one of the 4 population-based longitudinal studies, the high-CAC score group included over 17% of intermediate-risk males and over 24% of intermediate-risk females.93 A cross-sectional study of 8549 asymptomatic individuals without known CHD also reported prevalence of coronary artery calcification scores among Framingham risk groups (Table 6).234, 235

Table 6

Prevalence of Coronary Artery Calcification (CAC) Scores by Framingham Risk Group

| Males (%) | | | Females (%)
CAC Score | Low | Intermediate | High | Low | Intermediate | High
0 | 48 | 32 | 17 | 63 | 28 | 27
1–100 | 34 | 37 | 36 | 29 | 36 | 30
101–400 | 11 | 17 | 29 | 6 | 24 | 15
>400 | 8 | 13 | 28 | 2 | 12 | 13
>75^th^ age-sex Percentile | 21 | 27 | 31 | 19 | 32 | 40

## Key Question 3. Harms of Risk Assessment

We found no specific evidence about the harms of risk assessment with emerging markers.

EBCT for obtaining CAC delivers about 1 mSv of radiation exposure. Though studies included in this report all used EBCT, many centers are now implementing newer MSCT scanners. The newer Multislice CT scanners are being marketed because they offer better temporal resolution and more complete image reconstruction of the cardiac cycle; however, the radiation dose equivalent of these scanners is significantly higher (10–20 mSv). By contrast, the effective dose equivalent associated with coronary angiography is 6 mSv.236

A 2003 USPSTF review of screening for coronary disease237 assessed other potential adverse effects of screening with EBCT as follows:

“Potential adverse effects of screening for asymptomatic coronary artery disease with EBCT include increased false positive testresults and labeling. As is the case with electrocardiography and exercise electrocardiography treadmill testing, false-positive EBCT results often cause patients to undergo invasive diagnostic procedures such as coronary angiography, with resultant costs and risk of adverse events. Abnormal test results may also produce considerable anxiety until the test result is determined to be false. Labeling a person as suffering from coronary disease may also have negative consequences. Mixed evidence from hypertension screening suggests that being labeled as having increased risk may be associated with poorer future health.” 28

They also noted that in two studies of people’s reactions to a positive EBCT scan, patients were more worried about their health than those with negative results, but the impact of this finding on health and quality of life was unclear.238, 239

## Key Question 4a. Evidence About Treatment in Groups Identified as High-risk by Novel Risk Markers

### Homocysteine

Many trials of folate therapy with or without vitamins B6 and/or B12 have shown that homocysteine can be effectively reduced.240 In healthy adults, however, a causal relationship between homocysteine and CHD would be greatly supported if treatment studies showed a decrease in CHD risk in association with homocysteine lowering treatment. Early data from treatment trials have not shown reduced CHD with treatment.240, 241 Notably, recent data from both the Heart Outcomes Prevention Evaluation (HOPE) 2 study240 and the NORVIT trial241 showed no benefit in reducing the risk of major cardiovascular events in patients with vascular disease or recurrent CVD after acute MI in spite of reducing homocysteine levels with folic acid treatment. However, all trials to date have been of tertiary prevention and conducted among individuals with prevalent CHD, cerebrovascular disease or diabetes. Whether treatment of elevated homocysteine levels before an individual develops vascular disease will be beneficial is not resolved by these trials of tertiary prevention. Intriguingly, the HOPE study showed a significant decrease in stroke with a relative risk of 0.75 (0.59–0.97) supporting a possible role in modifying vascular disease; this was not shown in the NORVIT trial.

### Periodontal disease

Good preventive dental care has multiple benefits, especially on quality of life. Treating periodontal disease has been shown to reduce markers of inflammation such as CRP. However, studies evaluating the effect of preventive dental care or of treatment for periodontal disease on the risk for CHD events have not been conducted.

### Electron beam computed tomography and carotid intima media thickness

Lipid lowering therapy has been shown to be associated with slowing of carotid IMT. Conflicting evidence exists regarding the effect of statins on coronary calcification. In a prospective study of 66 asymptomatic patients with a LDL of at least 130, cerivastatin appeared to slow the increase in coronary calcification, though this finding was not statistically significant. This cohort had a baseline EBCT scan and then a 2^nd^ scan after a mean interval of 14 months without treatment. A 3^rd^ scan was performed after a mean of 12 months of treatment with cerivastatin. During the treatment phase the median CACS increased from 199 (23–3118) to 234 (21.6–3124) as compared to an increase during the untreated period of 165 (20.1–2239) to 199 (p=0.07).242

In a randomized controlled trial, 20 mg of atorvastatin did not reduce coronary calcification after 4 years as compared to no treatment. In the control group, the mean baseline CACS was 563 (25^th^ percentile 183, 75^th^ percentile 671), and the mean CACS at 4 years was 922 (25^th^ percentile 343, 75^th^ percentile 1138). In the treatment group, the baseline CACS was 528 (184, 636) and the 4-year CAC was 846 (335–1077). The p-value of the difference between the 2 groups was 0.80.^243^

### High sensitivity C-reactive protein

Although large randomized trials are lacking, weight loss, exercise training, or both have been associated with reductions in hsCRP and other inflammatory markers in observational (before/after) studies and a few small controlled trials.244 Intensive treatment with statins reduces both LDL-C and CRP. For example, in the Pravastatin or Atorvastatin Evaluation and Infection Therapy (PROVE-IT) trial, a randomized trial of atorvastatin 80 mg vs. pravastatin 40 mg in patients with a recent MI, statin treatment resulted in decreased CRP levels, which was independently and significantly correlated with the rate of progression of atherosclerosis.245 A primary prevention study of rosuvastatin for patients who have an elevated hsCRP is in progress.

## Key Question 6. Reliability, Availability of Population Norms, and Cost

The reliability, availability of population norms, and cost can also affect the choice of a new test for routine use in risk assessment. While most of the candidate tests are reliable and inexpensive, there are some exceptions.

### Periodontal examination

Assessment of periodontal disease is part of the physical examination. Some studies used self report (e.g., How many teeth do you have? Have you ever been told you had periodontal disease?) as a proxy for periodontal examination. The self-reported number of teeth is a highly accurate measure in the general population.66 Questions regarding a history of periodontal disease with bone loss are less accurate; among dentists, these questions have a positive predictive value of 0.76 and a negative predictive value of 0.74. The accuracy when asked in primary care is not clear. A periodontal examination requires skill with dental instruments and x-rays to assess for bone loss, depth of pockets, probe depth, gingival inflammation, number of teeth, plaque status and attachment loss. Most studies combined these assessments into scales such as the Periodontal Treatment Need System, the Russell PD Index, and others. The reliability of this examination in primary care has not been assessed.

### Electron beam computed tomography

#### Inter-observer reliability

CAC scores from a given scan assessed by different readers are highly correlated with over 90% inter-observer agreement and correlation coefficients of 0.99.^246–248^

#### Interscan variation

There is statistically significant variation between two scans performed with close temporal proximity on a given patient. In a study by Yoon, 951 asymptomatic, self-referred patients underwent two consecutive EBCT scans and had coronary calcium scores computed.248 The mean absolute difference between scans one and two was 19.3 +/− 70. Of 951 subjects, 354 (37%) had identical scores on scans one and two; and 314 (88.7%) of these individuals had coronary calcium scores of zero. In those with no coronary calcification on one of their two scans, the largest difference in coronary calcium score was four in women and nine in men.

The clinical significance of this interscan variation depends on the magnitude of the coronary calcium score and the threshold defining high risk. For example, if the threshold to treat were a coronary calcium score of 100 and a patient’s initial scan showed a coronary calcium score of zero, the score from a second scan would be unlikely to approach 100.

#### Scanner and patient variability

In a study by Nelson, calibration “phantoms” with known concentrations of calcium hydroxyapatite were used to explore variation between different types of EBCT scanners and to examine the effects of certain patient characteristics on coronary calcium scores independent of the actual burden of coronary calcification.249 Statistically significant variation was found among CAC scores obtained by different EBCT scanners. Likewise, certain patient characteristics, particularly body mass index, were observed to affect quantification of coronary calcium by EBCT.

Nelson’s group developed a formula to calibrate EBCT scanners to correct for this variation. Standardizing scores in this fashion changed the actual Agatston score category (0, 1–10, 11–100, 101–400, 401–1000,>1000) in only 3.5% of the study participants. This finding suggests that variation in unadjusted coronary calcium scores due to scanner type or patient characteristics have little clinical impact at the population level but may have a clinically significant effect on an given patient’s management if their CACS were near a treatment threshold.249

#### Cost

The cost of an EBCT scan to yield a CAC score is $400–500 per scan.26

### Lipoprotein(a)

Studies vary in sample handling and storage methods, which have not been standardized, and commercial assays are aimed at research laboratories rather than clinical laboratories. A meta-analysis found that storage temperature was strongly associated with variability in Lp(a) analysis.187 Much of the inaccuracy of commercial Lp(a) determinations results from the use of techniques sensitive to apoliprotein(a) size.190 A study by Kronenberg concluded that small apoliprotein(a) isoforms were more susceptible to degradation than large apoliprotein(a) isoforms.191 The ELISA assay has been reported to underestimate the concentration of Lp(a) containing small apolipoprotein(a) isoforms.192 Studies that compared the ELISA and IRMA assay methods reported conflicting levels of agreement between the two assays.181, 193

## Summary of Evidence About Emerging Risk Factors

Table 7 below summarizes the findings and quality of evidence on the nine risk factors addressed in this review, by key question. Table 8 characterizes the evidence for each risk factor according to the evaluation framework described above, in Methods. Several emerging risk factors provided independent information about CHD risk, but for most there were limitations in the evidence base. Across all of the criteria listed in Table 8, hsCRP and EBCT had the strongest evidence for an independent effect in intermediate-risk individuals, and both reclassify some individuals as high-risk. However, data on EBCT are relatively sparse, it is more expensive, and its potential harms require more investigation. Periodontal disease, carotid IMT, homocysteine, and lp(a) probably provide independent information about CHD risk, but data about their prevalence and impact when added to Framingham risk score in intermediate-risk individuals is limited.

Table 7

Summary of Systematic Evidence Review

KQ^#^ | Key Question | Level and Type of Evidence | Quality of Evidence | Comments
1 | Compared with Framingham risk factors alone, does risk stratification of asymptomatic adults using novel risk markers ( Table 2 ) lead to reduced incidence of cardiovascular events (myocardial infarction, angina, sudden death, cerebrovascular accident), coronary heart disease events, or overall mortality? | None | Not applicable | There is no direct evidence that using a novel risk factor in screening leads to reduced incidence of cardiovascular events.
2 | What novel risk markers accurately predict cardiovascular events independent of Framingham risk factors? What is the added predictive value of novel risk markers? | Cohort and nested case control studies | Good-fair for CRP Fair for: Hcy, PD, Lp(a), WBC, FG, carotid IMT Poor for EBCT No evidence for ABI | In large population-based studies that adjusted for all Framingham risk score variables, CRP had a pooled RR of 1.66 (95%CI: 1.37, 2.02) for CRP >3.0 mg/L compared to CRP <1.0 mg/L. Some risk factors (Hcy, PD, Lp[a]) appear to be independently associated with incident CHD, but studies did not clearly establish applicability to the intermediate-risk population. For other risk factors, the results were inconsistent or the association was weak (WBC, FG), or the studies had more serious flaws (WBC, IMT). EBCT studies used unconventional measures for Framingham risk score factors and had self-selected subjects.
2a | What is the prevalence of these risk markers among intermediate-risk and low-risk individuals? | Population-based studies including NHANES | Good for: Hcy, Lp(a), and CRP Fair for: periodontal disease, EBCT Poor for: carotid IMT Not assessed for ABI, WBC, FG. | Reliable prevalence data are available from NHANES for Hcy, Lp(a), and CRP. Limited data on periodontal disease indicators are available in NHANES. Prevalence data for EBCT are limited by uncertain applicability to the general population. Prevalence was not assessed for ABI, WBC, and FG due to lack of evidence of an independent association.
2b | At what frequency does application of these novel risk markers significantly change the 10 year risk of cardiovascular events based on traditional risk factors alone? (e.g., from intermediate risk [10–20%] to high risk [>20%] or to low risk [<10%]) | Cohort and nested case control studies for CRP, combined with prevalence data from NHANES | Good for CRP Not applicable for other risk factors | In a prediction model based on good-quality cohort studies, about 31% of men and 6% of women were classified as intermediate-risk of CHD before adjustment for CRP, and about 11% of men and 6% of women originally in the intermediate risk group were reclassified to the high risk category after adjustment for CRP. We did not conduct similar analyses for other novel risk factors due to lack of evidence of an independent association, or uncertain applicability to the target population.
3 | What are the harms of risk assessment? | None | Not applicable | We found no direct evidence regarding the harms of risk assessment. One study noted that potential adverse effects of screening with EBCT include increased false positive test results, leading to overuse of invasive diagnostic procedures, but provided no specific data. EBCT for CAC delivers about 1 mSv of radiation exposure, but EBCT scanners have been largely replaced by Multidector CT scanners that deliver 10 times more radiation than EBCT, or 2–4 times more than coronary angiography.
4a | In groups identified as high-risk (>20% 10-year risk) by novel risk markers, does aggressive risk factor modification (treatment to lower blood pressure and lipid targets or more intense counseling) lead to improved intermediate outcomes (e.g., reduction in lipid levels; reduction in blood pressure; increased physical activity; healthy dietary changes, etc.)? | See comments | See comments | There is strong evidence (not addressed in this review) that aggressive risk factor modification improves intermediate outcomes among groups identified as high risk using traditional risk factors alone. It is plausible that aggressive risk factor modification would have a similar effect in individuals identified as high- risk by a combination of traditional and novel risk factors, but we did not find treatment studies conducted in such a group.
4b | In groups identified as high-risk (>20% 10-year risk) by novel risk markers, does aggressive risk factor modification lead to reduced incidence of cardiovascular events (myocardial infarction, angina, sudden death, cerebrovascular accident), cardiovascular disease-specific mortality, overall mortality? | None | Not applicable | We found no trials of aggressive risk factor modification in patients who were classified as high-risk because of novel risk factors, who would otherwise have been treated as intermediate-risk.
5 | What are the harms of aggressive risk factor modification? | See comments | See comments | The adverse effects of risk factor modification are described in other USPSTF reports (e.g., Screening for Dyslipidemia in Adults; Screening for Dyslipidemia in Children and Adolescents; Screening and Treatment of Obesity in Adults) and in smoking cessation guidelines. These are available at: http://www.ahrq.gov/clinic/uspstf/uspstopics.htm
6 | What are the costs associated with risk factor assessment and aggressive risk factor modification? | None | Not applicable | Most of the tests are inexpensive. In one EBCT study, the cost of an EBCT scan to yield a CAC score was $400–500 per scan. There has been no adequate evaluation of costs associated with additional procedures generated from use of tests for novel risk factors.

Abbreviations: ABI=ankle brachial index, CAC=coronary artery calcium; CRP=C-reactive protein; EBCT=electron beam computed tomography; FG=fasting glucose; FRF=Framingham risk factors; Hcy=homocysteine; IMT=intima media thickness; Lp(a)=lipoprotein(a), NHANES=National Health and Nutrition Examination Survey, PD=periodontal disease, RR=relative risk, USPSTF=United States Preventive Services Task Force, WBC=white blood cell count.

Table 8

Assessment of the Strength of Evidence and Magnitude of Benefit

Validity of evidence | | | | | | Net benefit or harm
Evidence on independent effect after controlling for Framingham factors | | | | | | Magnitude of effect * | Prevalence | Other considerations
Number of cohorts | Study design | Limitations (aggregate quality) | Consistency | Applicability (intermediate -risk individuals in the general population) | Other † | Adjusted relative risk (95% CI) | Prevalence in intermediate- risk individuals in the general population | Reliability, population norms, and cost | Treatment effects? | Harms
Ankle-brachial index
0 | Cohort | Serious limitations ‡ | No important inconsistency | Significant uncertainty ‡ | None | Not assessed | Not assessed | Not assessed
C-reactive protein
18 | Cohort & Nested Case- Control | Some limitations | No important inconsistency | Good | +Dose- response | 1.64 (1.41–1.91) for >3.0 v. <1.0 | Good (NHANES) and others | Reliable; Inexpensive | See note § | Low or none
Carotid intima media thickness
5 | Cohort | Some limitations | No important inconsistency | Some uncertainty \|\| | Sparse data | 1.19 to 3.8 | Poor Evidence | Not assessed | Unclear (for cardiac effects) | Unclear
Electron beam computed tomography
9 \|\| | Cohort | Serious limitations ¶ | No important inconsistency | Significant uncertainty (patients, outcome measure) \|\| | Sparse data | 2.56 (1.96, 3.35) for 1–100 v. 0 5.35 (3.13, 9.16) for 101–400 v. 0 8.01 (4.81, 13.33) for >400 v. 0 | Fair Evidence | Relatively low reliability; No norms for general population; Expensive | Conflicting evidence | Significant potential harms
Fasting glucose
10 | Cohort | Some limitations | Some inconsistency | Some uncertainty \|\| | Weak or absent association | None or small | Not assessed | Not assessed
Homocysteine
24 | Cohort & Nested Case- Control | Some limitations | Some inconsistency | Significant uncertainty \|\| | None | 1.18 (1.10–1.26) all studies & 1.21 (1.10–1.32) CHD explicitly excluded, per 5 μmol increase | Good (NHANES) | Reliable; inexpensive | Folate decreases serum levels but effect on CHD unknown | Low or none
Lipoprotein(a)
21 | Cohort & Nested Case- Control | Some limitations | No important inconsistency | Significant uncertainty (patients, outcome measure) | None | 1.57 (1.31–1.88) for 30+ v. <30 mg/dL | Good (NHANES) | Low reliability; No standard commercial assay | Unclear | Low or none
Periodontal disease
7 | Cohort | Some limitations | No important inconsistency | Some uncertainty \|\| | None | 1.24 (1.01–1.51) | Fair Evidence | Uncertain reliability; Inexpensive | Unclear | Unclear
White blood cell count
10 | Cohort & Nested Case- Control | Some limitations | Inconsistent results | Some uncertainty \|\| | Plausible confounders | 1.01 to 2.10 | Not assessed | Reliable; Inexpensive | No evidence | Low or none

* Table 8 shows a single risk ratio with 95% confidence interval if we conducted a meta-analysis for the risk factor. A range of point estimates indicates the highest and lowest risk ratios reported among studies that were not combined in meta-analysis.

† Negative factors include: imprecise or sparse data; high risk of reporting bias; effect of plausible residual confounding; a weak or absent association. Positive factors include: a strong or very strong association; evidence of a dose-response gradient.

‡ No studies were eligible because of: (1) inclusion of subjects with known coronary artery disease or symptomatic peripheral vascular disease, or (2) coronary heart disease events were not reported as an endpoint.

§ Weight reduction, statins, and other interventions reduce c-reactive protein. Evidence linking c-reactive protein changes to coronary heart disease events is limited.

|| Studies did not establish applicability of results to intermediate-risk individuals.

¶ Most studies had self-selected patients. Not evaluated in the major population-based cohorts. Use of self-report for Framingham risk factors could inflate estimates of the contribution of coronary artery calcification score. Results given are for two population-based, good-quality cohort studies.

Abbreviations: CHD=coronary heart disease, NHANES=National Health and Nutrition Examination Survey.

## Key Questions 2b, 4, and 5. Predicting the Potential Impact of Testing on Reclassification and Coronary Events

Direct evidence of the impact of testing for CRP on CHD events is not presently available. To examine the potential impact of CRP testing, we developed a model to estimate the impact of using a CRP test to stratify individuals classified as intermediate-risk based on the NCEP/ATP III risk equation. The methods we used to develop this model are described in detail above (II. Methods).

We extracted data for 5,335 survey participants, age 40 to 79 years, from the combined NHANES 1999–2000 and NHANES 2001–2002 datasets. Of these, 2,665 were men (weighted population n, 51,691,227), and 2,670 were women (weighted population n, 57,329,733). Population weights were age-adjusted using the reference population from year 2000 census data. We excluded 258 males (weighted n, 3,972,053) and 158 women (weighted n, 2,772,778) with prior cardiovascular events or CHD-equivalents (angina, stroke, congestive heart failure, diabetes). We also excluded 900 participants with incomplete data, including 622 who did not have complete Framingham risk factor data, and 278 who did not have hsCRP data.

The remaining 4,019 participants consisted of 1,949 men (weighted n, 39,055,881) and women and 2,070 women (weighted n, 45,382,856). The weighted mean age of men was 53.7 years and 55.2 years for women. Among both men and women, about 77 % were White-American, 9% were Black-Americans, and 11% were Hispanic-Americans, with other racial and ethnic groups accounting for the remaining 3%. Altogether the included participants represented 78% of the standard age-adjusted reference population of 109 million individuals aged 40–79 years based on year 2000 census estimates.

Risk Distribution (RD) Table 11 describes the characteristics of the 1,949 included men classified into three CRP categories, hsCRP< 1.0 mg/L, hsCRP 1.0–3.0 mg/L, and hsCRP >3.0 mg/L. Men with elevated hsCRP tended to be older, had higher total cholesterol and lower HDL cholesterol, higher systolic blood pressure, were more likely to be treated for hypertension, and are more likely to smoke. Among men, between 13.3% and 16.5% were also taking medication to lower cholesterol, a non-significant difference, although the intensity of treatment might have varied across categories. This could impact the 10-year risk of CHD events, however, cholesterol treatment is not incorporated in the ATP III risk prediction equation. As expected, based on the higher burden of traditional Framingham CHD risk factors, the baseline risk of expected CHD events at 10 years significantly increases as hsCRP increases. RD Table 12 shows similar patterns of characteristics for 2,070 women across each hsCRP category, except that the prevalence of smoking in women is relatively the same across categories.

RD Tables 11 and 12 also show the distribution of hsCRP values by race and ethnicity. Black American men had a significantly higher prevalence of hsCRP > 3 mg/L than Hispanic American men. A higher prevalence of elevated hsCRP (> 3 mg/L) was seen in both Black American and Hispanic American women compared to White American women. There were too few survey participants to reliably estimate prevalence for other racial or ethnic groups (e.g., Asian Americans, Native Americans).

CRP might be used in two different ways to improve risk stratification and primary prevention in the general population. One approach would be to obtain serum hsCRP levels on all individuals. This approach might be preferred if a large proportion of individuals in each category would be reclassified by adding hsCRP to initial screening. RD Table 13 shows how, using this strategy, the proportion of individuals classified as low (predicted 10-year risk of events <10%), intermediate (10–20%), or high risk (> 20%) changes when hsCRP is included in the risk prediction equation. The clinical endpoint used in the model was the number of CHD events averted over 10 years. Overall, the proportion of men classified as high risk increased from 9.1 (8.1, 10) to 10.8 (CI 9.5, 12.0), and the proportion of women classified as high risk increased from 0.7 (0.0, 1.1) to 1.0 (0.0, 3.0). The pattern of changes in the low-risk and intermediate-risk groups was inconsistent across age, sex, and racial subgroups.

A second strategy is to use hsCRP to further stratify intermediate-risk individuals, but not to test individuals who are initially classified as low-risk or high-risk. Before adjustment for hsCRP, 30.7% of men (n, 737; weighted n, 11,981,854) and 7.0% of women (n, 168; weighted n, 3,196,119) were classified as intermediate-risk for CHD events (RD Table 13). RD Table 14 shows the impact of testing for hsCRP in this group. CRP testing in men with intensive risk-reduction therapy of those reclassified from the intermediate to the high-risk category could potentially avert 47.8 CHD events over 10 years per 1,000 events in men age 40 to 79. We assumed that individuals reclassified from the intermediate-risk to high-risk category after adjusting for CRP-associated risk would receive aggressive risk-reduction therapy, with an efficacy of 30% in reducing the risk of future CHD events, and assumed 100% patient adherence with treatment.

In a sensitivity analysis using the lower and upper confidence intervals for the combined risk ratio from the meta-analysis, the estimated number of CHD events averted ranged from 19.2 per 1000 events to 78.5 per 1000 events in men age 40 to 79 years. Too few women age 40 to 49 years were reclassified to the higher risk group to reliably predict any potential of benefit of CRP testing. Among women (weighted n) from the NHANES 1999–2002 study classified in the intermediate (10–20%) risk category based on traditional Framingham risk factors, only 10 women were reclassified to the high risk group after adjustment for CRP-associated risk. RD Table 15 shows the characteristics of men who were reclassified from the intermediate risk to the high risk group compared to those remaining in the intermediate risk group after adjustment for CRP. Men in the higher risk group were older, had higher total weighted mean total cholesterol, higher weighted mean systolic blood pressure, and tended to be more likely to take cholesterol and blood-pressure lowering medications.

To place these findings in perspective, we applied the same model to examine a hypothetical blood pressure reduction strategy. Among 737 men and 186 women in the intermediate risk category, based on Framingham risk factors only, 128 men and 45 women had systolic blood pressures > 140 mm Hg (Stage 1 hypertension) and were not taking hypertension medications. The weighted mean systolic blood pressure in these individuals was 151.6 for men (95% CI, 146.8 to 156.4), and 163.7 for women (95% CI, 159.6 to 167.9). We assumed a 10-year risk reduction for CHD events of 21% (95% CI, 8% to 31%), based on a meta-analysis of clinical trials comparing low-dose diuretics with placebo for hypertension treatment.250 Among all ages, assuming 100% patient adherence, hypertension therapy in this group could potentially avert 31.9 (95% CI, 12.2 to 47.1) CHD events at 10 years per 1000 men and 27.5 (95% CI, 10.5 to 40.6) CHD events at 10 years per 1000 women. Because there is strong evidence for the benefit of blood pressure screening and treatment as a primary prevention strategy for CVD,251 this strategy would be appropriate for all patients with untreated hypertension in the intermediate risk group.

### Summary

We found that elevated CRP is significantly associated with elevated levels of other CHD risk factors, as has been reported previously for the NHANES population.198 This may explain our finding that incorporating the increased risk for CHD associated with CRP might have little impact in improving global risk assessment for CHD in the US. These findings substantiate those of previous studies that conclude that obtaining CRP measurements as a part of routine CHD risk factor assessment for all individuals may not improve global assessment of CVD risk in the population.198, 219

An important issue, however, is whether selected individuals could potentially benefit from improved CHD risk stratification based on CRP measurement. The 2003 consensus statement from a joint committee of the AHA and the CDC recommended that CRP measurements may be considered as another risk factor in guiding therapy specifically for those individuals with a 10–20% 10-year CHD risk based on traditional risk factors.16 Soon afterwards, an updated meta-analysis of epidemiologic studies of CRP found that earlier estimates of its predictive ability were inflated, leading to reconsideration of the consensus conference’s recommendations.205

Our analysis suggests that, using estimates of relative risk based on recent epidemiologic studies that had more complete adjustment for confounders, CRP measurement may be useful in this context for men. We found that that adding hsCRP testing for men with intermediate 10–20% 10-year CHD risk could potentially avert 47.8 hard CHD events (fatal or non-fatal MIs) over 10 years in men.

There were too few women in the intermediate risk group who were reclassified into the high risk group to reliably predict potential CHD events averted. We think this is largely explained by the finding that over 90% of women in this large population-based survey fall into the low risk category (< 10% 10-year CHD risk) based on traditional Framingham risk factors alone. It is conceivable that among women age 70–79 years, of whom 30.6% fall into the intermediate risk category, some could potentially benefit from reclassification based on elevated CRP measurements, however there are too few women in the NHANES 1999–2002 data to assess this.

This study is useful because it examines the burden of CHD risk and first CHD events that may relate to elevated CRP among NHANES 1999–2002 participants, a well-studied cross-sectional survey population representative of the US adult population. Studies of CRP in specific populations are useful in assessing the relative risk associated with this biomarker of inflammation.204, 207, 217, 252 Our model builds on previous studies using NHANES III survey data to study the population distribution of CHD risk in US adults,253 and to assess the public health impact of treatment for borderline levels of traditional CHD risk factors based on the attributed risk of first CHD events related these.12 An earlier, unpublished model we developed using CRP data from the NHANES III survey, that did not use the presently available hsCRP assay, found similar results to the model presented here.

A particular strength of this study is that we are able to focus attention on specific segments of the larger population that may receive the most benefit from CRP measurement. While our findings should be examined further in prospective, population-based studies, they indicate that CRP measurement could play an important role in improving the prediction of CHD risk in a large segment of the US male population. Our model would also be applicable to understanding the potential benefits of other novel risk factors. For example, we also had sufficient information from our evidence review to model potential benefits for homocysteine testing, however, this data was not available in the NHANES 1999–2002 data set.

The clinical utility of measuring CRP, however, arises from the potential benefit of treatment for those identified with elevated with CRP. It is presently not clear that any treatments are effective in reducing excess CHD risk that may attributable to elevated CRP. It has also been proposed that knowledge about elevated CRP levels may be useful in encouraging therapeutic lifestyle change in some individuals.223, 252 Conversely, a low CRP level could provide false reassurance that lifestyle change is not needed. Finally, if a lower CRP level leads to lower estimated risk of first CHD events in relation to assessment with traditional risk factors, there is presently no evidence supporting a less aggressive approach to medical management than recommended by NCEP/ATP III guidelines.

This study has several limitations. We used several “best-case” assumptions about the effectiveness of treatment. The first is that individuals reclassified as high-risk by a high CRP level would benefit as much from aggressive treatment as other high-risk individuals. The second is that we applied the risk reduction in CHD events from aggressive risk reduction management, observed in controlled trials over 2 to 5 years, to the entire 10-year risk of events. This assumption could be wrong if the benefits of aggressive treatment dissipate 5 to 10 years after initiation. Third, we assumed that the relative risk reduction from trials of statin therapy reflects the balance of benefits and harms in the population that would be identified by a CRP. In fact, many of these trials are selected for characteristics associated with a lower rate of adverse events and a higher compliance rate than would be observed in the general population.

There are other factors that influence the potential benefits of CRP testing that our model does not account for. For example, about 1 in 5 men who were reclassified from the intermediate risk to the high risk group (RD Table 15) were already taking cholesterol lowering medication. A comparison of serum lipoprotein levels in adults over 20 years of age between the NHANES III data (1988–1994) and more recent NHANES 1999–2002 data showed a significant decrease in LDL cholesterol levels, but no change in HDL cholesterol levels.254 This change was observed despite a significant increase in the prevalence of obesity and minimal changes in total dietary cholesterol. Over this same time, however, there was a significant increase in the proportion of US adults taking cholesterol lowering medications from 3.4% in 1988–1994 to 9.3% in 1999–2002. Present NCEP/ATP III treatment recommendations classify individuals into a number of different subgroups based on CHD risk factors and LDL cholesterol levels.3 The NCEP/ATP III risk prediction equation does not consider cholesterol treatment. If men reclassified from the intermediate to the high risk group were already receiving treatment of elevated cholesterol, then the incremental benefit of aggressive risk-reduction therapy could be lower than that predicted by our model.

We also found that a significant number of first CHD events might be averted in both men and women by applying accepted primary prevention strategies such as blood pressure screening and treatment. About 17% of men and 24% of women falling into the intermediate risk category had at least Stage I hypertension (systolic blood pressure >140), but were not taking blood pressure lowering medication. Among men in particular, this would be expected to lower the overall risk of 10-year CHD events in the intermediate risk category. As a result, there would likely be fewer men reclassified as high risk after adjustment for CRP. Tobacco cessation counseling and treatment is another effective and cost-effective CHD primary prevention strategy that would lead to a significantly fewer first CHD events over 10 years, but has yet to be fully integrated into most clinical practices.255–257

We applied the NCEP/ATP III risk prediction equation, based on Framingham risk calculations, to predict CHD risk in a multi-racial, multi-ethnic population. We choose this approach in order to study risk distributions in participants who were more representative of the broader US population rather than limit our study to whites only. The Framingham CHD prediction algorithm has been validated and appears reasonably accurate in other racial/ethnic groups, excepting Hispanic men in whom the Framingham risk prediction scores overestimate CHD risk.7 In our study, we did not find that Hispanic men had a significantly higher estimated 10-year CHD risk than other racial/ethnic groups, and excluding Hispanic men did not change the distribution of CHD risk before and after CRP adjustment in the remainder of the study population. Adjustment for CRP-related risk also did not change the distribution of CHD risk among Hispanic men.

While our findings should be examined further in prospective, population-based studies, our analysis indicates that CRP measurement could play an important role in improving the prediction of CHD risk in a large segment of the US male population with 10–20%10-year risk of first CHD events.