# 2 Methods

## Evaluation Framework

At the outset, USPSTF members met with the investigators to determine how the report findings would be used in making recommendations for risk assessment in primary care. These discussions centered on what information about an emerging risk factor would be considered to be sufficient to recommend its use in intermediate-risk individuals in primary care practice.

Based on input from USPSTF members, and review of previously developed frameworks for evaluating the evidence and impact of a new prognostic test16 or diagnostic test20, we developed an approach for evaluating and comparing each candidate risk factor. In this report, we

- Describe the strength and consistency of evidence that each risk factor provides independent prognostic information when used in addition to the Framingham scoring in intermediate-risk individuals.
- Assess the impact of using the risk factor on reclassification of individuals from intermediate to high risk and to low-risk.
- Estimate the potential impact of adding the risk factor on morbidity and mortality due to coronary disease and stroke.

The overall evaluation scheme is shown in Figure 2 and discussed in detail below. The potential impact of a novel risk factor depends on: 1) its predictive ability, 2) its prevalence in the target population, 3) the number of intermediate-risk individuals who are reclassified as high-risk when the risk factor is applied, 4) the net benefit (benefits minus harms) that would accrue to these high-risk individuals if they were managed according to guidelines for high-risk patients. We addressed these features of each test sequentially, for example, if predictive ability had not been well established we did not proceed to evaluate prevalence and clinical impact.

Figure 2

Sequential Evaluation Scheme for Each Risk Factor

This figure depicts the sequence of the authors’ approach for evaluating and comparing each candidate risk factor for coronary heart disease assessment. At the top of the diagram appears the first consideration in the authors’ evaluation: “Validity of evidence about predictive ability.” This consideration is divided into six columns, which read from left to right: “number of studies,” “design,” “validity of evidence (limitations),” “consistency,” “applicability to intermediate-risk individuals in the general population,” and “(+) A strong or very strong association, evidence of a dose-response gradient, prediction independent of Framingham variables. (−) Imprecise or sparse data, high risk of reporting bias, plausible residual confounding.” The sequence then proceeds down to the next consideration, which is “Prevalence.” One question appears in this section: “Is there reliable evidence about the prevalence among intermediate-risk individuals in the general population?” The sequence then proceeds down to the next set of considerations, “Other considerations,” which includes three questions. Question 1 is “Can the assay or test be standardized? Is retest variability accepted?” Question 2 is “Are there population norms to guide interpretation of results?” Question 3 is “What are the costs, burden, and harms of using the test?” The sequence then proceeds down, ending at “Estimate number of reclassified individuals and net benefit.”

## Literature Search and Strategy

For each risk factor listed in Table 2, we conducted multiple searches of MEDLINE (1966 to March 2006). We focused searches on identifying epidemiologic studies relevant to the independent predictive ability of the risk factor when used in intermediate-risk individuals (Appendix I). We obtained additional articles from recent systematic reviews, reference lists of pertinent studies, reviews, editorials, websites, and by consulting experts.

## Eligibility Criteria

We reviewed abstracts and full-text articles identified by the searches for relevance (Appendix II). Eligible articles had English-language abstracts and provided primary data relevant to the key questions. We excluded studies conducted exclusively in adults with previously diagnosed coronary disease or coronary disease equivalent (e.g., diabetes). Studies were included if they reported, at minimum, outcomes of coronary deaths and non-fatal MIs. Only prospective cohort studies (including those based on a cohort included in a randomized trial) and nested case-control studies were considered for assessing the predictive value of the novel risk factors.

We listed the cohorts represented among included studies and grouped publications by cohort. When more than one paper was published using data from a single cohort, we analyzed the findings for the cohort study rather than the nested case control study, or from the analysis with the highest validity and applicability to the study questions based on our quality ratings. For each cohort, we reviewed included and excluded publications to determine whether a particular risk factor had been measured. Then we determined whether published studies reported results in a manner that would allow us to determine the odds ratio for the novel risk factor among patients who did not have known CVD or diabetes and were intermediate-risk. When it was clear that a risk factor had been measured, but the independent contribution of the risk factor for predicting CHD events in the target population could not be determined, we contacted authors for more information that would enable us to include the cohort in the review.

## Approach to Assessing the Strength of Evidence

The overall strength of evidence is a function of the validity and applicability of individual studies as well as several dimensions of a body of studies.

### The validity of individual studies

The validity assessment evaluates the extent to which one can be confident that a study’s estimate of effect is correct. Investigators rated the validity of evidence of each study using criteria specific to cohort and nested case-control studies (Appendix III).21 These criteria were applied previously to large bodies of observational studies of hormone replacement therapy22 and of vitamins and the long-term risk of cardiovascular events.23

### Applicability of individual studies

Investigators assessed the applicability of each study’s sample, risk assessment, and outcome measures to the targets for this review. In rating the applicability of each study, investigators assessed the following study characteristics:

1. Study Sample. Ideally, the study sample was drawn from the general population or a demographic subset of asymptomatic adults who would be classified as “intermediate risk” in the ATP-III risk stratification scheme. Samples that included patients with known CHD or diabetes were acceptable if multivariate analyses adjusted for these characteristics or the results for the target population could be extracted from the study. A poor rating for Framingham Risk Factor assessment (next item) would reduce the likelihood that the study sample was representative of intermediate-risk individuals. Inclusion of additional risk factors (e.g., family history, triglyceride level) did not reduce the applicability rating.
2. Framingham Risk Factor measurement. Many studies used risk stratification schemes that were not identical to the components of the Framingham score; for example, some studies used the patient’s report of whether they had a history of hypercholesterolemia as a proxy for an actual total cholesterol level, while others had components (e.g., triglyceride level, family history) that were not included in the Framingham risk scoring model. Investigators compared the actual measures used for each component of the risk assessment method and coefficients from the study’s prediction model to the gold standard of the measurements and model coefficients used in developing the Framingham risk score.4
3. Emerging Risk Factor measurement and categories. Clinical, radiologic and laboratory test methods varied among studies. Some of this variation reflected improvement over time in assay or radiologic methods (for example, higher-sensitivity assays or higher-resolution radiographs). We recorded the methods used to measure the emerging risk factor and to define abnormal results. For many of these tests, a gold standard definition of abnormality has not been defined, and studies used a variety of quantiles (tertiles, quintiles, deciles) to make statistical comparisons.
4. Outcomes (Events). Studies used a variety of measures of the incidence of coronary or cardiovascular events. For the purpose of this review, the ideal measure included fatal and nonfatal MI and death due to coronary disease (“hard CHD” events.) When possible, we analyzed results for these events, but we also analyzed studies in which these events could not be separated out from broader measures that included other coronary events, such as unstable angina and percutaneous coronary intervention; and measures that included hard CHD events plus stroke (“major cardiovascular events”, CVD).

### Strength of evidence for a body of studies

Judgments about the validity or strength of evidence for a body of studies require consideration of study design, limitations of quality within a given design, consistency and applicability of the evidence. By a “body” of studies, we mean all evidence that addressed a specific question. For example, a body of evidence might include 10 cohort studies and 5 nested case-control studies addressing the predictive ability of CRP in intermediate-risk subjects. In rating the strength of a body of studies, investigators considered:

- The aggregate validity and applicability of the body of studies.
- The number and range of studies. A higher number of independent cohorts and a wider range of study circumstances compared with other risk factors would improve the rating.
- The consistency of results, that is, the similarity of effect across studies and, if applicable, across study designs. Evidence of consistency related to a dose response relationship, or the use of various cut-offs for an elevated test result, would also strengthen confidence in the validity of the body of literature.
- The precision of the results.
- The risk of reporting bias.
- The likelihood that there is a flaw common to most or all of the studies in a body of evidence. This criterion protects against the circumstance in which consistency of results reflects a consistent bias or flaw in study design. For example, failure of most or all studies to address a known potential confounder, or failure of some studies to adjust for a confounder that was important in other studies, would weaken confidence in the validity of the body of evidence.

## Approach to Assessing the Magnitude of Benefit

As noted above, the predictive ability of a risk factor, its prevalence, and the number of people who are reclassified as high risk affect the outcome of interest, that is, the reduction in the incidence of “hard CHD” events that would occur when the risk factor is applied.

### Predictive ability

We reviewed population-based, epidemiologic studies that assess the ability of the risk factor to predict major CHD events independently of Framingham risk factors in intermediate-risk subjects (Key Question 2).

For each risk factor that had consistent, fair-to-good-quality evidence, we conducted a meta-analysis of epidemiologic studies to determine the combined estimate of association between various risk factors and CHD events after controlling for Framingham risk factors. Estimates of risk ratio (relative risk [RR], hazard ratio [HR] or odds ratio [OR]) were obtained from a model with adjustment of Framingham risk factors from each study. Since different studies reported risk ratios on the basis of different cutoff levels including median, tertiles, quartiles or quintiles etc., or as increase in risk for a given increase in the risk factor, we standardized the risk ratio of each risk factor in the following ways to provide clinically relevant and easily interpretable results. For CRP, we adopted cutoff points proposed by CDC/AHA16 (Low < 1.0mg/L; Average 1.0 – 3.0 mg/L; High > 3.0 mg/L) with group of < 1.0 mg/L as reference. When studies categorized CRP concentrations using other cutoff points, we calculated risk ratios using 1.0 and 3.0 mg/L as cutoff points by assuming that CRP is log-normally distributed24 and there is a log-linear association of CHD risk over mid-range of log-CRP concentrations.24 Distribution parameters of CRP were estimated from published information from each study. For coronary artery calcium (CAC) score, we standardized the results into 4 CAC score categories (0 as reference, 1–100, 101–401, and > 400). These or similar categories have been used in several studies,25–27 and represent a simple categorization of the range of CAC scores encountered in clinical practice. The risk ratios based on these four categories were calculated from the published estimates assuming a log-linear relationship between CHD risk and log-CAC score28 or age- and sex-adjusted percentiles (CS% score).29 The median CAC score and the median CS% score in each of these categories was estimated using published cross-sectional data29 and we matched the age and gender distribution for each study. For homocysteine, many studies reported risk ratios per unit increase in homocysteine concentration, and we standardized the estimates to be risk ratios of a 5μmol increase, as well as risk ratio of top quintile vs. bottom = quintile assuming a log-normal distribution of homocysteine (since most studies reported a right-skewed distribution of homocysteine), and log-linear relationship between CHD risk and homocysteine concentrations.

Heterogeneity was assessed by standard χ^2^ tests. The risk ratios were combined by using a random effects model to account for variation among studies. When there is no variation among studies, the random effects model yields the same results as a fixed effects model. Study level variables such as degree of adjustment (the number of Framingham variables adjusted, the number of non-Framingham variables adjusted), mean duration of the study, study design (cohort vs. nested case-control), outcome measures (hard CHD events vs. hard plus other CHD or CVD events), quality rating, and for CAC score, minimum area of calcification, slice thickness and risk factors measured or by questionnaire, etc., were investigated either by using a random effects meta-regression or by sensitivity analysis. Publication bias was checked using funnel plots and Egger’s linear regression method30 and adjusted using the “trim and fill” method31 when necessary.

### Prevalence

Even if a risk factor has been shown to provide independent information, its usefulness in screening cannot be reliably assessed unless there are reliable estimates of its prevalence in the target population. For risk factors that had statistically significant and independent predictive ability, we assessed the prevalence of the risk factor in the intermediate-risk population, with particular attention to the availability and reliability of estimates of prevalence among demographic subgroups. When available, we also used nationally representative data to estimate prevalence. We considered lack of data about prevalence in the target population (intermediate-risk adults) to be a serious limitation. For tests that lacked such information, we did not proceed to subsequent steps in examining the magnitude of benefit.

### Other considerations

If meta-analysis of the population-based studies indicated that use of the test is able to improve overall prediction beyond that of traditional risk factors, we examined several other characteristics that affect its actual impact in practice, including:16

1. the ability to standardize the assay and to control the variability of the measurement
2. the presence of population norms to guide interpretation of results
3. the costs, burden, and harms of using the test

Among risk factors that had similar predictive ability and prevalence, differences in cost, convenience, technical characteristics such as intra-assay or inter-observer reliability, and harms could affect the acceptability and cost-effectiveness of testing intermediate-risk individuals. We examined evidence about these characteristics to choose candidate risk factors for further analysis.

### Number of reclassified individuals

For risk factors that had at least fair-quality data about prevalence in intermediate-risk individuals from the general population, we extracted information about the number of intermediate-risk individuals reclassified as high-risk or low-risk by using the novel risk factor when it was available in published studies.

### Net benefit

At present, no randomized controlled trials have assessed whether risk stratification of intermediate risk patients using a novel risk factor, and more aggressive risk factor modification of patients identified as high-risk on the basis of a novel risk factor, improves outcomes (Key Questions 1 and 4b.) There are also no data from adequately powered controlled trials that would permit a direct measurement of the benefits or harms of treatment decisions arising from use of a novel risk factor in intermediate-risk patients (Key Questions 4a and 5).

A body of evidence, however, indirectly supports the view that the benefits of aggressive risk factor management with lipid-lowering therapy depends on overall risk, even when low density lipoprotein levels are not elevated.19 If the benefits of aggressive risk factor management are more related to overall risk than to the specific contributing risk factors, correctly classifying more high-risk patients would be expected to be beneficial. Therefore, after consultation with USPSTF members, we chose to estimate the net benefit to reclassified individuals by assuming that they have a net benefit similar to those of high-risk and very-high-risk subjects in major lipid-lowering trials.

This approach provides an estimate of the upper bound of potential benefit rather than the expected or likely benefit. Moreover, the validity of this assumption is likely to differ for different risk factors or categories of risk factors. For example, the validity of this assumption might be different for inflammatory markers, such as hsCRP or periodontal disease, than for markers of atherosclerosis such as coronary calcification or ankle-brachial index; or lipid-related markers such as triglyceride or Lp(a) levels.

The literature review and meta-analyses described above resulted in information about the strength of evidence, prevalence, and adjusted odds for predicting the 10-year risk of CHD events for each risk factor. We tabulated this information, adding in information about reliability and cost, to select risk factors for further analysis of the number of individuals who would be reclassified by using the risk factor to further stratify intermediate-risk subjects. To be selected for additional analysis, the risk factor had to have at least fair strength of evidence; there also had to be reliable information about the prevalence of the risk factor among intermediate-risk individuals in the adult population (or in a defined demographic subgroup of the general population); and our estimate of the adjusted odds ratio for the 10-year risk of hard CHD events had to be statistically significant and relatively high compared with others.

## Modeling Potential Benefits of Risk Factor Testing

For one risk factor, high sensitivity C-reactive protein (hsCRP), the availability of data from the NHANES 1999–2002 survey allowed us to construct a model to estimate the potential benefit of testing and treatment in individuals with no prior history of CHD who were representative of the US population. The choice of hsCRP was also desirable because the estimate of the adjusted odds ratio for the 10-year risk of hard CHD events from our meta-analysis was statistically significant and relatively high compared with other risk factors. As such, the potential benefit of testing and treatment based on hsCRP would likely represent an upper bound of the potential benefit from using other risk factors to improve CHD risk prediction.

Direct evidence showing that CRP testing reduces future risk of CHD events is not presently available. To estimate the potential benefit of CRP testing, we developed a model that predicts the impact of using CRP measurements to reclassify individuals in an intermediate risk category, defined as a 10%–20% 10-year risk of “hard” CHD events (fatal or non-fatal MIs) based on traditional Framingham risk factors 10–20% CHD 10-year risk category to a high-risk category, defined as >20% 10-year risk of hard CHD events. The clinical endpoint for the potential benefit of CRP testing in the model was the number of hard CHD events averted through more aggressive risk-reduction therapy for those individuals shifted into the high-risk category. For example, based on NCEP/ATP III recommendations, a 10-year CHD risk >20% in an asymptomatic person is considered to be a CHD-equivalent.2 These individuals may benefit from more aggressive treatment with statin drugs to lower LDL. Based on recent trial data, we assumed the efficacy of aggressive risk-reduction therapy for high-risk individuals to be a 30% in the 10-year risk for future hard CHD.3

We also assumed 100% patient adherence with aggressive risk-reduction therapy. We believe this is optimistic, however. For example, a study of statin usage in a usual-care setting, based on review of an health maintenance organization’s (HMO) electronic pharmacy dispensing records, found adherence with statin prescriptions based on refills to be 80% at 6 months, and 74%, 65%, and 61% at 1, 2, and 3 years, respectively.32 We also assumed that treatment would have no adverse effects. Altogether, we chose these assumptions to provide a best-case scenario for the potential benefits of CRP testing.

Our model did not consider individuals who were already in the high-risk category, assuming these individuals would already be treated according to ATP III recommendations. Based on recommendations of the NCEP/ATP III panel, asymptomatic persons with a 10-year CHD risk >20% based on multiple risk factors are at similar risk for CHD events as those with established CHD. Such individuals can be classified as having a CHD risk equivalent that already indicates the need for more intensive risk-reduction therapy.2 Although adjusting for CRP-associated risk in some for those with low hsCRP measurements will reclassify some of these individuals from the high-risk to the intermediate-risk category, we are not aware of data that would support less aggressive risk-reduction therapy in these individuals. We also did not model outcomes for individuals reclassified from the intermediate-risk category to the low-risk (<10% 10-year CHD risk) category. Such patients may already be treated with blood pressure lowering medication, or following life-style recommendations to modify CHD risk factors, that would be appropriate to continue in any case.

To estimate the impact of using hsCRP measurement in intermediate-risk individuals, we used data collected in the NHANES from 1999 through 2002. NHANES 1999–2002 used a multistage, stratified sampling design to ensure that the participants were a representative sample of the US population. Full details of the NHANES study design and the datasets used are available online.33

We extracted information from the NHANES 1999–2002 data for men and women age 40 to 79 years with no history of CHD or CHD equivalents (history of angina, stroke, congestive heart failure, diabetes). We selected men and women 40 to 79 years old as the age most relevant to primary CHD prevention efforts. Those selected also had to have complete information the traditional Framingham risk factors needed to calculate 10-year CHD risk using the NCEP/ATP-III risk 10-year CHD risk prediction tool.34 These included age, sex, total cholesterol, HDL, systolic blood pressure, current smoking status, and whether the participant was currently taking medication for hypertension. Complete data on hsCRP measurements were also available for those participants selected for our study.

To predict the additional 10-year risk associated with CRP elevation, we modified the ATP-III risk equation by incorporating the OR from our meta-analysis of published studies. In our meta-analysis of good quality studies that adjusted for all Framingham risk factors, the combined risk ratio for men was 1.27 (95% CI, 0.99, 1.63) for hsCRP 1.0–3.0 mg/L compared to hsCRP < 1.0 mg/L, and 1.59 (95% CI, 1.06, 2.40) for hsCRP >3.0 mg/L compared to hsCRP < 1.0 mg/L. For women, the combined risk ratio was 1.24 (95% CI, 1.01, 1.52) for hsCRP 1.0–3.0 mg/L compared to hsCRP < 1.0mg/L, and 1.81 (95% CI, 1.42, 2.31) for hsCRP >3.0 mg/L compared to hsCRP < 1.0mg/L. We used these risk ratios for hsCRP to modify the estimated 10-year risk for first incident CHD events for each individual in the NHANES dataset, resulting in a revised set of estimates of 10-year CHD risk. The 10-year risk was modified for each sex separately.

Since these risk ratios are combined estimates based on odds ratios and hazard ratios, we considered two different approaches to modify the 10-year risk. We denote the estimated 10-year risk for first hard CHD events from step 1 as P _FH_ , and the modified 10-year risk as P _FH+hsCRP_ . First, we assumed that the relationship between P _FH_ and P _FH+hsCRP_ could be expressed by a logit equation:

First, the authors assumed that the relationship between PFH and PFH+hsCRP could be expressed by a logit equation. The left side of the equation is the logit of the modified 10-year risk. The right side of the equation is the sum of three terms. The first term is the logit of Framingham 10-year risk. The second and third term is β1 times hsCRP1 and β2 times hsCRP2, respectively. In this equation hsCRP1 and hsCRP2 are two dummy variables with a value of 1 and 0, respectively. log ( (p_F H + h s C R P_)/(1 - p_F H + h s C R P_) ) = log ( (p_F H_)/(1 - p_F H_) ) + β_1_^*^ h s C R P_1_ + β_2_^*^ h s C R P_2_ 1

where hsCRP_1_ and hsCRP_2_ are two dummy variables with value 1 and 0. When hsCRP_1_ = 1, it means the individual was categorized into group hsCRP 1.0–3.0 mg/L, and hsCRP_1_ = 0 means otherwise. Similarly hsCRP_2_ = 1 means the individual has a hsCRP level >3.0 mg/L and hsCRP_2_ = 0 means otherwise. Coefficients β_1_ and β_2_ were calculated based on the combined estimates of risk ratios from meta-analysis. For men, β_1_ = log(1.27) = 0.24, β_2_ = log(1.59) = 0.46; for women, β_1_ = log(1.24) = 0.22, β_2_ = log(1.81) = 0.59. For those individuals with CRP of 1.0–3.0 mg/L or >3.0 mg/L, the modified 10-year risk was calculated based on (1).

To calculate the 10-year risk of those individuals with CRP < 1.0 mg/L, we made an additional assumption that total number of sex-specific incident hard CHD events predicted for 10 years based on Framingham risk factors would remain constant after adjusting for risk associated with hsCRP; in other words, applying hsCRP did not alter the overall risk of CHD events, but only redistributed the existing risk. Therefore, for those individuals with CRP < 1.0 mg/L, the modified 10-year risk was calculated as follows:

For those individuals with C-reactive protein levels less than 1.0 mg/L, the modified 10-year risk was calculated using the relationship that the logit of the modified 10-year risk equals the logit of Framingham 10-year risk plus β0. log ( (p_F H + h s C R P_)/(1 - p_F H + h s C R P_) ) = log ( (p_F H_)/(1 - p_F H_) ) + β_0_ 2

where β_\0_ is estimated for each sex based on the assumption that total number of predicted 10-year events remains constant after adjusting for hsCRP. An alternative approach is to treat the combined estimates of risk ratios as hazard ratios and obtain the modified 10-year risk based on a Cox regression model. NCEP/ATP III equation is aformula to calculate cumulative risk based on Cox regression. Adding hsCRP terms to NCEP/ATP III equation, we have

Adding hsCRP terms to the NCEP/ATP III equation, the authors obtained the modified 10-year risk for first hard CHD event as 1 minus the modified probability of not having the first hard CHD event in 10 years. The modified probability of not having the first hard CHD event is calculated as a function of the baseline 10-year risk, Framingham risk factors in the NCEP/ATP III risk equation, and two dummy variables for C-reactive protein categories. p_F H + h s C R P_ = 1 - s_0_ ( t )^exp ( x β_F H_ + β_1_^*^ h s C R P_1_ + β_2_^*^ h s C R P_2_ )^ 3

where vector β _FH_ represents coefficients for Framingham risk factors in NCEP/ATP III risk equation, x is a vector to represent the collection of Framingham risk factors, and s _0_ (t) is the baseline 10-year risk. For hsCRP_1_ and hsCRP_2_, they have the same meaning as in (1) and coefficients β_1_ and β_2_ have same values as in (1). To calculate the modified 10-year risk of those individuals with CRP < 1.0 mg/L based on Cox regression, we used

The authors obtained the modified 10-year risk for those individuals with C-reactive protein levels less than < 1.0 mg/L as 1 minus the modified probability of not having the first hard CHD event in 10 years. For those individuals the modified probability of not having the first hard CHD event was calculated as a function of the baseline 10-year risk, Framingham risk factors in the NCEP/ATP III risk equation, and β0, where β0 is estimated for each sex based on the assumption that the total number of predicted 10-year events remains constant after adjusting for hsCRP. p_F H + h s C R P_ = 1 - s_0_ ( t )^exp ( x β_F H_ + β_0_ )^ . 4

Again β_\0_ is estimated for each sex based on the assumption that total number of predicted 10-year events remains constant after adjusting for hsCRP.

The approach of using logit equation ((1) and (2)) could be considered as directly adjusting the 10-year ATP III risk using hsCRP, and equations (3) and (4) could be considered as recalculating the 10-year risk by adding information from hsCRP. For both approaches, we assumed that adding hsCRP does not affect the coefficients of Framingham risk factors in NCEP/ATP III equation thus our estimates on the modified 10-year risk are likely to be an upper bound in terms of magnitude of the effects of hsCRP. The two approaches yield similar results and for simplicity, we only presented results from first approach using logit equation.

We then used the revised estimates of individuals’ 10-year risk for incident hard CHD events (after adjustment for hsCRP) to examine the potential impact of using hsCRP on CHD risk prediction. The 10-year risk for CHD events and number of expected CHD events, before adjustment for CRP, were calculated using the NCEP/ATP III risk prediction equation based on Framingham risk factors. We calculated the 10-year risk for CHD events and the number of expected CHD events after adjustment for CRP using the modified risk prediction equation incorporating CRP-associated risk estimates from the meta-analysis.

The clinical endpoint used in the model was the number of CHD events averted over 10 years. To calculate the impact of testing intermediate-risk individuals on incident coronary events, we assumed that individuals reclassified from the intermediate-risk to high-risk category after adjusting for CRP-associated risk would receive aggressive risk-reduction, with an additional net efficacy, taking compliance into account, of 30% in reducing the risk of future CHD events compared with the therapy they would have received if classified as intermediate-risk patients.

### Statistical analysis

Analysis of logit equation approach was performed by using the Microsoft Excel Solver utility (Microsoft, Inc, Redmond, WA)., and the alternative approach using Cox regression was conducted by using SAS 9.1 (SAS institute Inc., Cary, NC, USA). When calculating population means for Framingham risk factors, CRP, predicted 10-year risk and population proportions for each risk group (low, intermediate or high), we used the combined 1999 to 2002 4-year final examination weights from NHANES data. Calculations of standard errors and 95% confidence intervals (CI) incorporated stratification and sampling unit data from the NHANES datasets to account for the complex sampling design used in the study. Population estimates were age-adjusted by the direct method using population age-distribution estimates for the year 2000.^35^ All data analyses were performed using the JK-1 jackknife replication procedure in WESVAR® 4.2 statistical software (Westvar, Rockville, MD). To check the reliability of our analyses, we also analyzed the population distributions for Framingham risk factors and demographic variables (Table 1 and Table 2), and population distributions of CHD risk before and after adjusting for CRP (Table 3) using the Taylor series linearization method in SUDAAN Version 8 software (RTI, Research Triangle Park, NC) and found nearly identical results.

Table 3

Cohorts in which CHD Novel Risk Factors Were Studied

Cohort^*,†^ | # RFs | CIMT | CRP | EBCT | FG | Hcy | Lp(a) | PD | WBC
Adult Health Study, a subset of 100,000 residents in Hiroshima or Nagasaki as of 1950 | 1 | | | | | | | | ÷
Atherosclerosis Risk in Communities (ARIC) | 6 | + | + | | ∅ | ÷ | + | | ÷
British Regional Heart Study (BRHS) | 3 | | + | | | ÷ | | | +
British United Provident Association (BUPA) | 1 | | | | | +
British Women’s Heart and Health Study | 1 | | ÷
Bruneck Study | 1 | | | | | | ÷
Caerphilly Study and Speedwell Study | 4 | | ∅÷ | | ∅ | ÷ | | | +
California, USA (Wong, 2000^92^) | 1 | | | +
Camerano study group | 1 | | | | ∅
Cardiovascular Health Study | 1 | +
Chicago, IL, USA (Kondos, 2003^94^) | 1 | | | +
Dallas, TX, USA (LaMonte, 2005^97^) | 1 | | | +
Dental longitudinal study, VA | 1 | | | | | | | +
East and West Finland Study | 1 | | | | ∅
Edinburgh Artery Study | 1 | | | | | | ∅
FINRISK ’92 Hemostasis Study | 1 | | | | | | ∅
Framingham/Framingham Offspring Study | 5 | | ÷ | | + | + | + | | ÷
France (Blacher, 2002^116^) | 1 | | | | | +
Goteburg, Sweden (Ohlson, 1986^57^) | 1 | | | | ∅
Gothenburg, Sweden (Zylberstein, 2004^141^; Rosengren, 1990^162^) | 2 | | | | | + | +
Gottingen Risk Incidence and Prevalence Study (GRIPS) | 1 | | | | | | +
Health Professionals Follow-up Study (HPFS) | 3 | | + | | | | ∅ | +
Helsinki Aging Study | 1 | | | | | | | +
Helsinki Heart Study | 2 | | | | | | ÷ | | ÷
Helsinki Policemen Study | 1 | | | | ∅
Hoorn | 1 | | | | | +
Hordaland Homocysteine Study | 1 | | | | | +
Italy (Belcaro, 1996^83^) | 1 | +
Kaiser Permanente | 1 | | ÷
Kuopio Ischemic Heart Disease Risk Factor Study | 2 | + | | | | ∅
Lipid Research Clinics Coronary Primary Prevention Trial | 1 | | | | | | +
Malmo, Sweden (Lind, 2003^126^) | 1 | | | | | ÷
Mini Finland Health Survey | 1 | | | | | | | ∅
Mobile Clinic Health Exam Survey, Finland | 1 | | | | | ∅
Monitoring of trends and determinants in cardiovascular disease study (MONICA) | 4 | | + | | ∅ | ÷ | +
Monitoring Project on CVD Risk Factors | 1 | | | | | ∅
Multiple risk factor intervention trial (MRFIT) | 4 | | ÷ | | | ∅ | ∅ | | ÷
Nashville, TN, USA (Raggi, 2001^29^) | 1 | | | +
NHANES I | 2 | | | | | | | + | ∅
North Karelia Project | 1 | | | | | ∅
Northern Manhattan Study | 1 | | | | | ÷
Nurses’ Health Study (NHS) | 3 | | ÷ | | | + | | + ‡
Nutrition Canada Study | 1 | | | | | | | ÷
Olmsted County, MN, USA (Nguyen, 1997^173^) | 1 | | | | | | +
Paris Prospective Study I and II | 1 | | | | | | | | ÷
Physicians Health Study (PHS) | 4 | | + | | | + | ∅ | ∅
Prospective Army Coronary Calcium Project | 1 | | | +
Prospective Cardiovascular Munster Study (PROCAM) | 1 | | | | | | +
Prospective Epidemiological Study of Myocardial Infarction (PRIME) | 2 | | + | | | | ÷
Quebec Cardiovascular Study | 2 | | ∅ | | | | ÷
Reykjavik Study | 1 | | +
Rotterdam Study | 4 | + | ÷ | + | | ÷
Second Northwick Park Heart Study | 1 | | | | | | +
South Bay Heart Watch | 2 | | ÷ | +
St. Francis Heart Study – population 1 | 1 | | | +
St. Francis Heart Study – population 2 | 1 | | | +
Stanford Five-City Project | 1 | | | | | | ÷
Tromso Health Study | 1 | | | | | +
Vantaa Study | 1 | | | | ∅
Vasterbotten Intervention Program (VIP) | 2 | | | | | ÷ | +
Women’s Health Initiative Observational Study (WHI-OS) | 1 | | +
Women’s Health Study (WHS) | 3 | | + | | | ÷ | +
Worksite Hypertension Program | 1 | | | | ÷
Zutphen Study (Dutch portion of 7 Countries Study) | 2 | | | | | ÷ | | | ÷

# RFs=number of emerging risk factors per cohort among publications that met inclusion criteria.

Note: No studies of ankle-brachial index (ABI) met the inclusion criteria.

* Some cohorts contained sub-cohorts by gender or region.

† Please see evidence tables for references, as they vary per risk factor

‡ Combined with Health Professional Follow-up Study cohort.

“+” indicates that the risk factor was significantly predictive of CHD.

“÷” indicates a positive association that was not statistically significant.

“∅” indicates a null finding.

Abbreviations: CIMT=carotid intima media thickness, CRP=C-reactive protein, EBCT=electron beam computed tomography, Hcy=homocysteine, FG=fasting glucose, Lp(a)=lipoprotein(a), PD=periodontal disease, WBC=white blood cell count.