# 1 Introduction

In the United States, coronary heart disease (CHD) and cardiovascular disease (CVD) account for nearly 40% of all deaths each year.1 Several risk factors for CHD and CVD, such as tobacco use, elevated low-density lipoprotein cholesterol (LDL-C), hypertension, hypercoagulable states, and obesity, are modifiable. Identifying individuals at risk, encouraging therapeutic lifestyle changes, and, when appropriate, initiating drug treatment to reduce LDL-C, are highly effective measures to reduce an individual’s risk of coronary events and stroke.

An individual’s risk for CHD events (or sometimes CVD events) guides the intensity of LDL-C lowering and other interventions. For this reason, assessing an individual’s risk plays an important role in initiating measures to modify risk. Several risk stratification systems are available for this purpose. The Adult Treatment Panel III (ATP III) of the National Cholesterol Education Program (NCEP) algorithm, which is the most widely used system, categorizes individuals into 3 risk categories (see Table 1).2, 3 This system uses the Framingham risk scoring system to stratify individuals who do not have established CHD, diabetes, or noncardiac vascular disease.

Table 1

ATP-III Risk Categories

- Established CHD and CHD equivalents. Any of the following:; - - established CHD; - - diabetes; - - established noncardiac vascular disease—peripheral arterial disease, abdominal aortic aneurysm, carotid artery disease (symptomatic, e.g., transient ischemic attack or stroke of carotid origin, or >50 percent stenosis on angiography or ultrasound); - - a 10-year risk of CHD events ≥20% using Framingham scoring; - Multiple (2+) risk factors that modify LDL goals (cigarette smoking, hypertension, HDL <40 mg/dL, family history of premature CHD, age ≥45 in men, ≥55 in women); - 0–1 Risk Factors

The sex-specific Framingham risk functions predict an individual’s 10-year risk of risk of developing “hard CHD events,” that is, the combined risk of myocardial infarction (MI) or death from coronary disease.4 The functions were derived from 2439 white men and 2812 white women, 30 to 74 years of age, in either the original Framingham cohort or the Framingham Offspring Study.

When used with the ATP III algorithm, the sex-specific Framingham risk functions takes into account age, blood pressure, the serum total cholesterol level, the high-density lipoprotein cholesterol (HDL-C) level, and cigarette smoking. Otherwise, the Framingham risk score includes these factors plus diabetes. The Framingham score does not take into account family history, obesity, triglycerides, small LDL particles, lipoprotein(a) (Lp[a]), coagulation factors, homocysteine, or the metabolic syndrome. Of these excluded factors, the best-established is a family history of coronary disease in first-degree relatives, which was a relatively strong, independent predictor of CHD events in the Framingham Offspring Study.5 The metabolic syndrome is a common constellation of findings associated with a higher risk of developing diabetes. It may also be an independent predictor of stroke.6

The Framingham risk functions also do not take race or ethnicity into account, but have been validated in many populations. The risk functions perform well in black men and women,7 but overestimate the risk of CHD events in Japanese-American and Hispanic men, Native American women, and in Chinese men and women.8

Framingham risk factors account for most of the excess risk for CHD morbidity and mortality among individuals who have not had a previous cardiovascular event or diagnosis.4, 9 However, 10–20% of individuals with CHD have no identified risk factors and miss the opportunity for primary prevention.10, 11 Approximately 40% of CHD deaths occur in patients with cholesterol levels lower than the population average.10

The potential impact of new risk factors is greatest for individuals who are classified as intermediate-risk using the Framingham risk functions. In an analysis of National Health and Nutrition Examination Survey (NHANES) data, men older than age 45 years who had two elevated risk factors or one elevated risk factor and four or more borderline risk factors, and women older than age 55 years who had at least three elevated risk factors, were most likely to be classified as intermediate-risk.12

Epidemiologists and biologists have tried to identify new risk factors, particularly modifiable risk factors that could explain some of the variability in CHD risk that is not explained by traditional risk factors. Over 100 potential risk factors have been proposed.13 Many of these candidates have been evaluated in epidemiologic studies, and some are now widely used in primary care practice. Two broad classes of factors—inflammatory markers and markers of atherosclerotic burden—have received the most attention.

An American Heart Association (AHA) conference, Prevention Conference V, held in 1998, assessed inflammatory markers as well as markers of atherosclerotic burden. The conferees examined several potential clinical uses for inflammatory markers, two of which are relevant to primary prevention: (1) prediction of a first cardiovascular event in all individuals who do not have known CVD (that is, primary prevention), and (2) “to augment risk assessment in the identification of persons who should be considered for lipid-lowering, antiplatelet, or other cardioprotective drug therapies.” With respect to the latter, the conferees posed the question of whether individuals who have an elevated baseline risk based on their Framingham risk score could benefit by further stratification using a novel risk factor. The potential effect of further stratification might include reclassifying some individuals as lower risk and others as high-risk, permitting more aggressive treatment and encouragement of lifestyle changes toward the latter group.

## Inflammatory Markers

Several lines of evidence have implicated chronic inflammation in the etiology of CHD.14 With respect to inflammatory markers, the Prevention Conference V concluded that

“…many of these markers (including inflammatory markers) are not yet considered applicable for routine risk assessment because of: (1) lack of measurement standardization, (2) lack of consistency in epidemiological findings from prospective studies with endpoints, and (3) lack of evidence that the novel marker adds to risk prediction over and above that already achievable through the use of established risk factors.”15

In 2002, the Centers for Disease Control and Prevention (CDC) and the AHA co-sponsored a conference and workshop on several laboratory-based inflammatory markers: adhesion molecules, cytokines, fibrinogen, high-sensitivity C-reactive protein (hsCRP), serum, amyloid A, and the white blood cell (WBC) count.16 The workshop participants concluded that, of the tests studied, the hsCRP test had the most desirable characteristics. Assays for some markers, such as cytokines, were not sufficiently standardized for clinical use, and other markers that had reliable, commercially available assays, such as the WBC count, were not as predictive or had not been demonstrated to be an independent predictor of CVD events. The conference recommended that, when hsCRP is used, it should be “measured twice, either fasting or nonfasting, with the average expressed in mg/L, in metabolically stable patients,” and that results should be categorized as low, average, or high corresponding to approximate tertiles of values (<1.0, 1.0 to 3.0, and >3.0 mg/L, respectively.)

The workshop participants recommended against routine use of hsCRP in conjunction with risk assessment for all primary prevention individuals, but supported measurement of hsCRP in individuals who had a 10-year CHD risk in the range of 10% to 20%. They noted, however, that the benefits of this strategy “remain uncertain,” and recommended that randomized trials should be performed “to test whether risk categorization by hsCRP leads to: (1) therapeutic risk reductions in additional patients who are not currently identified, or (2) a reduction in the number of patients in need of treatment by identifying low-risk groups that heretofore had been recommended for further diagnostic testing or aggressive interventions.”

## Markers of Atherosclerotic Burden

With respect to markers of atherosclerotic burden, Prevention Conference V endorsed the selective, physician-directed use of electron beam computed tomography (EBCT) scan for risk prediction in some intermediate-risk patients for whom the results might be useful in reclassifying the patient as high-risk17 as did an American College of Cardiology (ACC)/AHA conference.18

ATP-III, which was also published in 2002, evaluated a broader range of emerging risk factors.19 ATP-III used the following criteria to assess the potential benefit of each factor:

- Significant predictive power that is independent of the other major risk factors
- A relatively high prevalence in the target population (justifying routine measurement in risk assessment)
- Laboratory or clinical measurement must be widely available, well standardized, inexpensive, have accepted population-reference values, and be relatively stable biologically
- Preferably, but not necessarily, modification of the risk factor in clinical trials will have shown reduction in risk.

ATP-III examined several lipid-related potential risk factors (triglycerides, lipoprotein remnants, lipoprotein (a), small LDL particles, HDL subspecies, apolipoproteins, total cholesterol/HDL ratio) and the following nonlipid factors: homocysteine; fibrinogen and other prothrombotic factors; hsCRP; impaired fasting glucose; ankle-brachial index; exercise electrocardiogram testing; cardiac sonography to measure carotid intima-media thickening (IMT); and EBCT, spiral computed tomography, and other imaging tests for coronary calcification. In general, ATP-III endorsed the findings of Prevention Conference V and the ACC/AHA conferences. ATP III concluded that homocysteine, hsCRP, carotid IMT, and EBCT can be useful in certain circumstances, but did not recommend incorporating any emerging risk factors into risk assessment in all individuals in primary prevention risk assessment. ATP III also found that measurement of fasting glucose, waist circumference, and triglycerides are useful in the context of diagnosing the metabolic syndrome.

The 2004 update to ATP III lists the presence of a hsCRP>3 mg/L or coronary calcification>75^th^ percentile for a person’s age and sex among several factors that favor use of an LDL-lowering agent in persons who have a 10-year risk of 10% to 20% and LDL-C level of 100 to 129 mg/dL.3

## Scope and Key Questions

We conducted a systematic review of epidemiologic studies of certain emerging risk factors (Table 2) to help the US Preventive Services Task Force (USPSTF) determine which, if any, factors should be incorporated into guidelines for coronary and cardiovascular risk assessment in primary care. The USPSTF selected all but one of the risk factors examined in this report. After a preliminary literature review, the authors of the report added one factor, periodontal disease.

Table 2

Emerging Risk Factors

Risk factors addressed in this report:
Ankle-brachial index
C-reactive protein
Carotid intima media thickness
Electron beam computed tomography
Fasting glucose
Homocysteine
Lipoprotein(a)
Periodontal disease
White blood cell count
Some potential risk factors not addressed in this report:
Angiotensin-converting enzyme genotype
ApoE genotype
Apolipoproteins A1 and B
Cystatin C
D-dimer
Electrocardiogram findings
Exercise treadmill testing
Factors V, VII, and VIII
Fibrinogen
Fibrinopeptide A
Heart rate
High-density lipoprotein subtypes
Infectious agents: Cytomegalovirus, Chlamydia pneumonia, Helicobacter pylori, Herpes viruses
Insulin resistance
Interleukins (e.g., IL-6)
Lipoprotein-associated phospholipase A(2)
Metabolic syndrome
Microalbuminuria
Oxidized LDL
PAI-1 genotype
Physical inactivity
Plasminogen activator inhibitor 1 (PAI-1)
Platelet activity
Platelet aggregation
Platelet size and volume
Prothrombin fragment 1 + 2
Pulse pressure
Remnant lipoproteins
Serum amyloid A
Soluble CD40 ligand
Tissue-plasminogen activator
Vascular and cellular adhesion molecules
von Willebrand factor antigen
Waist-to-hip ratio

The analytic framework for this report is depicted in Figure 1. The population of interest for this review consists of asymptomatic adults who are identified as being “intermediate risk” after calculating the Framingham risk score. This target population excludes individuals with diabetes, coronary disease, peripheral vascular disease, and other individuals who have a predicted 10-year risk of “hard” coronary artery disease (CAD) events greater than 20%. Figure 1 shows that, after testing with one of the “emerging” risk factors, some intermediate-risk individuals are reclassified as “high-risk” (>20% risk of hard CAD events over 10 years) or “low-risk” (<10% risk over 10 years.) As a result of reclassification to high-risk, these individuals would be managed with more aggressive risk factor modification which could result in an improved risk profile and in greater reductions in the incidence of CAD than they would be expected to have if they were managed as intermediate-risk patients.

Figure 1

Analytic Framework and Key Questions

Key Questions

1. Compared with Framingham risk factors alone, does risk stratification of asymptomatic adults using novel risk markers lead to reduced incidence of cardiovascular events (myocardial infarction, angina, sudden death, cerebrovascular accident), coronary heart disease events, or overall mortality?

2. What novel risk markers accurately predict cardiovascular events independent of Framingham risk factors? What is the added predictive value of novel risk markers?

a) What is the prevalence of these risk markers among intermediate-risk and low-risk individuals?

b) At what frequency does application of these novel risk markers significantly change the 10 year risk of cardiovascular events based on traditional risk factors alone? (e.g., from intermediate risk [10–20%] to high risk [>20%] or to low risk [<10%])

3. What are the harms of risk assessment?

4. a) In groups identified as high-risk (>20% 10-year risk) by novel risk markers, does aggressive risk factor modification (treatment to lower blood pressure and lipid targets or more intense counseling) lead to improved intermediate outcomes (e.g., reduction in lipid levels; reduction in blood pressure; increased physical activity; healthy dietary changes etc)?

b) Does improvement in intermediate outcomes lead to reduced incidence of cardiovascular events (myocardial infarction, angina, sudden death, cerebrovascular accident), cardiovascular disease-specific mortality, overall mortality?

5. What are the harms of aggressive risk factor modification?

6. What are the costs associated with risk factor assessment and aggressive risk factor modification?

This figure depicts the analytic framework for risk assessment of coronary heart disease using nontraditional risk factors. The diagram starts on the left with text that reads “Asymptomatic adults.” An arrow then leads to the right and forks at the midpoint. At the midpoint a vertical line leads up to “Risk assessment using APT-III version of Framingham score.” The arrow continues to the right to “Intermediate risk category,” whereupon it branches to arrow 2 and arrow 3. The statement, “Emerging Risk Factor Assessment,” appears above the branching of arrows 2 and 3. Arrow 1, which proceeds upward from this statement and then to the right, represents KQ1: “Compared with Framingham risk factors alone, does risk stratification of asymptomatic adults using novel risk markers lead to reduced incidence of cardiovascular events (myocardial infarction, angina, sudden death, cerebrovascular accident), coronary heart disease events, or overall mortality?” Appended to “Emerging Risk Factor Assessment” is a footnote explaining the emerging risk factors addressed in this report: ankle-brachial pressure index; white blood cell count; fasting glucose, periodontal disease, carotid intimal thickness, electron beam CT, homocysteine, lipoprotein(a), and C-reactive protein. Arrow 1 goes directly to the end of the diagram on the far right. Arrow 3 represents Key Question (KQ) 3: “What are the harms of risk assessment?” Arrow 3 curves down and ends at an oval reading “Adverse effects.” Arrow 2 represents KQ2: “What novel risk markers accurately predict cardiovascular events independent of Framingham risk factors? What is the added predictive value of novel risk markers? a) What is the prevalence of these risk markers among intermediate-risk and low-risk individuals? and b) At what frequency does application of these novel risk markers significantly change the 10-year risk of cardiovascular events based on traditional risk factors alone (e.g., from intermediate risk [10-20%] to high risk [>20%] or to low risk [<10%])?” Above Arrow 2 appears “Emerging risk factor assessment.” Arrow 2 then forks in four directions. The second fork goes to a box labeled “Reclassify as low risk.” The third fork goes to a box labeled “Remain intermediate risk.” The third fork goes to a box labeled “Reclassify as high risk,” and the text is in bold. From there, the arrow continues to “Aggressive risk factor modification,” also in bold. Here there is a footnote explaining that risk factor modification includes lipid-lowering therapy, exercise counseling, and other measures as recommended by NCEP. The arrow then branches in three directions. The first direction is Arrow 4b, which represents KQ4b: “Does improvement in intermediate outcomes lead to reduced incidence of cardiovascular events (myocardial infarction, angina, sudden death, cerebrovascular accident), cardiovascular disease-specific mortality, or overall mortality?” Arrow 4b goes directly to the end of the diagram on the far right. The second direction is Arrow 5, representing KQ5: “What are the harms of aggressive risk factor modification?” Arrow 5 curves down and ends at an oval reading “Adverse effects.” The third direction is Arrow 4a, which represents KQ4a: “In groups identified as high-risk (>20% 10-year risk) by novel risk markers, does aggressive risk factor modification (treatment to lower blood pressure and lipid targets or more intense counseling) lead to improved intermediate outcomes (e.g., reduction in lipid levels; reduction in blood pressure; increased physical activity; healthy dietary changes, etc.)?” Arrow 4a continues to a box labeled “Reduced risk profile (lower LDL, higher HDL, more active, better diet, weight loss if overweight, lower HgbA1c).” From there, the arrow proceeds via a dotted line to the last box of the diagram, labeled “Reduced incidence of coronary events,” and the text is in bold.

The USPSTF selected the following Key Questions for this report (Figure 1):

1. Compared with Framingham risk factors alone, does risk stratification of asymptomatic adults using novel risk markers (Table 2) lead to reduced incidence of cardiovascular events (myocardial infarction, angina, sudden death, cerebrovascular accident), coronary heart disease events, or overall mortality?
2. What novel risk markers accurately predict cardiovascular events independent of Framingham risk factors? What is the added predictive value of novel risk markers?
  a. What is the prevalence of these risk markers among intermediate-risk and low-risk individuals?
  b. At what frequency does application of these novel risk markers significantly change the 10-year risk of cardiovascular events based on traditional risk factors alone (e.g., from intermediate risk [10–20%] to high risk [>20%] or to low risk [<10%])?
3. What are the harms of risk assessment?
4. a. In groups identified as high-risk (>20% 10-year risk) by novel risk markers, does aggressive risk factor modification (treatment to lower blood pressure and lipid targets or more intense counseling) lead to improved intermediate outcomes (e.g., reduction in lipid levels; reduction in blood pressure; increased physical activity; healthy dietary changes, etc.)?
  b. Does improvement in intermediate outcomes lead to reduced incidence of cardiovascular events (myocardial infarction, angina, sudden death, cerebrovascular accident), cardiovascular disease-specific mortality, overall mortality?
5. What are the harms of aggressive risk factor modification?
6. What are the costs associated with risk factor assessment and aggressive risk factor modification?

The key questions reflect the USPSTF’s goal of comparing the strength of evidence and the magnitude of effect of the emerging risk factors. No previous USPSTF decision has called for a similar comparison of a large number of alternatives, and none have focused primarily on refining an existing risk assessment tool. For this reason, the methods section describes in detail our approach to comparing the quality of evidence and magnitude of potential effect for the candidate risk factors.