# 4 Discussion

## Future Research Recommendations

Table 9 summarizes future research recommendations from this review.

Table 9

Summary of Future Research Recommendations

Risk factor | Research recommendations
Ankle-brachial index | None.
Carotid intima media thickness | Epidemiologic cohorts that have measured carotid IMT should measure the impact of carotid IMT on prediction of CHD events among intermediate-risk individuals and on reclassification of these individuals. It is highly plausible that intervention directed toward modification of traditional risk factors in individuals with increased carotid IMT might reduce the risk of subsequent CHD. Randomized controlled trials are needed to evaluate this hypothesis.
C-reactive protein | Trials of aggressive risk factor modification in asymptomatic patients who have elevated CRP levels are underway. Additional information from cohort studies in racial and ethnic minority populations is needed.
Electron beam computed tomography | Better studies of the accuracy of different protocols for EBCT scanning and methods for CAC scoring are needed. A broader range of cohort studies are needed to define the prevalence and impact of CAC scoring by EBCT in the general population. Clinical trials of aggressive versus less aggressive risk factor modification for individuals who have high CAC scores are unlikely to be acceptable ethically. For this reason, trials should compare a comprehensive risk assessment and follow-up strategies that do and don’t include EBCT testing.
Fasting glucose | None.
Homocysteine | Although homocysteine is well-studied, most research to date has focused on whether elevated homocysteine is a causal factor, rather than simply a marker of elevated CHD risk. Epidemiologic cohorts could measure the impact of elevated homocysteine levels on prediction of CHD events among intermediate-risk individuals and on reclassification of these individuals.
Lipoprotein(a) | Additional epidemiologic research is needed in racial and ethnic minority groups. Additional development of reliable, stable assays is needed before clinical applications are practical.
Periodontal disease | The weight of currently existing evidence suggests that there may be an important link between periodontal disease and CHD. Additional longitudinal studies with standardized measures of periodontal disease and careful adjustment for socioeconomic status as well as for traditional CHD risk factors would be useful. To definitively link CHD and periodontal disease etiologically will require randomized controlled trials in which individuals are randomized to treatment versus no treatment of periodontal disease and followed carefully for CHD outcomes. However, a short-term trial may not definitively answer the etiologic question as it is highly plausible that long term exposure to periodontal disease might be more predictive of subsequent CHD. Thus, the best intervention trial would be one that began in early childhood rather than adult life.
White blood cell count | None.

Abbreviations: CAC=coronary artery calcification, CHD=coronary heart disease, CRP=c-reactive protein, EBCT=electron beam computed tomography, IMT=intima media thickness.