# Appendix IV Search and Selection of Literature

Evidence Table 1

White Blood Cell Count as a Risk Factor for Coronary Heart Disease

Author, year | Parent study | N enrolled | N incident cases | % Male | N cases in full model | Duration of follow- up | Age range or mean | Excluded baseline CHD | Excluded baseline DM | Framingham RFs: age, BP, TC or LDL, DM, Gender, HDL, Smoking | Additional Non-FRFs in analysis | Type of categorization | RR (95%CI) | | | Quality rating
Cohort studies
Folsom, 1997^42^ | ARIC | 14,477 | 348 | 43.50% | 289 | 5 years | 45–64 | Yes | No | Age, BP, TC or LDL, DM, gender, HDL, smoking | ARIC field center, use of antihypertensives, waist- to-hip ratio, and sport index. | Categorized, x1000/mm3: <0.31 5.1–6.5 >6.5 Result compares highest to lowest 3rd | Men: 1.13 (95%CI 0.98–1.31) Women: 1.45 (95%CI 0.86–2.44) | | | Good
Gillum, 1993^43^ Wheeler, 2004^49^ | NHANES I | 6,196 | 1,401 | 47% | 1163 (whites); 238 (blacks) 914 in Wheeler 2004 | Range 6.8 to 16.4 years, median 13.9 years; median 18.3 in Wheeler 2004 | Gillum 1993: 25–74; Wheeler 2004: mean 48.1 | Yes | No | Age, BP, TC or LDL, DM, gender, smoking Not for HDL | Pulse rate, hemoglobin concentration, BMI, education | Categorized, x1000/mm3: <6.6 6.6–8.1 >8.1 | (Whites only) Men: RR (95%CI) <6.6 1.00 (reference) 6.6–8.1 0.94 (0.76–1.15) >8.1 1.31 (1.07–1.61) Women: <6.6 1.00 (reference) 6.6–8.1 1.26 (1.03–1.55) >8.1 1.31 (1.05–1.63) Wheeler, 2004: lowest 3rd: 1.00 (reference) middle 3rd: 1.07 (0.92–1.26) highest 3rd: 1.01 (0.85–1.20) | | | Fair
Kannel, 1992^44^ | Framingham Offspring Study | 2,794 | 197 | 49.90% | NR | 12 years | 30–59 | Yes | No | Age, gender, smoking Not for BP, TC/LDL, HDL, or DM | NR | Dichotomized; Compares <=6.0 to >6.0 ×1000/mm3 | Nonsmokers: Smokers: | Men 2.1 (p<0.01) 1.3 (p=ns) | Women 1.2 (p=ns) 1.6 | Poor
Olivares, 1993^39^ | Paris Prospective Study II | 2,856 | 24 major events | 100% | 2782 | 5.5 years | Per cohort: 42.1, 44.3 | Yes | No | Age, smoking status, gender; did not adjust for TC, HDL, BP, or diabetes. | NR | Continuous per 1,000 cells/mm3 | RR for total WBC in 1,000 cells/mm3: 1.04 (95%CI 0.95–1.14), p-value = 0.40 | | | Poor
Phillips, 1992^45^ | British Regional Heart Study; MRFIT 1 and 2 | 28,181 combined | 1,768 | 100% | 1,768 | 6–12 years, mean per study: BRHS: 8.0 MRFIT 1: 7.0 MRFIT 2: 12.0 | Mean 46–50 | MRFIT1,2: Yes BRHS: No | MRFIT1,2: Yes BRHS: No | MRFIT1,2: age, BP, TC or LDL, DM, gender, smoking Not for HDL BRHS: age, BP, TC or LDL, gender, smoking Not for DM or HDL | NR | Continuous per 2000/mm3 increase | BRHS: 1.32 (1.18, 1.47), p<0.0001 MRFIT 1: 1.15 (1.07, 1.23), p=0.0001 MRFIT 2: 1.14 (1.05, 1.25), p=0.003 | | | Fair
Prentice, 1982^46^ | Adult Health Study, a subset of 100,000 residents in Hiroshima or Nagasaki as of 1950 | 16,290 | 154 | 38% | 62 | 2 years | 74% < 45 | Yes | No | Sex, age, smoking, TC, BP. Not for DM or HDL | NR | Continuous hundred/mm3 | RR 1.54 (p=0.58) adjusted for age, sex, smoking, BP and TC, but the number of cases was limited (N =62). RR adjusted for age, sex, and BP was similar between never smokers & current smokers: 3.00 (p=0.38, ns) v. 2.09 (p=0.4, ns) | | | Fair
Sweetnam, 1997^47^ | Caerphilly and Speedwell Collaborative Heart Disease Studies | 4,615 | 565 | 100% | NR | 9–10 years | 45–63 | No | NR (See Bainton D) | Age, BP, TC or LDL, gender, smoking Not for DM or HDL | Preexistent IHD BMI | Quintiles; result compares highest to lowest quintile | OR = 2.10 (95%CI 1.51–2.92). | | | Fair
Weijenberg, 1996^48^ | Zutphen Study (Dutch portion of 7 Countries Study) | 884 | NR | 100% | NR | 5 years | 64–84 | No | No | Age, BP, TC or LDL, DM, gender, HDL, smoking | BMI, serum albumin, Hct, | Continuous per 1000/mm3 increase | RR 1.14 (95%CI 0.98–1.32) | | | Fair
Zalokar, 1981^40^ | Paris Prospective Study I | 7206 | 104 | 100% | NR | 6.5 years | 43–53 | Yes | No | Adjusted only for gender and smoking in men aged 43–53. Did not adjust for BP, TC/LDL, HDL, DM. | NR | <6000–7799/mm3 >7800/mm3 | Incidence per 1000 person-years (95%CI), by #cigarettes per day/WBC count: 1–9/<6000–7799: 0.8 (0.0–4.6) 1–9/7800+: 0.0 (0.0–16.2) 10–19/<6000–7799: 1.7 (0.5–4.0) 10–19/7800+: 7.6 (3.7–13.5) 20–24/<6000–7799: 4.8 (2.8–7.7) 20–24/7800+: 9.1 (5.3–14.6) 25+/<6000–7799: 3.7 (1.2–8.6) 25+/7800+: 6.1 (2.9–15.1) | | | Poor
Nested case- control studies
Manttari, 1992^50^ | Helsinki Heart Study | 140 cases 280 controls | N/A | 100% | 140 | 5 years | 40–55 | Yes | No | Age, TC or LDL, gender, smoking Not for BP, DM or HDL | Physical activity, alcohol, BMI | Categorized, x1000/mm3: <5.2 5.2–6.7 >6.7 | Nonsmokers: WBC < 5.2: 1.00 (reference) WBC 5.2–6.7: 1.11 (0.54–2.24) WBC > 6.7: 1.86 (0.81–4.28) Smokers: WBC < 5.2: 1.58 (0.64–3.90) WBC 5.2–6.7: 2.62 (1.62–6.70) WBC > 6.7: 3.07 (2.23–8.19) | | | Fair

Abbreviations: ARIC=Atherosclerosis risk in communities, BMI=Body mass index, BP=Blood pressure, BRHS=British Regional Heart Study, CHD=Coronary heart disease, CI=Confidence interval, DBP=Diastolic blood pressure, DM=Diabetes mellitus, ECG=Electrocardiogram, Hct=Hematocrit, HDL=High density lipoprotein, IHD=Ischemic heart disease, LDL=Low density lipoprotein, MI=Myocardial infarction, MRFIT=Multiple Risk Factor Intervention Trial, NA=Not applicable, NHANES=National Health and Nutrition Examination Survey, NOS=Not otherwise specified, NR=Not reported, OR=Odds ratio, RR=Relative risk, SBP=Systolic blood pressure, TC=Total cholesterol, WBC=White blood cell

Evidence Table 2

Impaired Fasting Glucose as a Risk Factor for Coronary Heart Disease

Study | N enrolled | N events | Duration of follow- up | Age range or mean (years) | % Men | Additional (Non-FRF) variables adjusted in analysis | Excluded DM Hx | Excluded baseline CVD/CHD | Degree of adjustment for Framingham variables | Type of categorization | HR (95%CI) by FG level | Quality rating
Antonicelli, 2001^60^ Camerano study group | 455 | 73 | Follow-up visits were every 3 years; median followup 6 years | 68.3 | 46 | Blood pressure medication, triglycerides | Yes | Yes | Age, BP, TC or LDL, DM, Gender, Smoking Not for HDL | - 1) Dichotomized: >=126 vs. <126 mg/dL; - 2) 110–126 vs. <110 mg/dL (results not shown) | <126 mg/dL: 1.0 (reference) >=126 mg/dL: 2.01 (1.07–3.76), p=0.03 FG 110–126 mg/dL had no significant increased risk of CHD compared with FG < 110 mg/dL (results not shown) | Fair
Cohen, 2004^61^ Worksite Hypertension Program | 6672 | NR | Mean 5.6 +- 4.5 years (range 0.5– 21.7 years) | 51.8 | 63.8 | Ethnicity, left- ventricular hypertrophy, prior BP treatment, interaction of TC and FG | Yes | Yes | Age, BP, TC or LDL, DM, Gender, Smoking Not for HDL | Dichotomized: using 2 cutoffs, 103 and 110 mg/dL | Elevated FG magnifies the relative risk of CHD associated with TC in non-diabetic hypertensive patients. FG >103 mg/dL: TC 200-259 was 2.46 (1.26–4.77) compared with TC <200, p=0.008. Results were similar but less significant using FG 110 mg/dL as the cutoff: 2.70 (1.09–6.67), p=0.031 FG <103 mg/dL: TC 200-259 was 0.89 (0.61–1.29) compared with TC <200, p=ns | Fair
Folsom, 1997^62^ ARIC | 13,446 | 305 | 4–7 years, with followup in 1990–1992 and 1993–1995 | 45–64 | NR (~50) | ARIC study center, ethanol consumption, education, sports index, hormone replacement, BMI, waist-to-hip ratio, fibrinogen, triglycerides, antihypertensive medication use | No; analyzed separately | Yes | Age, BP, TC or LDL, DM, HDL, Gender, Smoking | Categorized in 5 groups, in mg/dL:; - 1) <91; - 2) 91–97; - 3) >97–102; - 4) >102–115; - 5) >115–140 | Among people without diabetes, fasting glucose was not independently associated with CHD incidence. Adjusted RR (95%CI) each FG category: Women:; - 1) <91: 1.00 (reference); - 2) 91–97: 0.92 (0.45–1.89); - 3) >97–102: 0.81 (0.35–1.87); - 4) >102–115: 0.76 (0.36–1.63); - 5) >115–140: 0.53 (0.18–1.55); Men:; 1. 1) <91: 1.00 (reference); 2. 2) 91–97: 0.92 (0.56–1.50); 3. 3) >97–102: 0.50 (0.28–0.89); 4. 4) >102–115: 0.66 (0.40–1.07); 5. 5) >115–140: 1.08 (0.62–1.90) | Good
Meigs, 2002^63^ Framingham Offspring Study | 3,370 | 118 | 4 years | 54 | 46 | None | Yes | Yes | Age, BP, TC or LDL, DM, HDL, Gender, Smoking | Continuous per 13 mg/dL increase | FPG, per 0.7 mmol/L (13 mg/dL) increase: 1.088 (95% CI 1.02–1.16) P=0.008 When included in the same prediction model, 2-h postchallenge hyperglycemia remained a significant risk factor for CVD, whereas fasting plasma glucose had a weak protective effect of borderline significance. | Good
Ohlson, 1986^57^ Goteburg, Sweden | 832 | 106 | 17 years | 50 | 100 | None | Yes | Yes | Age, DM Not for BP, TC or LDL, HDL, Smoking | Dichotomized: >103 vs. <=103 mg/dL | No trend in CHD risk by quintile or decile of FBG. FBG >103 vs. <=103 mg/dL: 1.3 (0.7–3.3) (5.7 mmol/L = 103 mg/dL) | Poor
Pyorala, 1985^58^ Helsinki Policemen Study | 982 | 63 | 9.5 years | 47.4 | 100 | Physical activity, BMI, TG | Yes | Yes | Age, BP, TC or LDL, DM, Gender, Smoking | Quintiles, not otherwise specified | OR = 1.118 (p=ns) | Fair
Qiao, 2002^64^ 5 cohorts from the DECODE study: Helsinki Policemen Study, Vantaa Study, FIN- MONICA study (2 regions), East and West Finland Study | 6766 | 380 | 7–10 years; mean 8 years | 55 | 58 | BMI | No; analyzed separately | Yes | Age, BP, TC or LDL, DM, Gender, Smoking Not for HDL | Continuous per one standard deviation in natural-log transformed FG | 2-h glucose tolerance test was a stronger predictor of CHD than fasting glucose. Hazard ratio (95% CI) for CHD corresponding to one standard deviation increase in natural-log transformed fasting glucose v. 2-h OGTT: 1.05 (0.94–1.17) v. 1.17 (1.05–1.30) | Fair
Yarnell, 1994^59^ Caerphilly and Speedwell Studies | 4860 (4349 in analysis) | 405 | Caerphilly: 61 months Speedwell: mean 38 months | 45–59 | 100 | Triglyceride; pre- existing IHD | No; analyzed separately | No; adjusted as confounder | Age, BP, DM, Gender, Smoking Not for TC or LDL, HDL | Categorized in 5 groups, in increments of 18 mg/dL:; - 1) <=85; - 2) 86-; - 3) 104-; - 4) 122-; - 5) >=140 | No trend in CHD risk with increasing FG. OR (95%CI) by FPG: <=4.7 (<=85): 1.0 (reference) 4.8- (86-): 0.9 (0.6–1.2) 5.8- (104-): 1.1 (0.6–2.1) 6.8- (122-): 2.9 (1.2–6.6), p<0.05) >=7.8 (>=140): 1.4 (0.5–3.9) | Fair

Abbreviations: ARIC=Atherosclerosis risk in communities, BMI=Body mass index, BP=Blood pressure, CHD=Coronary heart disease, CI=Confidence interval, CVD=Cardiovascular disease, DBP=Diastolic blood pressure, DM=Diabetes mellitus, FG or FBG= Fasting (blood) glucose, FPG=Fasting plasma glucose, HDL=High density lipoprotein, HR=Hazard ratio, Hx=History, IHD=Ischemic heart disease, LDL=Low density lipoprotein, MI=Myocardial infarction, Non-FRF=Non Framingham risk factor, NR=Not reported, OGTT=Oral glucose tolerance test, OR=Odds ratio, RR=Relative risk, SBP=Systolic blood pressure, TC=Total cholesterol, TG=Triglycerides

Evidence Table 3

Periodontal Disease as a Risk Factor for Coronary Heart Disease

Author, year, title | Parent study | N Enrolled | Duration Follow-Up | Outcomes | Demographics | Measurement of Dental Disease | Variables Adjsuted for | Exposure | Results | | | Quality rating
Ajwani, 2003^71^ | Helsinki Aging Study | 175 | 5 years | Mortality, CVD mortality | 175 men and women aged 75–85 with at least 2 teeth; prevalent CHD included | Dental exam | Age, sex, TC, HDL, BP, smoking, BMI, prevalent CHD, social class | Periodontal disease Tooth loss | [underlined: CV mortality] PD Baseline: 2.28 (1.03–5.05) Partially edentulous: 1.46 (0.69–3.10) | | | Fair
Beck, 1996^72^ | Dental Longitudinal Study VA | 1,221 | 18 years; 6 exams | Total CHD (MI, CHD death, angina), stroke | 1094 community dwelling, men ages 21–81, all veterans, free of unknown chronic illnesses, with dental examinations and complete datasets | Radiographic and dental exams | Age, BMI, smoking, sBP, dBP, TC, family history, CHD, EtOH | Periodontal disease Bone loss | [underlined: Total CHD] hi vs. low bone loss: 1.5 (1.04–2.14) - adjusted: age, smoking, sBP, NIDDM pockets >3mm: 3.1 (1.3–7.40) - adjusted: age, BMI, sBP, TC ≥ half of teeth with pockets >3mm: 2.0 (1.13–3.70) - adjusted: age, BMI, sBP, TC mean bone loss (continuous): 1.4 (1.10–1.86) [underlined: Fatal CHD] hi vs. low bone loss: 1.9 (1.10–3.43) - adjusted: age, smoking, sBP, Type 2 DM | | | Fair
DeStefano, 1993^73^ (Updated in Hujoel, 2001 233) | NHANESI | 9,760 | 14 years | CHD mortality, total mortality, CHD admission | Men and women aged 25–74 years without known CHD | Dental exam | Age, sex, race, education, marital status, sBP, TC, BMI, DM, activity, EtOH, poverty index, smoking | Number of decayed teeth, periodontal classification, periodontal index, oral hygiene index | CHD deaths or admissions: Periodontitis 1.25 (1.06–1.48) Men ≤ 50: 1.72 Gingivitis 1.05 (0.88–1.26) Oral hygiene index (per unit) 1.12 (1.06–1.20) Periodontal index (per unit) 1.04 (1.01–1.08) Edentulous 1.23 (1.05–1.44) | | | Good
Howell, 2001^74^ | PHS | 22,037 | 12 years | Stroke, all CVD, CV death, non-fatal MI | 22037 male physicians aged 40–84 without stroke, MI, TIA, or cancer, providing dental information | Self report | Age, sex, smoking, DM, BP, BMI, exercise, alcohol | Tooth loss Periodontal disease | [underlined: Baseline periodontal disease/tooth loss during follow-up:] Non-fatal MI: 1.01 (0.82–1.24)/1.01 (0.87–1.17) Non-fatal stroke: 1.01 (0.81–1.27)/1.07 (0.91–1.27) CV death: 1.0 (0.79–1.26)/0.61 (0.51–0.73) All CV: 1.01 (0.88–1.15)/0.92 (0.83–1.01) | | | Fair
Hujoel, 2000^75^ | NHANES I | 8,032 | 4 follow-up exams, 1975–1992 | CHD death, hospitalization, or revascularization | 8032 general US population, dentate, age 25–70 without CHD | Dental exam | Demographics, SES, DM, smoking, alcohol, dBP, sBP cholesterol, mental illness, activity, BMI | Periodontitis, gingivitis | PD category | CHD events | CHD death | Good
Hujoel, 2000^75^ | NHANES I | 8,032 | 4 follow-up exams, 1975–1992 | CHD death, hospitalization, or revascularization | 8032 general US population, dentate, age 25–70 without CHD | Dental exam | Demographics, SES, DM, smoking, alcohol, dBP, sBP cholesterol, mental illness, activity, BMI | Periodontitis, gingivitis | Periodontitis | 1.14 (0.96–1.36) | 1.20 (0.90–1.61) | Good
Hujoel, 2000^75^ | NHANES I | 8,032 | 4 follow-up exams, 1975–1992 | CHD death, hospitalization, or revascularization | 8032 general US population, dentate, age 25–70 without CHD | Dental exam | Demographics, SES, DM, smoking, alcohol, dBP, sBP cholesterol, mental illness, activity, BMI | Periodontitis, gingivitis | Gingivitis | 1.05 (0.88–1.26) | 1.17 (0.84–1.61) | Good
Hujoel, 2001^231^ (Update of DeStefano, 1993 73) | NHANESI, NHEFS | 11,348 | 4 follow-up exams, 17 years | - 1st occurrence - CHD mortality - CHD revascularization - non-fatal MI | 4027 males and females, NHANES, ages 55–74 with either periodontitis (n=1857) or edentulous (n=2170) | Dental exam | Age, sex, TC, BP, DM, smoking, BMI, exercise, alcohol use | Russell Periodontal index | Comparing edentulous to periodontal infections, adjusted for confounders, RR for CHD event 1.02(0.86–1.21) | | | Fair
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | Men | | | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | Baseline # teeth: | CHD events | CHD death | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | 25–32: | 1.0 | 1.0 | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | 17–24: | 1.10 (0.95–1.26) | 1.26 (1.01–1.57) | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | 11–16: | 1.35 (1.06–1.72) | 1.19 (0.79–1.80) | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | 0–10: | 1.36 (1.11–1.67) | 1.79 (1.34–2.40) | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | | CHD events | CHD death | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | incidence tooth loss: | 0.86 (0-72–1.04) | 0.69 (0.48–1.01) | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | cumulative tooth loss: | 0.94 (0.82–1.09) | 1.03 (0.80–1.33) | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | Women | | | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | Baseline # teeth: | CHD events | CHD death | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | 25–32: | 1.0 | 1.0 | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | 17–24: | 1.14 (0.92–1.42) | 1.02 (0.66–1.55) | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | 11–16: | 1.34 (0.97–1.87) | 1.07 (0.56–2.05) | Good
Hung, 2004^76^ | Health Professional Follow-up Study, NHS | 51,529 males & 121,700 females | Women ≤20 years; men ≤12 years | CHD including fatal CHD, SCD without other likely cause, non-fatal MI | Health professionals; 41,407 men ages 40–75; 58,974 women ages 30–55; healthy at baseline; provided dental data | Self report | Age, sex, TC, smoking, DM, BP, BMI, exercise, alcohol, FMH, MVI, Vit E, menopausal, HRT use | History of periodontal disease Number of teeth lost History of bone loss | 0–10: | 1.64 (1.31–2.05) | 1.65 (1.11–2.46) | Good
Morrison, 1999^77^ | Nutrition Canada Survey | 16,090 of which 3670 were excluded | ≤ 21 years | Mortality, CHD mortality | 4248 males and 5083 females ages 35–84 without CHD or cerebrovascular disease | Dental exam | Age, sex, TC, smoking, DM, HTN, province | Edentulousness, periodontitis, gingivitis | [underlined: Fatal CHD] None: 1.0 Mild gingivitis: 1.54 (0.89–2.67) Severe gingivitis: 2.15 (1.25–3.72) Periodonitis: 1.37 (0.80–2.35) Endentulous: 1.9 (1.17–3.10) | | | Fair
Tuominen, 2003^78^ | Mini Finland Health Survey | 3,091 men, 3,436 women | 12 years | CHD death | Ages 30–69; representative of Finnish population | Dental exam | Age, sex, TC, smoking, DM, BP | Edentulousness, periodontal treatment need system, frequency of dental attendance | For all parameters no association. | | | Fair
Tuominen, 2003^78^ | Mini Finland Health Survey | 3,091 men, 3,436 women | 12 years | CHD death | Ages 30–69; representative of Finnish population | Dental exam | Age, sex, TC, smoking, DM, BP | Edentulousness, periodontal treatment need system, frequency of dental attendance | [underlined: Periodontal pockets:] | [underlined: Men] | [underlined: Women] | Fair
Tuominen, 2003^78^ | Mini Finland Health Survey | 3,091 men, 3,436 women | 12 years | CHD death | Ages 30–69; representative of Finnish population | Dental exam | Age, sex, TC, smoking, DM, BP | Edentulousness, periodontal treatment need system, frequency of dental attendance | | RR (95% CI) | RR (95% CI) | Fair
Tuominen, 2003^78^ | Mini Finland Health Survey | 3,091 men, 3,436 women | 12 years | CHD death | Ages 30–69; representative of Finnish population | Dental exam | Age, sex, TC, smoking, DM, BP | Edentulousness, periodontal treatment need system, frequency of dental attendance | None | 1.0 | 1.0 | Fair
Tuominen, 2003^78^ | Mini Finland Health Survey | 3,091 men, 3,436 women | 12 years | CHD death | Ages 30–69; representative of Finnish population | Dental exam | Age, sex, TC, smoking, DM, BP | Edentulousness, periodontal treatment need system, frequency of dental attendance | 4–6mm | 1.0 (0.6–1.6) | 0.9 (0.3–2.1) | Fair
Tuominen, 2003^78^ | Mini Finland Health Survey | 3,091 men, 3,436 women | 12 years | CHD death | Ages 30–69; representative of Finnish population | Dental exam | Age, sex, TC, smoking, DM, BP | Edentulousness, periodontal treatment need system, frequency of dental attendance | > 6mm | 1.0 (0.6–1.6) | 1.5 (0.6–3.8) | Fair

Abbreviations: ASA/B=Aspirin, BMI=Body mass index, BP=Blood pressure, CHD=Coronary heart disease, CV=Cardiovascular, CVD=Cardiovascular disease, DM=Diabetes mellitus, FMH=Family history, HDL=High density lipoprotein, HO=History of, HRT=Hormone replacement therapy, HTN=Hypertension, LDL=Low density lipoprotein, M=Measured, MI=Myocardial Infarction, MVI=Multivitamin, NHANES I=National Health and Nutrition Examination Survey-I, NHEFS=NHANES I Epidemiological Follow-up Study, NHS=Nurses Health Study, NR=Not reported, PD=Periodontal disease, RCT=Randomized controlled trial, RR=Relative risk, SCD=Sudden cardiac death, TC=Total cholesterol

Evidence Table 4

Carotid Intima-Media Thickness as a Risk Factor for Coronary Heart Disease

Author, year, title | Parent study | N enrolled | Duration follow- up | Outcomes | Variables adjusted for in analysis | Demographics | Results | | | | Quality rating
Belcaro, 1996^83^ | Italy | 2,322 randomly selected | 6 years | CV events: those requiring hospital admission | None | Ages 30–70; no prevalent CVD | Univariate analysis: Subjects with lower US score had lower event rates | | | | Poor
Chambless, 2003^41^ | ARIC | 15,792 - original 12,841 | 5.2 years | CHD “events” MI-definite or possible CHD death ELG MI Coronary revascularization | Age Sex Race HDL TC BP | No baseline CVD, DM, HTN, or hyperlipidemia | | | Women | Men | Good
Chambless, 2003^41^ | ARIC | 15,792 - original 12,841 | 5.2 years | CHD “events” MI-definite or possible CHD death ELG MI Coronary revascularization | Age Sex Race HDL TC BP | No baseline CVD, DM, HTN, or hyperlipidemia | Tertile 3/1: | | 3.76 (1.68–8.43) | 2.02 (1.32–3.09) | Good
Chambless, 2003^41^ | ARIC | 15,792 - original 12,841 | 5.2 years | CHD “events” MI-definite or possible CHD death ELG MI Coronary revascularization | Age Sex Race HDL TC BP | No baseline CVD, DM, HTN, or hyperlipidemia | >95th/less | | 2.42 (1.45–4.04) | 1.36 (0.84–2.18) | Good
Chambless, 2003^41^ | ARIC | 15,792 - original 12,841 | 5.2 years | CHD “events” MI-definite or possible CHD death ELG MI Coronary revascularization | Age Sex Race HDL TC BP | No baseline CVD, DM, HTN, or hyperlipidemia | >1mm | | 2.62 (1.55–4.46) | 1.20 (0.81–1.77) | Good
Chambless, 2003^41^ | ARIC | 15,792 - original 12,841 | 5.2 years | CHD “events” MI-definite or possible CHD death ELG MI Coronary revascularization | Age Sex Race HDL TC BP | No baseline CVD, DM, HTN, or hyperlipidemia | 0.19mm continuous | | 1.42 (1.24–1.64) | 1.18 (1.06–1.32) | Good
O’Leary,1999^86^ | Cardiovascular Health Study | 5888 enrolled, then 1389 excluded due to presence of CV disease, leaving 4476 for study | median 6.2 years | Incident MI and/or stroke | sBP dBP Age Sex Atrial fibrillation DM Smoking | Median age 72, 32% men, 15.2% African American | Composite score: Maximal CCA and ICA IMT (by quintile) 1: 1.0 2: 1.58 (0.89–2.81) 3: 2.20 (1.28–3.78) 4: 2.45 (1.44–4.19) 5: 3.61 (2.13–6.11) per 1 SD 1.36 (1.23–1.52) P trend < 0.001 | | | | Fair
Salonen, 1991^79^ | Kuopio | 1,288 men aged 42–60 | 1 month – 2.5 years | CHD events | None | Ages (n) NR aged 42: 277 aged 48: 299 aged 54: 365 aged 60: 347 | IMT (MM) 2.14 (1.08–4.26) Small plaques in common carotid 4.15 (1.51–11.47) Large “stenotic” plaques 6.71 (1.33–33.91) | | | | Poor
Van der Meer, 2004^87^ | Rotterdam | 6389 | Until January 2000 | Incident MI | Age Sex TC HDL BP DM BMI Smoking ASA BP meds Lipid meds | Mean age 69.3 10% with DM 22% smokers 62% women | [underlined: IMT:] | [underlined: Continuous(ISD)] | 1.28(1.14–1.44) | | Good
Van der Meer, 2004^87^ | Rotterdam | 6389 | Until January 2000 | Incident MI | Age Sex TC HDL BP DM BMI Smoking ASA BP meds Lipid meds | Mean age 69.3 10% with DM 22% smokers 62% women | | | [underlined: Women] | [underlined: Men] | Good
Van der Meer, 2004^87^ | Rotterdam | 6389 | Until January 2000 | Incident MI | Age Sex TC HDL BP DM BMI Smoking ASA BP meds Lipid meds | Mean age 69.3 10% with DM 22% smokers 62% women | Mild | 1.19(0.75–1.89) | 1.15(0.46–2.89) | 1.30(0.71–2.38) | Good
Van der Meer, 2004^87^ | Rotterdam | 6389 | Until January 2000 | Incident MI | Age Sex TC HDL BP DM BMI Smoking ASA BP meds Lipid meds | Mean age 69.3 10% with DM 22% smokers 62% women | Mod | 1.24(0.81–1.88) | 2.98(1.35–6.59) | 1.14(0.62–2.10) | Good
Van der Meer, 2004^87^ | Rotterdam | 6389 | Until January 2000 | Incident MI | Age Sex TC HDL BP DM BMI Smoking ASA BP meds Lipid meds | Mean age 69.3 10% with DM 22% smokers 62% women | Severe | 1.74(1.19–2.56) | 3.80(1.64–8.79) | 2.24(1.22–4.11) | Good

Abbreviations: ASA=Aspirin, BMI=Body mass index, BP=Blood pressure, CCA=Common carotid artery, CHD=Coronary heart disease, CVD=Cardiovascular disease, dBP=Diastolic blood pressure, DM=Diabetes mellitus, HDL=High density lipoprotein, ICA=Internal carotid artery, IMT=Intima-media thickness, MI=Myocardial Infarction, sBP=Systolic blood pressure, SD=Standard deviation, TC=Total cholesterol

Evidence Table 5

Electron Beam Computed Tomography Score as a Risk Factor for Coronary Heart Disease

Author, title, year | Source of cohort | Mean age (±SD) | Percent female | Observed annual hard event rate for entire cohort | Observed hard events/total no. of study participants | Mean length of follow-up (years) | Observed hard events per number of participants in highest CACS interval | Observed annual hard event rate for highest CACS interval | CACS groups for corresponding RR and OR | RR^*^ (CI) | OR^*^(CI) | † Risk factors adjusted (italics=measured) | Endpoint for which RR’s or OR’s are calculated | Slice thickness | Minimum area of calcification | Quality rating
Arad et al, 2000^91^ | self-referred | 53±11 | 29% | 0.40% | 18/1177 | 3.6 | not reported | N.A. | >80 160 600 | NR | 14.3 (4.9- 42.3) 19.7 (6.9– 56.4) 20.2 (7.3– 55.8) | age, htn, elevated TC, DM, smoking, family history | hard and soft coronary events | 3 mm | 0.93 mm2 | Poor
Arad et al, 2005^93^ | population-based | 59±6 | 35% | ‡0.20% | 40/4613 | 4.3 | 63/450 (CACS ≥400) | 3.3%^§^ | □ | NR | NR | age, gender, family history, LDL, HDL, smoking, blood pressure, DM, CRP | hard and soft coronary events | 3 mm | NR | Fair
Greenland, 2004^95^ | population-based | 65.7±7.8 | 10% | 0.94%,^#^ | 17/257,^#^ | 7^¶^ | 8/41^#^ 8/77 (CACS>300) | 2.8%^#^ 1.5% (CACS>300) | 0 1–100 101–300 >300 | 1, 3.4 (0.7–17.7)^#^ 3.2 (0.7–17.7)), 5.3 (1.1–25.0) 6.2 (1.0–37.0), 6.2 (1.2–31.8) 17.6 (3.7–83.0), 8.9 (1.9–41.8) | NR | Framingham risk score | hard coronary events | 6 mm | NR | Good
Kondos, 2003^94^ | self-referred | 50±9 for men; 54±9 women | 26% | 0.4% (M) 0.1% (W) | 52/4151 (M) 6/1484 (F) | 3.1 | 24/1034 (M) 3/390 (F) (CAC>75th%)^**^ | 0.7% (M) 0.3% (F) (CAC>75th%)^**^ | 0 1–3.8 4–30 31–169 170–7000 | 1^***^ 1.76 (0.39–7.88) 2.84(0.73–11.11) 5.61 (1.57–20.06) 7.24 (2.01–26.15) | NR | age, smoking, htn, hypercholesterolemia, DM | hard coronary events | 3 mm | 1 mm2 | Fair
LaMonte, 2005^97^ | self and physician referred | 54+/−10 | 36% | males 0.26% females 0.14% | males 62/6835 females 19/3911 | 3.5+/−1.4 | males 34/1380 (CACS>249, 20% males) females 7/376 (CACS>112, 10% females) | males 0.7% (CAC>249) females 0.5% (CACS>112) | Men 0 1–38 39–249 >249 Women 0 1–16 17–112 >113 | Men 1.0 3.3 (0.8–13.4) 10.2 (3–35.4) 17.7 (5.1–61.8) Women 1.0 2.2 (0.5–10.1) 3.9 (1.0–15.2) 7.2 (0.8–12.5) | NR | age, sex by stratification, htn and hypercholesterolemia and DM and smoking (y/n) | hard coronary events | 3 mm | NR | Fair
Raggi, 2001^29^ | physician-referred | 52±16 - those without events; 55±8 - those with events | 49% | 1.60% | 30/676 | 2.9 | 29/357 (CACS>0) | 2.8% (CACS>0) | Increase in age- sex specific CACS decile | NR | 1.03 (1.02– 1.05) | age, sex, smoking, htn, DM, and hypercholesterolemia | hard and soft coronary events and stroke | 3 mm | 1.03 mm2 | Fair
Taylor, 2005^98^ | population-based | males - 42.9+/−2.8 females 42.8+/−2.7 | 18% | males 0.18% females 0% | males 9/1627 females 0/356 | 3+/−1.4 | 7/124 (CACS>44, 7% males) | 1.9% (CACS>44) | 1–9 10–44 >44 | 4.32 (1.10–16.97) per increasing in tertile for those with CACS>0 | NR | Framingham risk score | hard coronary events and unstable angina | 3 mm | NR | Good
Vliegenthart, 2005^96^ | population-based | 71±5 | 58% | 0.70% | 40/1795 | 3.3 | 14/196 (CACS >1000) | 2.2% (CACS>1000) | 0–100 101–400 401–1000 >1000 | 1 2.7 (1.0–7.7) 4.1 (1.4–11.6) 8.1 (2.9–22.3) | NR | age, sex, BMI, blood pressure,TC, HDL, smoking, DM, family history | hard coronary events | 3 mm | 0.65 mm2 | Good
Wong, 2000^92^ | self- and physician-referred | 54±10 | 21% | 0.30% | 6/926 | 3.3 | 1/122 (CACS>271) | 0.2% (CACS>271) | 1–15 16–80 81–270 >270 | O.72 (p>0.05) 3.29 (p>0.05) 4.5 (p<0.05) 8.8 (p<0.001) | NR | age, gender, htn, hypercholesterolemia, DM, smoking | hard coronary events | 3 mm | 0.51 mm2 | Fair

* adjusted

† Risk factors that were measured, rather than obtained by history, are in itallics.

‡ rate is for 4613 study participants of whom 1293 had risk factors measured and were included in multivariate analysis

§ event rate includes coronary death, nonfatal MI, CABG, and PTCA. Event rate for this combined outcome for entire cohort was 2.6%

□ Framingham risk calculated in manuscript text. For intermediate-risk group (10-year risk 10–20%), observed coronary event rates (hard and soft) were greater than 2% per year for those with CAC scores in the highest 3rd tertile (actual CAC score not reported).

¶ median rather than mean

# data for Framingham risk groups 10–15% and 16–20%, respectively. Referent for RR’s is Framingham risk 0–9% and CAC score <300.

** CACS greater than 75th age-sex percentile

*** RR’s are for males. RR’s for females were not statistically significant.

ABBREVIATIONS: CACS = coronary artery calcium score; CS% = calcium score percentile; DM = diabetes mellitus; M=male, F=female; MI = myocardial infarction; OR= odds ratio; RR=relative risk

Evidence Table 6

Cohort Studies of Homocysteine as a Risk Factor for Coronary Heart Disease

Author, year, title | Parent study | N enrolled | Duration follow-up | Variables adjusted for | Quality rating
Bostom, 1999^134^ | Framingham | 1933, mean age 71, males and females | 10 years | Sex, age, DM, smoking, sBP, TC, LDL | Good
Nurk, 2002^135^ (See Vollset below) | Hordaland Homocysteine Study | 17361 men and women | Mean 5.3 years | Sex, age, smoking, DM, Cholesterol, BMI, sBP, HTN | Fair
Sacco, 2004^136^ | Northern Manhattan Study | 2939 men & women aged >=40, mean age 69 Excluded prevalent stroke. | Mean 5 years | Age, race, sex, education, HTN, DM, cardiac disease, HDL < 40, alcohol, smoking, renal insufficiency, B12 deficiency | Good
Stehouwer, 1998^137^ | Zutphen Elderly Study, 7 countries studied | 878 men aged 64–84, baseline CHD included Mean age 71 | 9+ years | Age, BMI, BP, HDL, TC, DM, smoking | Fair
Ubbink, 1998^138^ | Caerphilly in South Wales | 2398 mean age 50–64 | 5 years | Age, social class, sex, smoking, prevalent CHD, DM, BMI, HDL, TC, dBP | Fair
Vollset, 2001^139^ (See Nurk above) | Hordaland | 4766 men and women aged 65–67 of high and low CVD risk (prevalent CHD included) | 4.1 years | TC, sBP, dBP, smoking, BMI, physical activity, age, sex, baseline CVD risk status | Fair
Voutilainen, 2004^140^ | Kuopio | 2,682 men recruited; 1,229 eligible No baseline CHD ages | 7 years, 8 months | Age, exam year, sBP, smoking, BMI, LDL, HDL | Fair
Zylberstein, 2004^141^ | 24 year follow-up of the population study of women in Gotenburg without baseline myocardial infarction | 1368 women aged 38–60 | 24 years | Age, smoking, BMI W/H ratio, TG, chol, BP, (coffee, creatinine, B-12, dietary folate) added to 3rd model | Fair

Abbreviations: AMI=acute myocardial infarction, BMI=body mass index, BP=blood pressure, CAD=coronary artery disease.

Evidence Table 7

Nested Case Control Studies of Homocysteine as a Risk Factor for Coronary Heart Disease

Author, year, title | Parent study | Enrolled N cases, N controls | Demographics | Duration of follow-up | List variables adjusted for | Quality rating
Albert, 2002^113^ | Physicians Health Study | CA 97 CO 192 | 22,071 male physicians aged 40–84 without CVD | 9 years | Age, smoking, length of follow-up, HTN, DM, BMI, FMH, alcohol use, exercise | Fair
Alfthan, 1994^114^ | North Karelia | CA 92 men, 99 women CO 141 men, 128 women | 12,055 men and women ages 30–64 from 2 Finnish provinces without CVD | 9 years | Age, sex, TC sBP, smoking | Fair
Arnesen, 1995^115^ | Tromso Health Study | CA 122 CO 478 | ~22,000 men and women aged 12–61 | 4 years | Survey date, age, sex, hours since last meal, TC, HDL, BP, DM, TG, smoking, angina | Fair
Blacher, 2002^116^ | France | CA 110 CO 154 | 215 men, 49 women mean age 65 15 with prior CHD | Mean 14 years | Age, sex, BP, CRP, DM, prevalent CHD | Poor
Bots, 1999^117^ | Rotterdam | CA 224 CO 533 | Men and women age ≥ 55 ~24% of cases and 6.5% of controls with prior MI | 2.7 years mean | Age, sex, TC, HDL, BP, DM, smoking, prevalent CHD or stroke | Good
Chasan-Taber, 1996^258^ | Physicians Health Study | CA 333 CO 333 | 14,916 male physicians ages 40–84 without CHD | 7.5 | DM, angina, age, smoking, ASA use, HTN, quetelets, TC, HDL | Good
de Bree, 2003^118^ | Monitoring Project on CVD RF | CA 170 CO 749 | Men and women ages 20–59 Prevalent CHD excluded | 8–13.4 years (mean 10.3 years) | Age, sex, TC, HDL, BP, smoking, creatinine, study center | Good
Evans, 1997^119^ | MRFIT | CA 240 CO 472 | 12,866 Caucasian men aged 35–57 at moderately high risk | 11–17 years | Age, smoking, clinic, race, HDL, LDL, smoking, TG, dBP | Good
Fallon, 2001^120^ | Caerphilly | CA 312 CO 1248 | Men aged 45–59 South Wales 29.8% of cases with ECG ischemia | 10 years | Age, TC, HDL, smoking, TG, BMI, alcohol use, BP, fibrinogen prevalent CHD, DM, creatinine | Good
Folsom, 1998^121^ | ARIC | CA 232 CO 537 | Population -based, ages 45–64 Prevalent stroke, CHD, and TIA excluded men and women | Median 3.1 years | Age, sex, TC, HDL, BP, DM, smoking, race, center | Good
Hoogeveen, 2000^122^ | Hoorn | CA 171 CO 640 | Men and women aged 50–75 Prevalent CHD included | 5 years | Age, sex, TC, BP, DM, smoking, HbAIC, albumin | Fair
Hultdin, 2004^123^ | MONICA, VIP | CA 50 CO 56 | 89 men 17 women Age 53 Not clearly stated but appears prevalent MI excluded | 8.4 years | Age, sex, creatinine albumin | Poor
Knekt, 2001^125^ | Mobile clinic health exam survey Finland 1973–1976 | [underlined: With CHD] CA 166 CO 311 [underlined: Without CHD] CA 272 CO 524 | 3471 men aged 45–64 884 (25%) with prior CHD | 13 years | Age, sex, TC, BP, DM, smoking, alcohol use, BMI | Fair
Knekt, 2001^124^ | Mobile clinic health exam | Baseline [underlined: CHD] CA 74 CO 147 No CHD at [underlined: Baseline] CA 75 CO 149 | 3479 women aged 45–64 757 (22%) with prior CHD | 13 years | Age, sex, TC, BP, DM, smoking, BMI | Good
Lind, 2003^126^ | Malmo | CA 241 CO 241 | Men mean age 48 Prevalent CVD excluded | 17 years | Age, sex, TC, BP, DM, smoking | Fair
Ridker, 1999^127^ (see Ridker 2000 below) | Women’ s Health Study | CA 122 CO 244 | Women, mean age 59, enrolled in trial, post-menopausal, no prevalent CVD | 3 years | Age, sex, TC, BP, BMI, exercise, family history | Good
Ridker, 2000^14^ | Women’ s Health Study | CA 122 CO 244 | Womens Health Study Mean age 59.3 Post-menopausal No prevalent CVD | 3 years | Age, sex, TC, HDL, BP, DM, smoking, BMI, ASA, vitamin E, family history, CVD, CRP, Lp(a) | Good
Shai, 2004^128^ | Nurses Health Study | CA 237 CO 458 | U.S. nurses ages 30–55 at inception, n=32826. Excluded prevalent CHD. | 8 years | age, smoking, hours fasting, year Hcy, BMI, parental MI<age 60, HTN, DM, HRT, alcohol, activity, HDL, TC, CRP | Good
Stampfer, 1992^129^ | Physicians Health Study | CA 271 CO 271 | U.S. male physicians aged 40–84 (mean 58.9) Prior MI, CVA, TIA, Cancer excluded | 5 years | Age, sex, TC, HDL, BP, DM, ASA, angina, BMI, smoking | Good
Verhoef, 1997^130^ | Physicians Health Study | CA 149 CO 149 | U.S. male physicians aged 40 84 (mean 58.9) Prior MI, CVA, TIA, Cancer excluded | 9 years | TC, HDL, BP, DM, BMI, alcohol use, ASA | Good
Voutilainen, 2000^131^ | Kuopio Ischemic Heart Disease Risk Factor Study | CA 163 CO 163 | Men, median age 53 without prevalent CHD | 8.9 years | Exam year, urinary nicotine | Poor
Wald, 1998^132^ | British United Provident Association (BUPA) | CA 229 CO 1126 | Men, median age 53, without prevalent CHD | 8.7 years | Age, sex, BP, Apoprotein B | Poor
Whincup, 1999^133^ | British regional heart study | CA 386 CO 454 | 7735 men aged 40–59 (mean ~52) Prevalent CHD included 44% CA 26% CO | 12.8 years | Age, TC, HDL, BP, DM, smoking, BMI, exercise, alcohol use, FEV, creatinine, urate | Poor

Abbreviations: ARIC=Atherosclerosis Risk in Communities Trial, ASA=acetylsalicylic acid, BMI=body mass index, CA=cases, CHD=coronary heart disease, CO=controls, CRP=c-reactive protein, CVD=cardiovascular disease, DM=diabetes mellitus, HTN=hypertension, ECG=electrocariogram, FEV=forced expiratory volume, Lp(a)=lipoprotein(a), MI=myocardial infarction, MONICA=Monitoring of Trends and Determinants in Cardiovascular Disease Study, MRFIT=Multiple risk factor intervention trial, RF=risk factor, sBP=systolic blood pressure, TC=total cholesterol, TG=triglycerides, TIA=transient ischemic attack, VIP=Vasterbotten Intervention Program.

Evidence Table 8

Lipoprotein(A) as a Risk Factor for Coronary Heart Disease

Author, year Cohort | Study design | N enrolled | Duration of follow-up | FRFs in model | Sample storage | Assay method | Type of categorization | RR | RR.LB | RR.UB | Study quality | Significant association?
Bostom, 1994^164^ & 1996^165^ Framingham & Offspring | Cohort | 3103 women; 2191 men | Median 15.4 years | Age, BP, TC/LDL, Diabetes, Gender, HDL, Smoking, BMI | Fresh | Electrophoresis; ELISA | Dichotomous: band presence vs. absence Band presence generally correlates to Lp(a) levels of >30 mg/dL. | Men: 1.9 Women: 1.61 | Men: 1.2 Women: 1.13 | Men: 2.9 Women: 2.29 | Good | Y
Cantin, 1998^167^ Quebec Cardiovascular Study | Cohort | 2156 men | 5 years | Age, BP, TC/LDL, Gender, HDL, Smoking; did not adjust for diabetes | Frozen 7 years at −80C | ELISA | Tertiles, mg/dL: <11.0 11.0–33.0 >33.0 | 1.16 | 0.73 | 1.85 | Fair | N
Cremer, 1997^170^ GRIPS | Cohort | 5639 men | 10 years | Age, BP, TC/LDL, Diabetes, Gender, HDL, Smoking, EtOH, physical activity, family hx of MI, apo B, apo AI, fibrinogen, uric acid | Frozen 9 years at −90C | ELISA | Dichotomous: <30 v. >=30 mg/dL | 2.0 (p=0.0001) | NR | NR | Fair | Y
Dahlen, 1998^180 &^ Thogersen, 2004^184^ MONICA & VIP | NCC | 62 cases 124 controls 100% male | NR | Age, BP, TC/LDL, Gender, Smoking, BMI; did not adjust for Diabetes and HDL | Frozen 9 years at −80C | ELISA | Dichotomous: <20 v. >=20 mg/dL; Categorized: <=30 mg/L 30–65 mg/L 65–134 mg/L >134 mg/L | Dichot: 6.76 Categ: 7.21 | Dichot: 2.11 Categ: 1.31 | Dichot: 21.68 Categ: 39.8 | Fair | Y
Evans 2001^149^ MRFIT | NCC | 246 cases 490 controls for Lp(a) analysis; 246 controls for apo(a) isoform 100% male | Up to 20 years | Age, Diabetes, Gender, Smoking, apo(a) size; did not adjust for BP, TC/LDL and HDL. (Model not reported adjusted for all FRFs +CRP: null finding) | Frozen 20 years at −50 to −70C | ELISA | Quartiles, mg/dL: 0.1–1.2 1.3–3.4 3.5–9.2 9.3–83.3 Results are for nonfatal MI among smokers | 0.99 | 0.95 | 1.03 | Fair | N
Jauhiainen, 1991^181^ Helsinki Heart Study | NCC | 138 cases 130 controls 100% male | 5 years | Age, TC/LDL, Gender, HCL, Smoking, did not adjust for BP abd Diabetes | Frozen 7 years at −20C | ELISA | Dichotomous: <28 v. >=28 mg/dL | 1.32 | 0.77 | 2 | Fair | N
Kronenberg, 1999^191^ Bruneck Study | Cohort | 421 men 498 women | 5 years | Analysis stratified by high and low molecular weight apo(a). | NR | ELISA | Lp(a) cutoff of 32 mg/dL. Referent group: HMW apo(a), low Lp(a). | HMW apo(a), high Lp(a): 1.0 LMW apo(a), high Lp(a): 3.4 | HMW apo(a), high Lp(a): 0.2 LMW apo(a), high Lp(a): 1.7 | HMW apo(a), high Lp(a): 4.6 LMW apo(a), high Lp(a): 6.5 | Fair | N
Luc, 2002^172^ PRIME | Cohort | 9133 men | 5 years | Age, BP, TC/LDL, Diabetes, Gender, HDL, Smoking, TG | Fresh | Immunoassay | Quartiles, mg/dL: <21 21–66 66–210 >210 | 1.42 | 0.88 | 2.27 | Good | N
Nguyen, 1997^173^ | Cohort | 4967 men; 4969 women | 14.1 years in women, 13.9 years in men | Age, BP, TC/LDL, Diabetes, Gender, TG; did not adjust for HDL and smoking | Fresh | Electrophoresis | Categorized: Band presence in 4 groups of increasing amount (qualitative assessment) | Men: 1.6 Women: 1.9 | Men: 1.0 Women: 1.3 | Men: 2.6 Women: 2.9 | Fair | Y
Pischon, 2005^186^ Health Professionals Follow-up Study | NCC | 243 cases 496 controls 100% male | 6 years | Age, gender, history of hypertension, diabetes, smoking; did not adjust for TC, LDL, HDL. | Frozen in liquid nitrogen at −130C, duration not reported. | Immunoturbimetric method | Quintiles, median values per quintile (mg/dL): 1) 2.00 (reference) 2) 6.50 3) 11.60 4) 23.80 5) 67.35 | 1.59 P for trend = 0.11 | 0.95 | 2.65 | Fair | N
Price, 2001^174^ Edinburgh Artery Study | Cohort | 809 men; 783 women | 5 years | Age, BP, TC/LDL, Gender, HDL, Smoking, BMI, fibrinogen; did not adjust for diabetes | Frozen 7 years at −50C | ELISA | Continuous: one-unit increase of lp(a) on a logarithmic scale | 1.06 | 0.91 | 1.24 | Fair | N
Ridker, 1993^182^ Physicians’ Health Study | NCC | 296 cases 296 controls 100% male | 60.2 months | Age, BP, TC/LDL, Gender, HDL, Smoking, Randomized Rx, BMI, family hx of MI | Frozen 5 years (mean follow-up) at −80C | ELISA | Quintiles, mg/dL: <=3 3.1–7.3 7.4–13.3 13.4–27.9 28–116 | 0.83 | 0.36 | 1.89 | Fair | N
Rosengren, 1990^162^ | NCC | 26 cases 109 controls 100% male | 6 years | Age, BP, TC/LDL, Gender, Smoking, BMI, maternal hx of MI; did not adjust for diabetes and HDL | Frozen 6 years at −70C | NR | Continuous per 0.1 mg/dL increase | 1.0031 (p=0.010) | NR | NR | Fair | Y
Salomaa, 2002^175^ FINRISK | Cohort | 986 men and 1254 women without baseline CHD | Mean 79 months | Age, BP, TC/LDL, Diabetes, Gender, Smoking; did not adjust for HDL | Frozen 8 months at − 70C | Immunoradiometric assay | Continuous per 1-SD increase | 0.93 | 0.73 | 1.18 | Fair | N
Schaefer, 1994^183^ Lipid Research Clinics - Coronary Primary Prevention Trial | NCC | 233 cases 390 controls 100% male | 7–10 years till 1983 | Age, BP, TC/LDL, Diabetes, Gender HDL, Smoking, BMI | Frozen 18 years at −80C | ELISA | Quintiles, mg/dL: <=3.0 3.1–7.2 7.3–15.5 15.6–34.8 34.9–119.8 | 2.08 | 1.19 | 3.63 | Fair | Y
Seed, 2001^176^ 2nd Northwick Park Heart Study | Cohort | 3,052 men; 2,616 analyzed (free of CHD at baseline and with Lp(a) levels) | Mean 6 years | Age, BP, TC/LDL, Diabetes, Gender, Smoking; did not adjust for HDL | Frozen 1 year at −80C | ELISA | Categorized, mg/dL: <2.9 2.9–26.3 >26.3 mg/dL | 1.9 | 1.1 | 3.3 | Fair | Y
Sharrett, 2001^177^ ARIC | Cohort | 5432 men; 6907 women | 10 years | Age, BP, TC/LDL, Diabetes, Gender, HDL, Smoking | Frozen 6 weeks at −70C | ELISA | Continuous per 1-SD increase | Men: 1.15 (p<0.01) Women: 1.17 (p<0.01) | NR | NR | Good | Y
Suk Danik, 2006^179^ Women’s Health Study | Cohort | 27791 women | 10 years | Age, BP, TC/LDL, Diabetes, Gender, HDL, Smoking. Model also adjusted for body mass index, current hormone therapy use, CRP, and treatment group (vit E, aspirin, or placebo) | Frozen at −150- to −180C, duration NR | Immunoturbimetric method | Quintiles, median (range, mg/dL) in each: 1) 1.90 (0.10–3.40) 2) 5.40 (3.50–7.50) 3) 10.60 (7.60–15.30) 4) 24.30 (15.40–43.90) 5) 65.50 (44.00–239.60) | Women: 1.47 | 1.21 | 1.79 | Good | Y
Von Eckardstein, 2001^178^ PROCAM | Cohort | 820 men | 10 years | Age, BP, TC/LDL, Diabetes, Gender HDL, Smoking, Angina, TG, family history of MI | Fresh | Electro-immunoassay | Dichotomous: <20 v. >=20 mg/dL | 2.7 | 1.4 | 5.2 | Fair | Y
Wild, 1997^185^ Stanford Five-City Project | NCC | 134 cases 134 controls 32.8% female | Cross-sectional population surveys were conducted every 2 years from 1979 to 1986, in 1989–1990 | TC only. Did not exclude subjects with diabetes, and did not adjust for diabetes. | Frozen at −70C >5 years | ELISA | Odds are calculated for 3-quintile difference in log Lp(a), and 1-mmol/L unit difference for the cholesterol levels. | Men: 1.44 Women: 1.38 | Men: 1.04 Women: 0.52 | Men: 1.98 Women: 3.66 | Fair | Yes, in men but not in women

Abbreviations: Apo(a)=Apolipoprotein(a), apo AI=apolipoprotein A-1, apo B=apolipoprotein B, ARIC=Atherosclerosis Risk in Communities, BMI=body mass index, BP=blood pressure, CHD=coronary heart disease, CRP=c-reactive protein, ELISA=enzyme-linked immunosorbent assay, EtOH= Alcohol use, FRF=Framingham risk factor, GRIPS=Goettingen Risk Incidence and Prevalence Study, HDL=High density lipoprotein, Hx=History, LP(a)=Lipoprotein(a), MI=Myocardial infarction, MONICA=Monitoring of Trends and Determinants in Cardiovascular Disease, NCC=Nested case control, NR=Not reported, PROCAM=Prospective Cardiovascular Muenster Study, RR=Relative risk (LB=lower bound, UB=upper bound), Rx=Treatment, SD=Standard deviation, TC=Total cholesterol, TG=Triglycerides.

Evidence Table 9

Cohort Studies of C-Reactive Protein as a Risk Factor for Coronary Heart Disease

| | | | | | | Definitions of Incident CHD Outcomes
| | | | | | | Non-fatal MI | | | Deaths | | | Framingham variables adjusted for in analyses | | | | | | | | | | | | Effect Size (RR, HR, OR) of CRP categories compared with lowest category (95% CI)
Author, year | Study name | Population/sampling | N in analysis | % Male | Mean age/range (years) | Mean follow-up (years) | Clinical features | ECG | Cardiac enzymes | Death certificate | Clinical Information | Other CVD Outcomes included in analysis | Age | Sex | Smoking | DM | HTN | HDL | LDL | TC | Other adjusted covariates | Number of Incident CHD events | Type of analysis | Analyzed by | 2nd | 3rd | 4th | 5th | Effect Size (95% CI) for increase in CRP as continuous variable | Quality rating
Blake, 2003^206^ | WHS | Cohort derived from RCT of health professionals/random | 15,215 | 0 | Mean = 54.1 | 8.1 (median) | 1 | 1 | 1 | 1 | 1 | Non-fatal ischemic stroke; coronary revascularization; and combined CV death | 1 | all female | 1 | 1 | 1 | 1 | 1 | 0 | 1) BMI; 2) Randomized assignment to ASA or Vitamin E | 321 [underlined: combined CV] outcomes (97 Non-Fatal MI; 33 CVD deaths; 85 Non- Ischemic stroke; 106 Coronary Revascularization) | Cox proportional hazards regression | Dichotomous (<3mg/L and ≥ 3mg/L) | 1.44 (no 95% Cl reported, p=0.005) | n/a | n/a | n/a | n/a | Good
Koenig, 2004^207^ | MONICA | General community/random | 3,435 | 100 | Incident CHD = 59.2 No incident CHD = 56.2 Range: 45 to 74 | 6.6 | 1 | 1 | 1 | 1 | 1 | None | 1 | all male | 1 | 1 | 1 | 1 | 0 | 1 | None | 191 | Cox proportional hazards regression | CDC/AHA cutpoints | 1.44 (0.95, 2.17) | 2.21 (1.49, 3.27) | n/a | n/a | n/a | Good
Koenig, 2004^208^ | MONICA | General community/random | 934 | 100 | All Subjects = 54.1 Incident CHD = 56.0 No incident CHD = 53.9 Range = 45 to 64 | 14 | 1 | 1 | 1 | 1 | 1 | None | 1 | all male | 1 | 1 | 1 | 1 | 0 | 1 | 1) Physical activity; 2) BMI; 3) Alcohol intake; 4) Education | 97 | Cox proportional hazards regression | Continuous | n/a | n/a | n/a | n/a | 1.28 (1.03, 1.06) [For 1 SD increase in CRP level] | Good
Lawlor, 2005^209^ | British Women’s Heart and Health Study | Community general practitioners’ patient registries/random stratified by town and age | 2,723 | 0 | Range = 60 to 79 | 3.5 (median) | 1 | 1 | 1 | 1 | 1 | Angina; CABG; and angioplasty | 1 | all female | 1 | 1 | 1 | 1 | 0 | 0 | 1) BMI; 2) ETOH use; 3) exercise; 4) leg length; 5) trunk length; 6) FEV; 7) “Life course SES position” | 151 (In the full sample of 3,745) | Cox proportional hazards regression | Continuous | n/a | n/a | n/a | n/a | 1.03 (0.94, 1.13) [For doubling of CRP level] | Fair
Lowe, 2001^210^ | Speedwell | General practitioners’ patient panels/complete | 1595 | 100 | Incident CHD = 58.6 No Incident CHD = 57.1 Range: 49 to 67 | 6.25 | 1 | 1 | 1 | 1 | 1 | New Q-waves on follow-up ECG in the absence of Q-waves at baseline | 1 | all male | 1 | 0 | 1 | 0 | 0 | 1 | 1) BMI; 2) Ischemia at baseline; 3) Sample thawed/unthawed | 191 | Multiple logistic regression | Quintiles | nr | nr | nr | 1.6 (0.90, 2.83) | n/a | Fair
Lowe, 2004^211^ | 1) Caerphilly, and 2) Speedwell | General practitioners’ patient panels & General community | 3065 | 100 | Range = 49 to 66 | 1) 8.75 2) 6.25 | 1 | 1 | 1 | 1 | 1 | New Q-waves on follow-up ECG in the absence of Q-waves at baseline | 1 | all male | 1 | 0 | 1 | 0 | 0 | 1 | 1) Cohort membership; 2) BMI; 3) evidence of ischemia at baseline | 351 (In the full sample of 3213) | Multiple logistic regression | Quintiles | nr | nr | nr | 1.72 (1.14, 2.58) | n/a | Fair
Mendall, 2000^212^ | Caerphilly | General community | 1,395 | 100 | Range: 45 to 59 | 13.7 | 1 | 1 | 1 | 1 | 1 | New Q-waves on follow-up ECG in the absence of Q-waves at baseline | 1 | all male | 1 | 0 | 1 | 0 | 0 | 1 | 1) Plate; 2) BMI; 3) FEV1; 4) ETOH; 5) Current and father’s social class; 6) Fibrinogen | 249 | Multiple logistic regression | Quintiles | 1.11 (0.58, 2.10) | 0.92 (0.48, 1.75) | 1.14 (0.60, 2.15) | 0.96 (0.50, 1.86) | n/a | Fair
Park, 2002^213^ | South Bay Heart Watch | General community/respondents to mailing | 967 | 90.5 | Incident CHD = 67 No incident CHD = 66 Range: 45 and older | 6.4 | 1 | 1 | 1 | 1 | 1 | None | 1 | 0 | 1 | 0 | 1 | 1 | 0 | 0 | 1) ASA use; 2) BMI; 3) Race | 50 | Cox regression | Continuous | n/a | n/a | n/a | n/a | 1.49 (0.94, 2.37) [For 1 unit increase in log scale] | Fair
Pirro, 2001^214^ | Quebec Cardiovascular | General community, using electoral lists/random | 2,037 | 100 | Mean = 56.5 Range: 45 to 76 | 5 | 1 | 1 | 1 | 1 | 1 | Atypical angina and coronary insufficiency | 1 | all male | 1 | 1 | 1 | 1 | 1 | 1 | 1) Medication use; 2) BMI; 3) Triglycerides | 105 (61 “hard”) | Cox proportional hazards regression | Dichotomous (<1.77mg/L and ≥ 1.77mg/L) | 1.1 (0.7, 1.6) | n/a | n/a | n/a | n/a | Fair
Ridker, 2005^215^ | WHS | Cohort derived from RCT of health professionals/random | 15,632 | 0 | Mean = 54.4 Range(interquartile): 48 to 59 | 10 | 1 | 1 | 1 | 1 | 1 | Non-fatal ischemic stroke; coronary revascularization; and combined CV death | 1 | all female | 1 | 1 | 1 | 0 | 0 | 0 | 1) BMI; 2) Randomized assignment to ASA or Vitamin E | 464 [underlined: combined CV] outcomes (131 MI; 76 “CV deaths”) | Cox proportional hazards regression | Quintiles | 1.85 (1.16, 2.96) | 1.91 (1.21, 3.03) | 2.38 (1.52, 3.72) | 2.98 (1.90, 4.67) | n/a | Fair
Ridker, 2004^216^ | WHS | Cohort derived from RCT of health professionals/random | 15,745 | 0 | Range: 45 and older | 9 | 1 | 1 | 1 | 1 | 1 | Non-fatal ischemic stroke; coronary revascularization; and combined CV death | 1 | all female | 1 | 1 | 1 | 1 | 1 | 0 | None | 698 [underlined: combined CV] outcomes | Cox proportional hazards regression | CDC/AHA cutpoints | 1.2 (0.9, 1.6) | 1.9 (1.4, 2.5) | n/a | n/a | n/a | Good
Ridker, 2002^217^ | WHS | Cohort derived from RCT of health professionals/random | 27,939 | 0 | Mean = 54.7 Range: 45 and older | 8 | 1 | 1 | 1 | 1 | 1 | Non-fatal ischemic stroke; coronary revascularization; and combined CV death | 1 | all female | 1 | 1 | 1 | 0 | 0 | 0 | 1) Use of HRT; 2) Randomized assignment to ASA or Vitamin E | 571 [underlined: combined] CV outcomes (371 CHD; 80 CV death; 158 Ischemic stroke) | Cox proportional hazards regression | Quintiles | 1.4 (0.9, 2.2) | 1.6 (1.1, 2.4) | 2.0 (1.3, 3.0) | 2.3 (1.6, 3.4) | n/a | Fair
St. Pierre, 2005^218^ | Quebec Cardiovascular | General community, using electoral lists/random | 1,982 | 100 | All Subjects = 56.5 Incident CHD = 58.7 No Incident CHD = 56.2 | 13 | 1 | 1 | 1 | 1 | 1 | None | 1 | all male | 1 | 1 | 1 | 1 | 1 | 0 | 1) Medication use; 2) BMI; 3) Triglycerides | 210 | Cox proportional hazards regression | Quartiles | nr | nr | 0.98 (0.65, 1.49) | n/a | n/a | Good
Wilson, 2005^219^ | Framingham (original and second generation offspring cohorts) | General community | 4,446 | 43.8 | Men = 57 Women = 59 | 8 | * | * | * | * | * | None | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | None | 160 | Cox proportional hazards regression | CDC/AHA cutpoints | 1.38 (0.88, 2.15) | 1.22 (0.81, 1.84) | n/a | n/a | n/a | Fair

Abbreviations: AHA=American Heart Association, ASA=Acetylsalicylic acid, BMI=body mass index, CABG=coronary artery bypass graft, CDC=Centers for Disease Control, CHD=coronary heart disease, CI=confidence interval, CV or CVD=cardiovascular disease, CRP=c-reactive protein, ECG=echocardiogram, ETOH=alcohol use, FEV=forced expiratory volume, MONICA=Monitoring of trends and determinants in cardiovascular disease study, RCT=randomized controlled trial, SD=standard deviation, SES=socio-economic status, WHS=Women’s Health Study.

Evidence Table 10

Nested Case Control Studies of C Reactive Protein as a Risk Factor for Coronary Heart Disease

| | | | | | | Definitions of Incident CHD Outcomes
| | | | | | | Non-fatal MI | | | Deaths | | | Framingham variables adjusted for in analyses | | | | | | | | | | | Effect Size (RR, HR, OR) of CRP categories compared with lowest category (95% CI)
Author, year | Study name | Population/sampling | N in analysis | % Male | Mean age/range (years) | Mean follow-up (years) | Clinical features | ECG | Cardiac enzymes | Death certificate | Clinical Information | Other CVD Outcomes included in analysis | Age | Sex | Smoking | DM | HTN | HDL | LDL | TC | Other adjusted covariates | Type of analysis | Analyzed by | 2nd | 3rd | 4th | 5th | Effect Size (95% CI) for increase in CRP as continuous variable | Quality rating
Ballantyne, 2004^227^ | ARIC | Community/probability sample | 1,348 | Case=67.8 Non-case=41.1 | Case=58.5 Non-case=56.7 | Approximately 6.0 (time to event 4.1) | 1 | 1 | 1 | 1 | 1 | Silent MI (9.5%); and coronary revasculization (39.0%) | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1) Race | Cox proportional hazards regression | CDC/AHA cutpoints | 1.31 (0.96, 1.80) | 1.72 (1.24, 2.39) | n/a | n/a | n/a | Good
Danesh, 2004^205^ | Reykjavik Study | Community/random | 5,933 | Case=72 Control=69 | Case=55.8 (9.3) Control=55.7 (9.1) | Case=17.5 (8.7) Control=20.6 (8.2) | 1 | 1 | 1 | 1 | 0 | None | 1 | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 1) Year of enrollment; 2) Triglycerides; 3) BMI; 4) FEV1 | Unmatched stratified logistic regression | Tertiles | nr | 1.37 (1.17, 1.60) | n/a | n/a | n/a | Fair
Danesh, 2000^204^ | British Regional Heart Study | General practitioners’ patient registries/random (summary for those with no baseline CHD) | 1,149 | 100 | Case=55.2 (5.3) Control=52.2 (5.3) | Case=9.5 | 1 | 1 | 1 | 1 | 0 | None | 1 | all male | 1 | 0 | 1 | 1 | 0 | 1 | 1) Town; 2) Triglycerides; 3) BMI | Unmatched stratified logistic regression | Tertiles | nr | 2.61 (1.81, 3.77) | n/a | n/a | n/a | Fair
Folsom, 2002^228^ | ARIC | Community/probability sample | 1,205 | Only reported by cohort quintile | Only reported by cohort quintile. | 3.88 | 1 | 1 | 1 | 1 | 1 | Silent MI (9.5%); and coronary revasculization (39.0%) | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1) Race; 2) Use of antihypertensives | Pooled logistic regression | Quintiles | 0.8 (0.5, 1.3) | 1.6 (1.0, 2.7) | 1.9 (1.1, 3.4) | 1.5 (0.8, 2.7) | n/a | Fair
Luc, 2003^220^ | PRIME | Community | 772 | 100 | Case=55.3 (2.9) Control=55.2 (2.7) | 5 | 1 | 1 | 1 | 1 | 1 | Angina pectoris | 1 | all male | 1 | 1 | 1 | 1 | 1 | 0 | 1) Triglycerides; 2) Time and place of recruitment | Stratified conditional logistic regression | Tertiles | 0.81 (0.47, 1.40) | 2.16 (1.26, 3.72) | n/a | n/a | n/a | Good
Pai, 2004^221^ | NHS | National sample of registered nurses in U.S. | 708 | 0 | Case=60.4 (6.5) Control=60.2 (6.5) | 8 | 1 | 1 | 1 | 1 | 1 | None | 1 | all female | 1 | 1 | 1 | 1 | 0 | 1 | 1) BMI; 2) ETOH intake; 3) Physical activity; 4) Month of sampling; 5) Parental history of CHD before 60 years old; 6) Fasting status; 7) HRT use | Unconditional logistic regression | CDC/AHA cutpoints | 1.17 (0.69, 2.00) | 1.53 (0.89, 2.62) | n/a | n/a | n/a | Good
Pai, 2004^221^ | HPFS | National sample of male health professionals in U.S. | 794 | 100 | Case=65.2 (8.3) Control=65.1 (8.3) | 6 | 1 | 1 | 1 | 1 | 1 | None | 1 | all male | 1 | 1 | 1 | 1 | 0 | 1 | 1) BMI; 2) ETOH intake; 3) Physical activity; 4) Month of sampling; 5) Parental history of CHD before 60 years old | Unconditional logistic regression | CDC/AHA cutpoints | 1.60 (1.09, 2.34) | 1.79 (1.14, 2.83) | n/a | n/a | n/a | Good
Pradhan, 2002^222^ | WHI-OS | Nation-wide, general community, post-menopausal women/random with priority for ethnic minorities | 560 | 0 | In full sample of 608: case=69.0 (6.6) control=69.0 (6.6) | 2.9 | 1 | 1 | 1 | 1 | 1 | None | 1 | all female | 1 | 1 | 1 | 1 | 0 | 1 | 1) BMI; 2) ETOH; 3) Exercise frequency; 4) Follow-up time; 5) Family history of premature CHD; 6) Ethnicity; 7) HRT use | Conditional logistic regression | Quartiles | 1.4 (0.8, 2.8) | 1.4 (0.7, 2.6) | 2.1 (1.1, 4.1) | n/a | n/a | Good
Ridker, 2000^14^ | WHS | Case and control within RCT of female postmenopausal health professionals | 366 | 0 | Case=59.3 Control=59.3 | 3 | 1 | 1 | 1 | 1 | 1 | Stroke; and coronary revasculation | 1 | all female | 1 | 1 | 1 | 1 | 0 | 0 | 1) BMI; 2) parental history of premature MI | Logistic regression | Quartiles | nr | nr | 3.1 (1.1, 8.3) | n/a | n/a | Fair
Ridker, 1998^223^ | WHS | Case and control within RCT of female postmenopausal health professionals | 366 | 0 | Case=59.3 (8.4) Control=59.3 (8.4) | 3 | 1 | 1 | 1 | 1 | 1 | Stroke; and coronary revasculation | 1 | all female | 1 | 1 | 1 | Adjusted for “hypercholesterolemia”, unspecified. | | | 1) Random assignment ASA/beta- carotene; 2)BMI; 3) Exercise; 4) Family history of CHD | Logistic regression | Quartiles | 2.0 (0.8, 4.7) | 2.3 (1.0, 5.6) | 4.1 (1.7, 9.9) | n/a | n/a | Fair
Ridker, 1997^203^ | PHS | Case and control within RCT of male health professionals | 492 | 100 | Case=58 (8.6) Control=59 (9.1) | 8 | 1 | 1 | 1 | 1 | 1 | Stroke; and venous thrombosis | 1 | all male | 1 | 1 | 1 | 0 | 0 | 0 | 1) Random assignment ASA/beta- carotene; 2) Time since randomization; 3) BMI; 4) Family history of CHD | Conditional logistic regression | Quartiles | 1.5 (0.9, 2.5) | 2.4 (1.5, 4.0) | 2.6 (1.6, 4.4) | n/a | n/a | Fair
Rifai, 2002^224^ | WHS | Case and control within RCT of female postmenopausal health professionals | 260 | 0 | Case = 60.4 Control = 60.3 | 4.8 | 1 | 1 | 1 | 1 | 1 | Stroke | 1 | all female | 1 | 1 | 1 | Adjusted for “hyperlipidemia”, unspecified. | | | 1) Random assignment ASA/beta-carotene; 2)BMI; 3) Exercise; 4) Family history of CHD | Conditional logistic regression | Quartiles | 2.9 (1.2, 7.1) | 3.4 (1.4, 8.2) | 5.6 (2.3, 13.2) | n/a | n/a | Fair
Van der Meer, 2003^225^ | Rotterdam Study | Community-based cohort | 657 | Case = 61.1 Control = 40.6 | Case = 70.8 (7.6) Control = 69.2 (8.4) | Mean not reported. Range = 4 to 8. | 1 | 1 | 1 | 1 | 1 | None | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1) Age squared; 2) BMI; 3) Family history of early MI | Logistic regression | Quartiles | 0.9 (0.5, 1.7) | 1.0 (0.5, 1.9) | 1.2 (0.6, 2.2) | n/a | n/a | Fair
Witherell, 2003^226^ | Kaiser Permanente Medical Care Program (KPMCP) | Subscribers of KPMCP in Northern California | 325 | Case = 56.2 Control = 57.4 | Case = 55.2 (7.5) Range = 40.0 to 68.2 | 5.1 | 1 | 1 | 1 | 1 | 1 | None | 1 | 1 | 1 | 0 | 1 | 0 | 0 | 1 | 1) interaction between TC and history of HTN; 2) Hx of abnormal ECG; 3) obesity; 4) race; 6) date of serum collection; 7) location of check-up | Logistic regression | Continuous | n/a | n/a | n/a | n/a | 1.3 (1.0, 1.7) [For increase in CRP level of 1 natural log (i.e., 2.72-fold)] | Fair

Abbreviations: AHA=American Heart Association, ARIC=Atherosclerosis Risk in Communities Study, ASA=Acetylsalicylic acid, BMI=body mass index, CHD=coronary heart disease, CRP=c-reactive protein, CVD=cardiovascular disease, DM=diabetes mellitus, ECG=electrocardiogram, ETOH=alcohol use, FEV=forced expiratory volume, HPFS=Health Professionals Follow-up Study, HRT=hormone replacement therapy, HTN=hypertension, MI=myocardial infarction, NHS=Nurses Health Study, PRIME=Prospective Epidemiological Study of Myocardial Infarction, RCT=randomized controlled trial, TC=total cholesterol, WHI-OS=Women’s Health Initiative Observational Study.

Risk Distribution Table 11

Distribution of CRP Levels and Clinical Characteristics for 1949 US Men 40 to 79 Years with no Prior History of CHD or CHD Equivalent^†^

| hs-CRP < 1 mg/L n = 536 Weighted n = 11,997,526 (31%) Mean (95% CI) | hs-CRP 1–3 mg/L n = 758 Weighted n =15,140,641 (39%) Mean (95% CI) | hs-CRP > 3 mg/L n =655 Weighted n = 11,917,713 (31%) Mean (95% CI)
Age, years | 51.9 (51.3, 52.4) | 53.9 (53.4, 54.4) | 55.3 (54.2, 56.5)
Total cholesterol, mg/dl | 207.9 (206.2, 209.5) | 210.9 (205.6, 216.1) | 212.6 (208.3, 216.9)
High-density lipoprotein cholesterol, mg/dl | 52.2 (51.6, 52.8) | 47.0 (44.0, 50.0) | 45.2 (44.8, 45.5)
Taking Medication for Cholesterol % | 13.3% (12.2%, 14.5%) | 16.5% (11.2%, 21.8%) | 14.0% (12.3%, 15.7%)
Systolic blood pressure, mm Hg | 124.1 (121.1, 127.0) | 127.0 (126.1, 127.8) | 130.5 (129.7, 131.3)
Taking Medication for Hypertension, % | 12.1% (9.7%, 14.4%) | 17.2% (14.9%, 19.6%) | 26.8% (22.1%, 31.5%)
Current Smoker, % | 16.7% (11.4%, 22.0%) | 21.7% (15.8%, 27.6%) | 31.4% (29.1%, 33.6%)
10 Year Risk of First Hard CHD Event^‡^, % | 7.3% (6.7%, 7.9%) | 9.7% (8.6%, 10.9%) | 11.8% (11.1%, 12.6%)
hsCRP Prevalence
Caucasian American | 30.7 (30.1, 31.4) | 39.3 (37.6, 41.1) | 29.9 (27.5, 32.3)
African American | 26.4 (19.8, 32.9) | 34.1 (27.8, 40.3) | 39.6 (39.2, 39.9)
Hispanic American | 30.4 (15.0, 45.8) | 41.0 (27.5, 54.4) | 28.7 (26.6, 30.7)

† Estimates are based on age-adjusted and population-weighted data for individuals selected from the the National Health and Nutrition Examination Survey 1999 to 2002

‡ Estimated 10-year risk for first CHD event (fatal or nonfatal myocardial infarction) based on the NCEP/ATP III risk prediction equation

Abbreviations: CHD = coronary heart disease, CI = confidence interval CRP = c-reactive protein.

Risk Distribution Table 12

Distribution of CRP Levels and Clinical Characteristics for 2070 US Women 40 to 79 Years with no Prior History or CHD or CHD Equivalent^†^

| hs-CRP < 1 mg/L n = 365 Weighted n = 10,050,739(22%) Mean (95% CI) | hs-CRP 1–3 mg/L n = 648 Weighted n = 14,202,955 (31%) Mean (95% CI) | hs-CRP > 3 mg/L n = 1,057 Weighted n = 21,129,161 (47%) Mean (95% CI)
Age, years | 51.8 (50.6, 53.0) | 56.1 (56.0, 56.3) | 56.2 (55.6, 56.7)
Total cholesterol, mg/dl | 203.8 (200.2, 207.3) | 215.5 (214.3, 216.7) | 216.8 (216.5, 217.1)
High-density lipoprotein cholesterol, mg/dl | 62.8 (60.0, 65.6) | 59.6 (58.6, 60.5) | 55.8 (54.5, 57.1)
Taking Medication for Cholesterol % | 9.2% (7.8%, 10.7%) | 16.5% (15.5%, 17.4%) | 15.1% (14.0%, 16.1%)
Systolic blood pressure, mm Hg | 122.3 (119.5, 125.2) | 128.8 (126.7, 130.9) | 132.0 (128.3, 135.7)
Hypertension treatment, % | 12.0% (5.2%, 18.8%) | 25.0% (19.5%, 30.5%) | 32.1% (23.0%, 41.1%)
Current Smoker, % | 18.3% (14.8%, 21.9%) | 18.6% (18.4%, 18.9%) | 17.2% (16.8%, 17.6%)
10 Year Risk of First Hard CHD Event^‡^, % | 2.0% (1.7%, 2.4%) | 3.4% (2.9%, 3.9%) | 3.9% (3.6%, 4.2%)
Prevalence of hs-CRP
Caucasian American | 23.3 (18.9, 27.7) | 31.4 (27.7, 35.1) | 45.2 (43.7, 46.8)
African American | 15.0 (13.9, 16.1) | 30.0 (29.6, 30.3) | 55.0 (54.0, 56.0)
Hispanic American | 13.5 (6.8, 20.2) | 33.4 (26.4, 40.5) | 53.1 (52.8, 53.4)

† Estimates are based on age-adjusted and population-weighted data for individuals selected from the the National Health and Nutrition Examination Survey 1999 to 2002

‡ Estimated 10-year risk for first CHD event (fatal or nonfatal myocardial infarction) based on the NCEP/ATP III risk prediction equation

Abbreviations: CHD = coronary heart disease, CI = confidence interval, CRP = c-reactive protein.

Risk Distribution Table 13

Risk for First Hard CHD Event Among US Adults Age 40 to 79 Years Before and After Adjustment for Risk Related to CRP^†^

| | 10-Year Risk for CHD, % of Weighted Population, (95% CI)
| | Before Adjustment for CRP § | | | After Adjustment for CRP
| n (weighted n) | <10% | 10–20% | >20% | <10% | 10–20% | >20%
Men
40–49 | 646 (16,851,595) | 87.8 (86.5 ,89.0) | 11.1 (7.8 ,14.3) | 1.2 (0.0 ,3.2) | 86.0 (85.6 ,86.4) | 12.6 (10.2 ,15.1) | 1.4 (0.0 ,3.5)
50–59 | 457 (11,314,783) | 67.5 (64.4 ,70.5) | 28.1 (21.6 ,34.7) | 4.4 (0.8 ,8.0) | 64.8 (58.7 ,70.8) | 27.9 (25.3 ,30.5) | 7.3 (3.4 ,11.2)
60–69 | 493 (6,536,782) | 15.7 (13.9 ,17.6) | 70.8 (64.5 ,77.1) | 13.5 (5.4 ,21.6) | 23.2 (22.0 ,24.5) | 60.2 (49.8 ,70.6) | 16.6 (5.8 ,27.5)
70–79 | 353 (4,352,720) | 1.8 (0.0 ,5.2) | 53.0 (48.8 ,57.2) | 45.2 (41.1 ,49.2) | 3.6 (2.2 ,5.1) | 49.1 (46.2 ,52.0) | 47.3 (43.6 ,51.0)
Total | 1,949 (39,055,881) | 60.3 (60.0 ,60.5) | 30.7 (29.5 ,31.8) | 9.1 (8.1 ,10.0) | 60.1 (57.5 ,62.8) | 29.1 (25.2 ,32.9) | 10.8 (9.5 ,12.0)
Women
40–49^‡^ | 662 (17,798,619) | 99.4 (99.2 ,99.5) | 0.5 (0.4 ,0.6) | 0.1 (0.0 ,0.3) | 99.1 (98.8 ,99.5) | 0.8 (0.2 ,1.3) | 0.1 (0.0 ,0.3)
50–59^‡^ | 473 (12,317,649) | 98.1 (98.0 ,98.2) | 1.6 (1.0 ,2.3) | 0.3 (0.0 ,1.0) | 98.0 (97.2 ,98.9) | 1.7 (1.5 ,1.8) | 0.3 (0.0 ,1.0)
60–69 | 556 (8,185,685) | 90.5 (84.9 ,96.1) | 9.0 (4.0 ,14.0) | 0.5 (0.0 ,1.1) | 88.5 (86.1 ,90.9) | 10.4 (9.9 ,11.0) | 1.0 (0.0 ,3.0)
70–79 | 379 (7,080,903) | 66.3 (65.0 ,67.5) | 30.6 (28.5 ,32.7) | 3.1 (2.2 ,4.0) | 67.7 (61.0 ,74.3) | 27.7 (20.0 ,35.4) | 4.6 (3.5 ,5.7)
Total | 2,070 (45,382,856) | 92.3 (84.9 ,96.1) | 7.0 (4.0 ,14.0) | 0.7 (0.0 ,1.1) | 88.5 (86.1 ,90.9) | 10.4 (9.9 ,11.0) | 1.0 (0.0 ,3.0)
Race/Ethnicity
Men
Caucasian | 978 (30,460,553) | 59.8 (58.8 ,60.8) | 31 (30.3 ,31.7) | 9.2 (8.4 ,9.9) | 59.3 (59.0 ,59.6) | 29.9 (28.7 ,31.1) | 10.8 (9.9 ,11.7)
African American | 371 (3,502,278) | 59.7 (56.0 ,63.4) | 31.0 (28.5 ,33.6) | 9.3 (3.0 ,15.5) | 60.6 (59.0 ,62.2) | 27.9 (25.1 ,30.6) | 11.5 (7.1 ,15.9)
Hispanic | 561 (4,034,941) | 66.6 (58.9 ,74.3) | 25.0 (19.6 ,30.5) | 8.4 (6.0 ,10.7) | 64.8 (47.6 ,82.0) | 25.0 (7.8 ,42.2) | 10.1 (9.8 ,10.5)
Women
Caucasian | 1,012 (34,562,831) | 92.3 (91.3 ,93.3) | 7.1 (6.8 ,7.4) | 0.6 (0.0 ,1.3) | 91.8 (91.3 ,92.4) | 7.2 (6.5 ,7.8) | 1.0 (0.0 ,2.1)
African American | 382 (4,267,199) | 91.2 (86.2 ,96.2) | 7.5 (3.6 ,11.4) | 1.3 (0.2 ,2.4) | 90.2 (86.7 ,93.7) | 8.0 (5.9 ,10.0) | 1.8 (0.3 ,3.2)
Hispanic | 625 (4,844,679) | 93.7 (93.5 ,93.9) | 5.4 (4.5 ,6.3) | 0.9 (0.0 ,2.0) | 92.8 (89.0 ,96.6) | 6.2 (3.2 ,9.2) | 1.0 (0.2 ,1.9)

† Estimates are based on age-adjusted and population-weighted data for individuals from the National Health and Nutrition Examination Survey 1999 to 2002 with no prior history of CHD or CHD equivalent

§ Estimated 10-year risk for first CHD event (recognized or unrecognized myocardial infarction or coronary death) based on the NCEP/ATP III risk prediction equation

‡ Estimate unstable due to small sample size.

Abbreviations: CHD = coronary heart disease, CRP = c-reactive protein.

Risk Distribution Table 14

Distribution of Expected CHD Events at 10 Years Among US Adult Population 40 to 79 Years Old with 10–20% 10-Year Risk Before and After Adjustment for Risk Associated with CRP*

| | Before Adjustment for CRP | | | After adjustment for CRP
| | Number at Risk weighted n | 10-Year Risk for CHD Events, % | Expected CHD Events,^†^ weighted n | Number at Risk for CHD Events at 10 Years by Risk Category weighted n (% Total) | | | 10-Year Risk for CHD Events, % | | | Expected CHD Events at 10 years by Risk Category weighted n (% Total) | | | CHD Events per 1000 Persons Averted with Treatment^§^
Men | Age, yr | 10–20% | 10–20% | 10–20% | <10% | 10–20% | >20% | <10% | 10–20% | >20% | <10% | 10–20% | >20% | n/1000
| 40–49^‡^ | 1,863,023 | 13.8% | 257,221 | 187,343 (10.1%) | 1,616,219 (86.8%) | 59,462 (3.2%) | 8.1% | 14.2% | 20.9% | 15,106 (5.9%) | 229,691 (89.3%) | 12,424 (4.8%) | 14.5
| 50–59 | 3,182,698 | 14.0% | 444,077 | 409,889 (12.9%) | 2,415,479 (75.9%) | 357,330 (11.2%) | 8.9% | 13.7% | 21.7% | 36,611 (8.2%) | 329,947 (74.3%) | 77,519 (17.5%) | 52.4
| 60–69 | 4,628,912 | 14.6% | 673,710 | 703,156 (15.2%) | 3,480,548 (75.2%) | 445,209 (9.6%) | 9.0% | 14.7% | 21.9% | 63,161 (9.4%) | 513,204 (76.2%) | 97,346 (14.4%) | 43.3
| 70–79 | 2,307,221 | 16.1% | 371,580 | 79,811 (3.5%) | 1,817,562 (78.8%) | 409,848 (17.8%) | 9.0% | 15.0% | 22.2% | 7,184 (1.9%) | 273,260 (73.5%) | 91,136 (24.5%) | 73.6
| Total | 11,981,854 | 14.6% | 1,746,589 | 1,380,198 (11.5%) | 9,329,808 (77.9%) | 1,271,849 (10.6%) | 8.8% | 14.4% | 21.9% | 122,062 (7.0%) | 1,346,102 (77.1%) | 278,426 (15.9%) | 47.8
Women | Age, yr | 10–20% | 10–20% | 10–20% | <10% | 10–20% | >20% | <10% | 10–20% | >20% | <10% | 10–20% | >20% | n/1000
| 40–49^‡^ | 93,394 | 15.7% | 14,650 | | 93,394 (100.0%) | | | 15.7% | | | 14,650 (100%) | | —
| 50–59^‡^ | 197,679 | 12.4% | 24,474 | 62,980 (31.9%) | 134,699 (68.1%) | | 8.0% | 14.4% | | 5,030 (20.6%) | 19,444 (79.4%) | | —
| 60–69^‡^ | 736,351 | 13.7% | 100,696 | 101,060 (13.7%) | 582,107 (79.1%) | 53,185 (7.2%) | 7.7% | 14.0% | 21.8% | 7,780 (7.7%) | 81,343 (80.8%) | 11,573 (11.5%) | 34.5
| 70–79^‡^ | 2,168,696 | 13.4% | 291,120 | 515,720 (23.8%) | 1,514,005 (69.8%) | 138,971 (6.4%) | 8.7% | 14.3% | 21.2% | 44,651 (15.3%) | 217,060 (74.6%) | 29,409 (10.1%) | 30.3
| Total | 3,196,119 | 13.5% | 430,939 | 679,760 (21.3%) | 2,324,204 (72.7%) | 192,156 (6.0%) | 8.5% | 14.3% | 21.3% | 57,461 (13.3%) | 332,497 (77.2%) | 40,981 (9.5%) | 28.5

* Estimates are based on age-adjusted and population-weighted data for individuals from the National Health and Nutrition Examination Survey 1999 to 2002 with no prior history of CHD or CHD equivalent

† Estimated 10-year risk for first CHD event (recognized or unrecognized myocardial infarction or coronary death) based on the NCEP/ATP III risk prediction equation

‡ Estimates unstable due to small sample size.

Abbreviations: CHD = coronary heart disease, CRP = c-reactive protein.

§ Based on treatment of individuals with >20% 10-year risk for CHD events after adjustment of CRP assuming 30% reduction in the 10-year risk of CHD events and 100% compliance with treatment.

Risk Distribution Table 15

Clinical Characteristics of US Men 40 to 79 Years wtih 10–20% 10-Year CHD Risk After Adjustment of CRP^†^

| 10-Year Risk for CHD Events, %
| 10–20% | >20%
n (weighted n) | 565 (9,329,808) | 93 (1,271,849)
Age, years | 60.4 (59.9, 60.9) | 64.4 (63.9, 64.8)
Total cholesterol, mg/dl | 216.2 (216.2, 216.3) | 224.7 (218.8, 230.7)
High-density lipoprotein cholesterol, mg/dl | 46.8 (46.1, 47.5) | 45.6 (44.0, 47.1)
Taking Medication for Cholesterol % | 15.4% (3.1%, 27.6%) | 22.3% (19.8%, 24.8%)
Systolic blood pressure, mm Hg | 131.4 (130.2, 132.6) | 137.2 (136.1, 138.4)
Taking Medication for Hypertension, % | 26.1% (20.8%, 31.3%) | 36.0% (20.8%, 51.2%)
Current Smoker, % | 37.4% (34.9%, 39.9%) | 36.0% (16.7%, 55.3%)
10 Year Risk of “Hard” CHD Event^‡^, % | 14.4% (13.9%, 14.9%) | 21.9% (21.8%, 22.0%)

† Estimates are based on age-adjusted and population-weighted data for individuals selected from the the National Health and Nutrition Examination Survey 1999 to 2002 with no history of CHD or CHD Equivalent

‡ Estimated 10-year risk for first CHD event (recognized or unrecognized myocardial infarction or coronary death) based on the NCEP/ATP III risk prediction equation after adjustment for risk related to CRP

Abbreviations: CHD = coronary heart disease, CRP = c-reactive protein.