# Appendix II Inclusion/Exclusion Criteria

All risk factors used the below inclusion/exclusion criteria to determine included studies:

Include | - Minimum outcomes: coronary deaths & non-fatal myocardial infarction; - Appropriate measures of Framingham variables (Age, sex, LDL, HDL, total cholesterol, diabetes, smoking status, hypertension); - & at least one novel risk factor; - Cohort, nested case-control, cardiovascular trial follow-up study (or systematic review or meta-analysis of these study types) that measures a novel risk factor and estimates its predictive value after adjusting for Framingham variables
Exclude | - No data; - Population or sub-population with known coronary disease or coronary disease equivalent (e.g., diabetes); - Does not include minimum outcomes; - Does not measure Framingham variables appropriately; - Wrong study design/article format