# Appendix I Search Strategies

Search Terms: Appropriate terms were selected in conjunction with a medical research librarian and experts in the field, and individual search strategies were created to retrieve the literature pertaining to novel risk factors for intermediate risk of coronary heart failure.

## MEDLINE

### Ankle Brachial Index

1 | exp cohort studies/
2 | exp Cardiovascular Diseases/
3 | 1 and 2
4 | (ankle brachial blood pressure or ankle brachial pressure or ankle brachial index).mp.
5 | abi.mp.
6 | exp Blood Pressure/
7 | ankle.mp. or exp ANKLE/
8 | 4 or 5
9 | 6 and 7
10 | 8 or 9
11 | 3 and 10
12 | limit 11 to english language

### C-reactive Protein

1 | exp cohort studies/
2 | exp Cardiovascular Diseases/
3 | 1 and 2
4 | exp C-Reactive Protein/
5 | exp Inflammation/and exp Biological Markers/
6 | 3 and 5
7 | 3 and 4
8 | 6 or 7

### Carotid Intima-media Thickness

1 | exp cohort studies/
2 | exp Cardiovascular Diseases/
3 | 1 and 2
4 | exp tunica intima/or exp tunica media/
5 | exp carotid arteries/
6 | 4 and 5
7 | 3 and 6
8 | ((Intima-media thick$ or imt) adj5 carotid).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
9 | 3 and 8
10 | (carotid adj3 thick$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
11 | 3 and 10
12 | 7 or 9 or 11

### Electron Beam Tomography

1 | exp cohort studies/
2 | exp Cardiovascular Diseases/
3 | 1 and 2
4 | (electron beam computed tomograph$ or ebct).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
5 | 3 and 4
6 | exp Tomography, X-Ray Computed/
7 | electron beam$.mp.
8 | 6 and 7
9 | 3 and 8
10 | 5 or 9

### Homocysteine

1 | exp cohort studies/
2 | exp Cardiovascular Diseases/
3 | 1 and 2
4 | exp HOMOCYSTEINE/or homocysteine$.mp. or hyperhomocysteinem$.mp. or Cystathionine beta-Synthase.mp.
5 | 3 and 4

### Impaired Fasting Glucose

1 | exp cohort studies/
2 | exp Cardiovascular Diseases/
3 | 1 and 2
4 | exp Fasting/and exp Blood Glucose/
5 | 3 and 4
6 | exp Glucose Intolerance/or exp Glucose Tolerance Test/
7 | 3 and 6
8 | (fasting glucose adj3 (impair$ or lower$)).mp. [mp=title, original title, abstract, name of substance, mesh subject heading]
9 | 3 and 8
10 | 5 or 9

### Lipoprotein(a)

1 | exp cohort studies/
2 | exp cardiovascular diseases/
3 | 1 and 2
4 | small dense ldl.mp.
5 | small dense low density lipoprot$.mp.
6 | (oxidiz$ adj1 (ldl or low density lipoprot$)).mp.
7 | apolipoprotein$.mp.
8 | exp Apolipoproteins/
9 | triglyceride rich lipoprotein$.mp.
10 | lipoprotein a.mp. or exp “Lipoprotein(a)”/
11 | (lpa or “lp(a)”).mp.
12 | (lipoprot$ adj3 remnant$).mp.
13 | ((high density lipoprot$ or hdl) adj subfraction$).mp.
14 | 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13
15 | 3 and 14

### Periodontal Disease

1 | exp cohort studies/
2 | exp Cardiovascular Diseases/
3 | 1 and 2
4 | exp Periodontal Diseases/
5 | 3 and 4

### White Blood Cell Count

1 | exp Cardiovascular Diseases/
2 | exp cohort studies/
3 | 1 and 2
4 | exp C-Reactive Protein/
5 | exp inflammation/and exp Biological markers/
6 | 4 or 5
7 | 6 and 3
8 | exp leukocyte count/
9 | 8 and 3
10 | 9 not 7
11 | 8 and 1