# References

1 Ip S, Glicken S, Kulig J, O’'Brien R, Sege R. Management of neonatal hyperbilirubinemia. Evid Rep Technol Assess (Summ). Nov. 2002;(65):1-5.
2 Kernicterus threatens healthy newborns. Sentinel Event Alert. Apr. 2001;(18):1-4.
3 Management of hyperbilirubinemia in the newborn infant 35 or more weeks of gestation. Pediatrics. 2004;114(1):297-316. [pmid: 15231951].
4 Bhutani VK, Johnson LH, Schwoebel A, Gennaro S. A systems approach for neonatal hyperbilirubinemia in term and near-term newborns. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2006;35(4):444-455.
5 Chou SC, Palmer RH, Ezhuthachan S, et al. Management of hyperbilirubinemia in newborns: measuring performance by using a benchmarking model. Pediatrics. 2003;112(6 Pt 1):1264-1273. [pmid: 14654595].
6 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
7 Jaeschke R, Guyatt GH, Sackett DL. Users’ guides to the medical literature, III: How to use an article about a diagnostic test. What are the results and will they help me in caring for my patients? The Evidence-Based Medicine Working Group. JAMA. 1994;271(9):703-707. [pmid: 8309035].
8 Keren R, Bhutani VK, Luan X, et al. Identifying newborns at risk of significant hyperbilirubinaemia: a comparison of two recommended approaches. Arch Dis Child. 2005;90(4):415-421. [pmid: 15781937].
9 Newman TB, Liljestrand P, Escobar GJ. Combining clinical risk factors with serum bilirubin levels to predict hyperbilirubinemia in newborns. Arch Pediatr Adolesc Med. 2005;159(2):113-119. [pmid: 15699303].
10 Sarici SU, Serdar MA, Korkmaz A, et al. Incidence, course, and prediction of hyperbilirubinemia in near-term and term newborns. Pediatrics. 2004;113(4):775-780. [pmid: 15060227].
11 Agarwal R, Kaushal M, Aggarwal R, Paul VK, Deorari AK. Early neonatal hyperbilirubinemia using first day serum bilirubin level. Indian Pediatr. 2002;39(8):724-730. [pmid: 12196683].
12 Sanpavat S, Nuchprayoon I, Smathakanee C, Hansuebsai R. Nomogram for prediction of the risk of neonatal hyperbilirubinemia, using transcutaneous bilirubin. J Med Assoc Thai. 2005;88(9):1187-1193. [pmid: 16536103].
13 Petersen JR, Okorodudu AO, Mohammad AA, Fernando A, Shattuck KE. Association of transcutaneous bilirubin testing in hospital with decreased readmission rate for hyperbilirubinemia. Clin Chem. 2005;51(3):540-544. [pmid: 15738516].
14 Ho HT, Ng TK, Tsui KC, Lo YC. Evaluation of a new transcutaneous bilirubinometer in Chinese newborns. Arch Dis Child Fetal Neonatal Ed. 2006;91(6):F434-F438. [pmid: 16849367].
15 Eggert LD, Wiedmeier SE, Wilson J, Christensen RD. The effect of instituting a prehospital-discharge newborn bilirubin screening program in an 18-hospital health system. Pediatrics. 2006;117(5):e855-e862. [pmid: 16651290].
16 Bader D, Kugelman A, Blum DE, Riskin A, Tirosh E. Effect of phototherapy on cardiorespiratory activity during sleep in neonates with physiologic jaundice. Isr Med Assoc J. 2006;8(1):12-16. [pmid: 16450744].
17 Boo NY, Chew EL. A randomised control trial of clingfilm for prevention of hypothermia in term infants during phototherapy. Singapore Med J. 2006;47(9):757-762. [pmid: 16924356].
18 Djokomuljanto S, Quah BS, Surini Y, et al. Efficacy of phototherapy for neonatal jaundice is increased by the use of low-cost white reflecting curtains. Arch Dis Child Fetal Neonatal Ed. 2006;91(6):F439-F442. [pmid: 16877479].
19 Matichard E, Le Hénanff A, Sanders A, et al. Effect of neonatal phototherapy on melanocytic nevus count in children. Arch Dermatol. 2006;142(12):1599-1604. [pmid: 17178986].
20 Nuntnarumit P, Naka C. Comparison of the effectiveness between the adapted-double phototherapy versus conventional-single phototherapy. J Med Assoc Thai. 2002;85(Suppl 4):S1159-S1166. [pmid: 12549790].
21 Sarici SU, Alpay F, Dundaroz MR, Ozcan O, Gokcay E. Fiberoptic phototherapy versus conventional daylight phototherapy for hyperbilirubinemia of term newborns. Turk J Pediatr. 2001;43(4):280-285. [pmid: 11765155].
22 Seidman DS, Moise J, Ergaz Z, et al. A prospective randomized controlled study of phototherapy using blue and blue-green light-emitting devices, and conventional halogen-quartz phototherapy. J Perinatol. 2003;23(2):123-127. [pmid: 12673261].
23 Turan O, Ergenekon E, Koc E, et al. Impact of phototherapy on vasoactive mediators: NO and VEGF in the newborn. JPerinat Med. 2004;32(4):359-364. [pmid: 15346824].
24 Zainab K, Adlina S. Effectiveness of home versus hospital phototherapy for term infants with uncomplicated hyperbilirubinemia: a pilot study in Pahang, Malaysia. Med J Malaysia. 2004;59(3):395-401. [pmid: 15727387].
25 Newman TB, Xiong B, Gonzales VM, Escobar GJ. Prediction and prevention of extreme neonatal hyperbilirubinemia in a mature health maintenance organization. Arch Pediatr Adolesc Med. 2000;154(11):1140-1147. [pmid: 11074857].
26 Rutjes AW, Reitsma JB, Di Nisio M, et al. Evidence of bias and variation in diagnostic accuracy studies. CMAJ. 2006;174(4):469-476. [pmid: 16477057].
27 Ebbesen F. Recurrence of kernicterus in term and near-term infants in Denmark. Acta Paediatr. 2000;89(10):1213-1217. [pmid: 11083378].
28 Wu PY, Hodgman JE, Kirkpatrick BV, White NB Jr, Bryla DA. Metabolic aspects of phototherapy. Pediatrics. 1985;75(2 Pt 2):427-433. [pmid: 3969353].
29 Dahlquist G, Kallen B. Indications that phototherapy is a risk factor for insulin-dependent diabetes. Diabetes Care. 2003;26(1):247-248. [pmid: 12502692].