# Acknowledgments

The authors acknowledge AHRQ Medical Officer Iris Mabry-Hernandez, MD, MPH; AHRQ Task Order Officer Therese Miller, DrPH; and U.S. Preventive Services Task Force leads Thomas DeWitt, MD; Michael Le Fevre, MD, MSPH; and Virginia Moyer, MD, MPH for their contributions to this report.