# Discussion

This report is prepared for the USPSTF for use in drafting a set of statements concerning screening for neonatal hyperbilirubinemia. Whether screening for neonatal hyperbilirubinemia should be implemented is not addressed in this report. We only critically examined the evidence concerning the effectiveness of various screening strategies published in the literature.

## Key Question 1

A study that directly evaluates the effectiveness of different strategies to reduce the incidence of acute or chronic bilirubin encephalopathy is not feasible given the rare occurrence of kernicterus (one estimate of the prevalence of kernicterus was 1.87 cases per 100,000 live births27). One would have to perform a very large (cluster) randomized trial to evaluate the effectiveness of a particular strategy versus standard care in reducing the incidence of kernicterus in the general population. For practical consideration, studies on the effectiveness of different strategies to reduce the incidence of bilirubin encephalopathy could only rely on a surrogate outcome like serum bilirubin level.

## Key Question 2

Overall, the data suggest comparable predictability of the risk score developed by Keren et al.8 and the modified risk index (without family history of jaundice in a newborn) developed by Newman et al.9 in predicting later significant hyperbilirubinemia. Significant hyperbilirubinemia was defined as a post-discharge TSB greater than 95^th^ percentile on the hour-specific bilirubin nomogram in one study8 and as a TSB ≥ 25 mg/dL the first 30 days after birth in the other study.9 The risk score instruments used in the aforementioned studies predict significant hyperbilirubinemia had only two risk factors in common, namely exclusive breastfeeding and gestational age (gestational age was evaluated differently, as shown in Table 1). Therefore, the same infant may receive different risk scores with the two risk assessment instruments. Furthermore, the risk score and risk index (without family history of jaundice in a newborn) had not yet been independently verified in another population.

The original risk index (with family history of jaundice in a newborn) developed by Newman et al. in 2000^25^ had been independently verified in their later study and showed that eliminating the family history variable had little effect on the prediction of later significant hyperbilirubinemia.9

## Key Question 3

### Ability of early TSB measurements to predict high late TSB measurements

Three fair quality studies,8–10 and one poor quality study11 provided relevant data on the ability of early TSB measurements to predict high late TSB measurements. In three studies, the reference standard was a post-discharge measurement above the hour-specific 95^th^ percentile, and in the other study was a TSB greater than 20 mg/dL (which is above the 95^th^ percentile at 48 hours or later).9 The timing of the reference measurement varied between 48 to 150 hours. Overall, the four studies suggest comparable diagnostic abilities of early TSB measurements to predict late high TSB measurements.

### Ability of TcB measurements to identify TSB indicating need for phototherapy

Two poor quality studies provided relevant data on the ability of TcB measurements to identify TSB indicating the need for phototherapy.12,14 TSB cutoffs suggesting need for phototherapy were defined quite differently in these two studies. TcB measurements less than specific thresholds (the 75^th^ hour-specific percentile in one study14 and the 90^th^ in the other12) may predict TSB measurements that do not indicate the need for phototherapy. The later study had overt verification bias.12

### Combination of the risk index with early TSB levels

Results from one fair quality study comparing the ability of various screening strategies in predicting later hyperbilirubinemia suggest that the combination of the modified risk index with early TSB levels significantly enhanced prediction than using either one of the screening strategies alone.9

## Key Question 4

None of the studies in this review assessed potential harms of screening. Nevertheless, the potential harms of any form of screening should be carefully considered and monitored in any strategy.

## Key Question 5

Studies in this review did not evaluate the effectiveness of phototherapy in reducing the risk of bilirubin encephalopathy. Our previous review reported that one needs to treat six to ten otherwise healthy jaundiced neonates with TSB ≥ 15 mg/dL by phototherapy in order to prevent the TSB in one infant from rising above 20 mg/dL.1

## Key Question 6

This group of studies reporting on adverse or other effects associated with phototherapy had relatively small number (10 to 104) of subjects, compared to the 1974–1976 National Institute of Child Health and Human Development (NICHD) phototherapy trial where 672 infants received phototherapy and 667 infants did not. The NICHD trial found that term-infants who were treated with phototherapy tended to pass more stools and lose more weight during phototherapy than the control infants.28 In our review, one study reported changes in cardiopulmonary parameters while under phototherapy, although the clinical significance of these findings is unclear. One retrospective study found an association in children between sizes of melanocytic nevi and exposure to neonatal phototherapy. The study did not control for the number of melanocytic nevi in the parents. Also, how the subjects were selected for the study was not adequately explained. With these limitations in mind, it is difficult to agree with the conclusion proffered by the study authors that “intensive neonatal phototherapy is a strong risk factor for nevus development in childhood”. One study reported that one-third of the infants had an increase in core temperature after 2 hours of phototherapy; it also found a small proportion (~2%) of the infants had a decrease in core temperature after 2 hours of phototherapy. These findings emphasized the need to monitor infant’s temperature while undergoing phototherapy. One reviewer of this report alerted us to a published letter from Sweden suggesting that a history of phototherapy may be associated with an increased risk of type 1 diabetes.29 This letter did not provide detailed methodological information and therefore, it was difficult to assess the validity of this finding. Nonetheless, this is a potential harm that bears further investigation, although the mechanism behind the reported association is unknown.

## Limitations

First, because this is an update of our previous report, studies published prior to 2001 (search date of the previous report) that may provide potentially useful information were not included. Second, the number of eligible studies that addressed the key questions was limited, and none was graded good methodological quality. Of the included studies, half were of fair quality and half were of poor quality. Finally, because of the small number of studies and the clinical and methodological between study heterogeneity, we did not perform quantitative analyses.

## Future Research

In principle, a pragmatic (cluster) randomized controlled trial comparing different strategies would give the most definitive answer on which strategy can identify most infants developing severe hyperbilirubinemia. However, because severe hyperbilirubinemia is a relatively rare event (and because of the clustered design), tens of thousands of infants per arm would be needed to attain statistical power. This poses questions on the feasibility of this task. Alternative options (without the internal validity of a randomized trial) exist. As of this writing, the diagnostic ability of strategies that combine risk factors and early TSB measurements has not been verified in an independent sample. A prospective independent validation study could compare multiple screening strategies (e.g., risk factors only, early TSB only and combination thereof) in the same infants. This may inform on the incremental predictive ability of different strategies in an independent setting. It will improve the quality of the data in this field if the reporting of acute and chronic bilirubin encephalopathy is made mandatory. Future studies on preventive and screening strategies should actively monitor the potential harms from implementing such strategies in both infants and their family members. Prospective and properly controlled study will be helpful in clarifying the relationship between exposure to neonatal phototherapy and the development of melanocytic nevi.