# Results

Our search yielded 742 abstracts, of which 646 were rejected after initial abstract screening using very broad inclusion/exclusion criteria. Ninety-six articles were retrieved for full text examination. Full-text screening using the formal criteria rejected additional 79 articles. The following studies met our inclusion/exclusion criteria: Three studies in two publications addressed key question 2 (Does risk factor assessment accurately identify infants who may benefit from bilirubin testing?),8,9 nine studies addressed key question 3 (Does bilirubin testing accurately identify infants who may benefit from phototherapy?),4,8–15 and nine studies addressed key question 6 (What are the harms of treatment with phototherapy?).16–24 Of the 11 studies that addressed key questions 2 and 3, five were of fair quality; six were of poor quality ( Figure 2 ). There was no good quality study. We did not grade the methodological quality for the nine studies that addressed key question 6.

Figure 2 Study Eligibility Flow Chart

Key: ETCO=End-tidal carbon monoxide; TSB=total serum bilirubin

This figure depicts a flow chart for the study eligibility of the search results for hyperbilirubinemia screening. A rectangle at the top of the chart, on the left-hand side, reads “Citations identified in MEDLINE from 2001 to August Week 1 2007 (n=742).” An arrow proceeds straight down from this rectangle, and forks at the midpoint. At the fork, a horizontal arrow points to the right, to a second rectangle that reads “excluded* (n=645).” The forked arrow continues down to a third rectangle that reads “Full-text articles considered for inclusion (n=97).” An arrow proceeds straight down from this rectangle, and forks at the midpoint. At the fork, a horizontal arrow points to the right, to a fourth rectangle that reads “excluded* (n=79).” The forked arrow continues down to a fifth rectangle that reads “Full-text articles reviewed (n=18).” An arrow proceeds straight down from this rectangle, and forks at the midpoint. At the fork, a horizontal arrow points to the left and down to a sixth rectangle that reads: Q1: n=0; Q2: n=2 superscript "a" (2 fair). The superscript “a” refers to a footnote that explains that two articles provided data for both Q2 and Q3. Q3: n=9 superscript "a" (3 fair; 6 poor); Q4: n=0; Q5: n=0. The forked arrow continues to the right and down to a seventh rectangle that reads “Q6: Adverse events or other effects of phototherapy (n=9) superscript "b".” The superscript “b” refers to a footnote that explains that Q6 articles were not graded for methodological quality. To the right of the entire flow chart is a box reading: General exclusion criteria for Q1 through Q5: Review articles, letter to the editors, or case reports; Not relevant or no outcome; No comparison group; Preterm infants; Studies included only infants with evidence of hemolysis before discharge. Additional exclusion criteria for Q3: Studies on clinical or maternal assessments of jaundice, cord blood bilirubin, ETCO, or umbilical cord alpha-fetoprotein alone; Studies reported correlation coefficients and/or Bland-Altman limit of agreement data only; No data on the timing of measurements; Data were insufficient to determine the percentile of TSB. Additional exclusion criteria for Q5: Treatments were not phototherapy. Additional exclusion criteria for Q6: Adverse events were not reported; Adverse events for exchange transfusion only; No usable numerical data. A legend at the bottom of the figure reads “ETCO=End-tidal carbon monoxide; TSB=Total serum bilirubin.”

## Key Question 1. Does screening using risk factor assessment and/or bilirubin testing reduce the incidence of acute or chronic bilirubin encephalopathy?

There was no study that directly addressed this question. In the United States, acute or chronic bilirubin encephalopathy is not a mandated reportable condition and therefore, the true incidence and prevalence could not be reliably ascertained. Studies could only measure the effectiveness of using risk factor assessment and/or bilirubin testing to reduce the incidence of specific levels of hyperbilirubinemia (e.g., ≥ 20 mg/dL, ≥ 25 mg/dL, ≥ 35 mg/dL) (see answers to questions 2 and 3), but not the incidence of bilirubin encephalopathy as not every infant with hyperbilirubinemia develops bilirubin encephalopathy.

## Key Question 2. Does risk factor assessment accurately identify infants who may benefit from bilirubin testing?

One retrospective cohort study,8 and one nested case-control study and retrospective cohort study published in the same article9 examined the predictability using risk score or risk index for developing significant hyperbilirubinemia. All three studies were graded fair quality.

### Sampling of infants in each study

Keren 2005 retrospectively included all healthy term and near-term infants who participated in the hospital’s early discharge followup program and who had both pre- and post-discharge TSBs measured in the study period. Newman 2005 (Study 1) was a nested case-control study. The cases were all term and near-term infants with a maximum TSB ≥25 mg/dL in the first 30 days after birth, and the controls were randomly sampled from the cohort in the study period. Newman 2005 (Study 2) retrospectively included all infants discharged before 48 hours after birth who had a TSB measured before 48 hours in the study period. Infants with a TSB ≥20 mg/dL before 48 hours were excluded.

### Significant hyperbilirubinemia - reference standard

In Keren 2005, the outcome of significant hyperbilirubinemia was defined as a post-discharge TSB greater than 95^th^ percentile on the hour-specific bilirubin nomogram, which is nearly identical to the phototherapy threshold curve recommended for “medium risk” infants in the AAP’s 2004 clinical practice guideline. In Newman 2005 (Study 1), the outcome of significant hyperbilirubinemia was defined as a TSB ≥25 mg/dL in the first 30 days after birth. In Newman 2005 (Study 2), the outcome of significant hyperbilirubinemia was defined as a TSB ≥20 mg/dL at 48 hours or older after birth.

### Risk scores or risk indexes that predict significant hyperbilirubinemia

There were no common risk factors that predict significant hyperbilirubinemia included in the calculation of the risk score or risk index between Keren 2005 and Newman 2005, except for exclusive breastfeeding and gestational age ( Table 1 ). Calculation of the risk score from gestational age was handled differently between the two studies. Newman 2005 study aimed to validate a risk index for predicting significant hyperbilirubinemia that they previously developed and published in 2000.^25^ The Newman 2000 study has been summarized in our previous report and the detailed results are presented in Appendix F. However, in contrast to the original risk index, family history of jaundice was removed from the list of risk factors used to calculate the risk index in Newman 2005 study ( Table 1 ).

### Methodological comments

The risk score in Keren 2005 and the modified risk index in Newman 2005 had not yet been independently verified in another population. If a predictive score was derived in the same population that used to assess the predictability (e.g., sensitivity, specificity) for the outcome, the predictive model is almost always optimistically biased. Moreover, diagnostic studies of highly selected cases versus controls often show improved diagnostic ability compared with prospective cohort studies.26

### Ability of risk factor scores/indexes to predict later significant hyperbilirubinemia

Overall, the data suggest comparable predictability of the risk score developed by Keren et al. and the modified risk index (without family history of jaundice in a newborn) developed by Newman et al. in predicting later significant hyperbilirubinemia ( Table 2 ). Keren 2005 reported an AUC value of 0.71 (95% CI: 0.66, 0.76) for their risk score in predicting a post-discharge TSB greater than 95^th^ percentile on the hour-specific bilirubin nomogram. Newman 2005 (Study 2) reported an AUC value of 0.69 (no data for the 95%CI) for their modified risk index in predicting a TSB level ≥20 mg/dL at 48 hours. The original risk index (with family history of jaundice in a newborn) developed in Newman 2000 study had an AUC value of 0.84 (95% CI: 0.79–0.89) in predicting a TSB ≥25 mg/dL in the first 30 days after birth. This risk index had been independently verified in Newman 2005 (Study 1) and showed that eliminating the family history variable had little effect on the prediction. The AUC value declined from the previous reported value of 0.84 to 0.83 (95%CI: 0.77–0.89).

## Key Question 3. Does bilirubin testing accurately identify infants who may benefit from phototherapy?

### Ability of early TSB measurements to predict high late TSB measurements

Two prospective cohorts from India11 and Turkey10 and two retrospective cohorts from the United States8,9 with relevant data are described in Table 3. Three studies were graded fair quality,8–10 and one was graded poor quality.11

#### Sampling of infants in each study

Argawal 2002 prospectively included healthy infants with gestational age ≥35 weeks who were born in one center over a period of 5 months. Sarici 2004 prospectively included 366 consecutive infants with gestational age between 35 and 42 weeks, but reported data on the diagnostic ability of early TSB measurements only among 146 near-term infants (gestational age between 35 and 37 weeks). Newman 2005 Study 2 described a retrospective cohort of approximately 5,700 infants who were discharged earlier than 48 hours and had a pre-discharge TSB measurement less than 20 mg/dL (data were obtained from an electronic database on approximately 105,000 infants from Kaiser Permanente hospitals). Keren 2005 was a retrospective cohort of near-term and term infants born between 1995 and 1997, for whom both early (mostly pre-discharge – see Table 3 footnote) and late (mostly post-discharge– see Table 3 footnote) TSB measurements were available.

#### Post-discharge TSB measurement - reference standard

In three studies, the reference standard was a post-discharge measurement above the hour-specific 95^th^ percentile,8,10,11 and in Newman 2005 it was a TSB greater than 20 mg/dL (which is above the 95^th^ percentile at 48 hours or later).9 The timing of the reference measurement varied between 48 to 150 hours. In Sarici 2004, at least one of four measurements above the 95^th^ percentile during the first week (150 hours) was sufficient for TSB to be characterized as high.

#### Methodological comments

In Agarwal 2002, the reference standard (TSB at 72 hours) was not applied to infants with TSB less than 10 mg/dL at 72 hours (unclear how this was determined). This study may have underestimated the false negatives (inflating the calculated sensitivity) and overestimated the true negatives (inflating the calculated specificity) as apparently almost one-third of the infants did not get a TSB at 72 hours. Sarici 2004 reported results only among 146 near-term infants out of 366 near-term and term infants (reason was not given); it is unclear if this would have affected the reported findings.

#### Ability of early (pre-discharge) TSB to identify high late (post-discharge) TSB

The diagnostic ability of early measurements to identify post-discharge TSB above the 95^th^ hour-specific percentile (>20 mg/dL for Newman 2005) is shown in Figure 3 . Overall, the four studies suggested comparable diagnostic abilities of early TSB measurements to predict late high TSB measurements. Keren 2005 reported an AUC value of 0.83 (95% CI 0.80–0.86). Newman 2005 reported an AUC value of 0.79 (95% CI 0.77– 0.81) for an empirical ROC curve that considered four cutoffs for the early TSB measurement; and an AUC value of 0.83 (95% CI 0.80 0.85) when they considered continuous rather than categorical early hour-specific TSB measurements. Sarici 2004 used measurements at 6 hours and 30 hours to predict post-discharge high TSB. Measurements at 30 hours had better diagnostic ability than the earliest measurements. Agarwal 2002 suggested a negative likelihood ratio of less than 0.1, which showed a good ability to exclude post-discharge high TSB when early TSB was below the 75^th^ hour-specific percentile. However, this study had overt verification bias and therefore, the estimate may be overly optimistic.

Figure 3 Diagnostic Ability of Pre-discharge TSB Measurements to Predict Post-discharge Hour-specific TSB >95^th^ Percentile

Sensitivity/specificity pairs from the same study (obtained with different cutoffs for the early TSB measurement) are connected with lines. These lines may not be representative of the ROC curve of the pertinent studies. For example, Newman 2005 report higher AUC value than Keren 2005, something that is not directly evident from this graph (many intermediate cutoffs are not depicted). Studies lying on the left shaded area have a positive likelihood ratio of 10 or more. Studies lying on the top shaded have a negative likelihood ratio of 0.1 or less. Studies lying at the intersection of the grey areas (darker grey polygon) have both LR+>10 and LR−<0.1.

This receiver operating characteristic curve (ROC) depicts the diagnostic ability of early measurement of total serum bilirubin (TSB) levels to identify infants with high TSB levels (>95th hour-specific percentile) after discharge from the hospital. The horizontal axis represents 100%-specificity of the diagnostic measurement, going from 0% to 100% in 20% intervals; the vertical axis represents the sensitivity of the diagnostic measurement, going from 0% to 100% in 20% intervals. The data points on the graph correspond to the sensitivity and specificity pairs calculated from each study. The graph depicts four sensitivity/specificity pairs from the Sarici et al study (using 6-hour measurements), connected by a dotted line; three sensitivity/specificity pairs from the Keren et al study, connected by a dotted line; four sensitivity/specificity pairs from the Sarici et al study (using 30-hour measurements), connected by a solid line; three sensitivity/specificity pairs from the Newman et al study, connected by a solid line; and one sensitivity/specificity pair from the Agarwal study. The graph is shaded on the left, starting at 0% on the y axis of 100%-specificity and 0% sensitivity and gradually widening as it approaches the top (100% sensitivity), where it extends to approximately 10% on the y axis of 100%-specificity. Studies lying to the left of the shaded area have a positive likelihood ratio of ≥10. The graph is also shaded on the top, starting at 0% on the y axis of 100%-specificity and 90% sensitivity and gradually tapering to the right, where it approaches 0% on the y axis of 100%- specificity. Studies lying on top of this shaded area have a negative likelihood ratio of ≤0.1. Studies lying within the intersection of the two shaded areas (represented by a darker shaded polygon) have both positive likelihood ratios of >10 and negative likelihood ratios of <0.1. A paragraph of text at the bottom of the figure explains the meaning of the lines and the shaded areas, and the limitations of the lines, in more detail.

### Ability of TcB measurements to predict high late TSB measurements

One study from Thailand12 and one study from China (Hong-Kong)14 had relevant data; their characteristics are described in Table 4 . Both studies were graded poor for their methodological quality.

#### Sampling of infants in each study

Both studies included almost exclusively infants of Asian descent. Ho 2006 examined retrospectively all healthy term or near-term infants born over a period of 6 months that had TcB measurements above the 40^th^ percentile and also had a TSB measurement. Sapnavat 2005 enrolled healthy term infants born with caesarean section.

#### TSB measurement suggestive of phototherapy - reference standard

Ho 2006 used the American Academy or Pediatrics (AAP) guidelines to define TSB measurements indicating the need for phototherapy. According to the AAP guidelines, three hour-specific boundaries may be set; the lower corresponds to high risk infants (near-term with risk factors) and the highest one to low risk infants (term without risk factors). The middle boundary corresponds to middle risk infants (near-term without other risk factors or term with risk factors) and it roughly follows the hour-specific 95^th^ percentile line in the Bhutani nomogram. Sapnavat 2005 used their own criteria to define TSB values indicating the need for phototherapy. These were at least 10 mg/dL in the second day of life, at least 13 mg/dL in the third and at least 15 mg/dL after the third day of life.

#### Methodological comments

The study by Ho 2006 analyzed retrospectively only children who had TcB measurements above the 40^th^ hour-specific percentile and had undergone paired TcB and TSB measurements. Approximately 62% of children with TcB measurements above the 40^th^ percentile had paired measurements. Part of the analysis inappropriately used the 40^th^ percentile in TcB as cutoff (although no infants below this cutoff were included), yielding misleading estimates of sensitivity and specificity. The methodological quality of the study was graded poor. Sanpavat 2005 verified approximately 40% of the TcB measurements with TSB (unclear how the infants were selected; the study did mention obtaining TSB when infants were “jaundiced”).

#### Ability of early (pre-discharge) TSB to identify high late (post-discharge) TSB

Figure 4 summarizes the diagnostic ability of TcB measurements to identify TSB indicative of phototherapy in these two studies. Ho 2006 used three definitions of TSB that suggest the need for phototherapy according to the AAP TSB boundaries for low, medium, and high risk infants. Ho 2006 performed TSB infants with TcB measurements above the 40^th^ hour specific percentile. Using the TSB boundary for medium risk infants as a reference standard (which roughly corresponds to the 95^th^ hour-specific percentile in the Bhutani nomogram) suggests low negative likelihood ratio (LR−<0.1) when the TcB measurements are less than the 75^th^ percentile in the Bhutani nomogram. Using the TSB boundary for high risk infants, TcB measurements have sensitivity and specificity pairs that are not in the regions corresponding to high diagnostic ability (LR+>10 or LR−<0.1). Sanpavat 2005 had low negative LR for most of TcB measurements lower that the 90^th^ hour-specific percentile in the Bhutani nomogram. However, this study had overt verification bias, and therefore its sensitivity and specificity are likely to be inflated.

Figure 4 Diagnostic Ability of TcB Measurements to Identify Hour-specific TSB Suggesting the Need for Phototherapy

Sensitivity/specificity pairs from the same study (obtained with different cutoffs for the early TSB measurement) are connected with lines. These lines may not be representative of the ROC curve of the pertinent studies. Studies lying on the left shaded area have a positive likelihood ratio of 10 or more. Studies lying on the top shaded have a negative likelihood ratio of 0.1 or less. Studies lying at the intersection of the grey areas (darker grey polygon) have both LR+>10 and LR−<0.1.

This receiver operating characteristic curve (ROC) presents the diagnostic ability of transcutaneous bilirubin (TcB) measurement to identify infants with total serum bilirubin (TSB) levels suggesting the need for phototherapy treatment. The horizontal axis represents 100%-specificity of the diagnostic measurement, going from 0% to 100% in 20% intervals; the vertical axis represents the sensitivity of the diagnostic measurement, going from 0% to 100% in 20% intervals. The data points on the graph correspond to the sensitivity and specificity pairs calculated from each study. The graph depicts two sensitivity/specificity pairs from the Ho et al study (using high-risk infants), connected by a solid line; two sensitivity/specificity pairs from the Ho et al study (using medium-risk infants), connected by a dotted line; two sensitivity/specificity pairs from the Ho et al study (using low-risk infants), connected by a solid line; and six sensitivity/specificity pairs from the Sanpavat et al study, connected by a dotted line. The graph is shaded on the left, starting at 0% on the y axis of 100%-specificity and 0% sensitivity and gradually widening as it approaches the top (100% sensitivity), where it extends to approximately 10% on the y axis of 100%-specificity. Studies lying on the left of this shaded area have a positive likelihood ratio of ≥10. The graph is also shaded on the top, starting at 0% on the y axis of 100%-specificity and 90% sensitivity and gradually tapering to the right, where it approaches 0% on the y axis of 100%-specificity. Studies lying on top of this shaded area have a negative likelihood ratio of ≤0.1. Studies lying within the intersection of the two shaded areas (represented by a darker shaded polygon) have both positive likelihood ratios of >10 and negative likelihood ratios of <0.1. Text at the bottom of the graph explains the meaning of the lines and shaded areas, and the limitations of the lines, in more detail.

### Outcomes associated with the implementation of TcB screening and the use of hour-specific bilirubin nomogram

Three studies compared the number of newborns received phototherapy and/or readmission rate for hyperbilirubinemia for newborns who were born before to those who were born after the implementation of transcutaneous bilirubin (TcB) screening and the use of the hour-specific bilirubin nomogram in the United States.4,13,15 Their characteristics and results are summarized in Table 5 . All studies were of poor methodological quality because the outcomes reported in these studies came from retrospective descriptive analyses without controlling for confounding factors. Specifically, all three studies were retrospective in design, and the information on bilirubin levels in the populations was not obtained in two studies.4,13 In addition, many factors that could likely affect the prevalence of hyperbilirubinemia (e.g., increase in breastfeeding rate, increase in Asian immigrants, sentinel alert of resurgence in kernicterus2) and other potential confounders (e.g., changes in phototherapy procedures or background healthcare policy) were not ascertained. Therefore, the data presented here could only provide indirect evidence of the outcomes associated with the introduction of the implementation of TcB screening and the use of hour-specific bilirubin nomogram.

Bhutani 2006 described the changes in the use of intensive phototherapy and the changes in the readmission rates for intensive phototherapy in term and near-term infants with an incremental implementation of a systems approach that incorporated a hospital policy to (a) authorize nurses to obtain a bilirubin (total serum/transcutaneous) measurement for clinical jaundice, (b) universal pre-discharge total serum bilirubin (at routine metabolic screening), and (c) targeted followup, using the bilirubin nomogram (hour-specific, percentile-based total serum bilirubin/transcutaneous bilirubin).4 The data showed that the use of intensive phototherapy increased from 4.49% during 1993 to 1995 (the phase of universal TSB screening without hour-specific bilirubin nomogram) to 5.44% during 1996 to 1998 (the phase of universal TSB screening with hour-specific bilirubin nomogram). After a system-based approach for hyperbilirubinemia screening was implemented, the use of intensive phototherapy had decreased to 2.49% (3.0% in 1999 and 1.98% in 2000) during 1999 and 2000. During the nomogram development phase and the initiation of a system-based program, a steady and significant decline in readmission rate for intensive phototherapy was noted from 14 admitted in 1994 to 5.5 infants per 1000 well babies admitted in 2001 to 2003.

Eggert 2006 described the changes in the proportion of infants with significant hyperbilirubinemia and in the proportion readmitted to the hospital with a diagnosis of hyperbilirubinemia comparing before with after the initiation of universal pre-discharge TSB or TcB screeninge.15 Only two out of 18 hospitals used a screening jaundice meter for TcB estimation of bilirubin levels. A modified Bhutani’s hour-specific bilirubin nomogram was used. The authors stated the reason was that “an inordinately high number of neonates had bilirubin values in the intermediate- and high-risk zones of the Bhutani et al nomogram, particularly when evaluated between 24 and 48 hours of age.”. If an infant had a bilirubin level ≥40th percentile on the modified nomogram, the care provider was notified. Appropriate evaluation, intervention, and followup were arranged as necessary. The study reported that the incidence of severe hyperbilirubinemia among term and near-term infants increased significantly; while the proportion of newborns readmitted to the hospital for treatment of hyperbilirubinemia decreased from 0.55% to 0.43% (P<0.005) comparing before with after the initiation of universal pre-discharge TSB or TcB screening.

Petersen 2005 described the changes in the number of newborns received phototherapy, readmission rates for hyperbilirubinemia, length of stay, and the number of bilirubin measurements comparing before to after the initiation of TcB testing. The decision to start phototherapy or obtain additional bilirubin measurements was made using the hour-specific bilirubin nomogram. The study reported that the proportion of newborns treated with phototherapy in the nursery increased significantly after initiation of TcB (5.9% vs. 7.7% per month before vs. after TcB, respectively). However, the mean number of serum bilirubin per newborn did not change after introduction of TcB testing (1.51 vs. 1.56 TSB per newborn before vs. after TcB, respectively). After initiation of TcB testing, the mean (SD) number of readmission for hyperbilirubinemia decreased from 4.5 (2.8) to 1.8 (1.7) per 1000 births per month (P=0.044).

### Combination of the risk index with early TSB levels

Newman 2005 (Study 2) also compared the ability of various screening strategies in predicting a TSB level ≥20 mg/dL at 48 hours or older after birth. The results suggested that the combination of the modified risk index (described in Newman 2005 Study 1) with early TSB levels significantly enhanced prediction. The AUC value for prediction of developing a TSB level of 20 mg/dL or higher at age 48 hours or older improved from 0.69 to 0.86 (95%CI 0.84–0.88) after adding the early TSB z scores (the standard normal deviates for each participants’ early hour-specific TSB measurements) to the modified risk index. The AUC value for the combination of the modified risk index with early TSB z scores was also significantly better than that for the early TSB z scores alone (0.86 vs. 0.83, P=0.001).

## Key Question 4. What are the harms of screening?

Studies reviewed in this report did not assess the harms of screening.

## Key Question 5. Does treatment reduce the risk of bilirubin encephalopathy in infants identified by screening?

No studies in this review evaluated the effectiveness of phototherapy in reducing the risk of bilirubin encephalopathy.

## Key Question 6. What are the harms of treatment with phototherapy?

A total of nine studies assessed for potential adverse or other effects of phototherapy.16–24 One retrospective study compared the number of melanocytic nevi in children who received phototherapy with children who did not receive phototherapy.19 One study compared polysomnography findings in infants before phototherapy with findings during phototherapy.16

Three studies compared temperature before with during phototherapy.17,20,23 Seven studies compared different aspects of phototherapy (e.g., with versus without white curtain,18 single versus double,20 conventional versus fiberoptic,21 conventional versus LED,22 far versus near,23 hospital versus home24). Results are summarized in Table 6 .

Number of subjects in the studies ranged from 10 to 104. Adverse or other effects in infants evaluated included: hypo- or hyperthermia; weight loss; gastrointestinal problems; skin rash or erythema; and changes in cardiopulmonary parameters.

In the study that compared cardiopulmonary parameters in ten term infants before phototherapy with parameters in the same infants during phototherapy, the study reported the respiratory rate decreased from a mean of 54.3 ± 10.3 to 49.1 ± 10.8 (P <0.05) and the heart rate increased from a mean of 125.9 ± 11.7 to 129.7 ± 15.3 (P<0.05) in the active sleep phase, but no significant difference was found during the quiet sleep phase.16 There was a trend towards an increase in the duration of central apnea (P=0.07) while under phototherapy. It also reported a significant increase in heart rate (P<0.02) in the same group of infants while under phototherapy compared to no phototherapy. No significant effects on oxygen saturation, rate of apnea, or periodic breathing were found.

One study reported that the infants’ mean temperature increased from a baseline of 36.43°C ± 0.21°C to 36.70°C ± 0.25°C after 6 hours of phototherapy (P<0.05).23 Another study reported that 29/81 (36%) infants with initial core temperature of 36.5–37.5°C increased to >37.5° C after 2 hours of phototherapy.17 The same study also reported that 2/81 (2.5%) infants with initial core temperature of 36.5–37.5° decreased to <36.5° C after 2 hours of phototherapy. A third study on the exposure of phototherapy with or without white curtain reported no hypo- or hyperthermia in the infants.18

One retrospective study examined the presence of melanocytic nevi (a brown to black macule or papule) in 18 children who received phototherapy compared with 40 children who did not receive phototherapy.19 In the multivariate analysis, an association between phototherapy and nevi sizes were found after adjusting for risk factors (phototherapy, age, skin type I or II, color of skin, eye, and hair, freckles, sun exposure during vacation, and severe sunburn) (2–5 mm, P<0.001; ≥ 2 mm, P=0.003). This study did not control for the number of melanocytic nevi in parents and it was also unclear how the subjects in the phototherapy group were selected.

One study reported no significant weight loss, no skin or gastrointestinal problems in infants exposed to phototherapy with or without white curtain.18 Another study reported no significant difference in weight loss, stooling or hyperthermia in infants with single versus double phototherapy.20 A third study reported transient erythema and watery stool in either the infants who received fiberoptic (1/50; 3/50, respectively) or conventional phototherapy (1/50; 3/50 respectively).21 A fourth study reported no side effects were noted in infants who received either conventional or LED blue or blue-green phototherapy.22 A fifth study found no significant difference in terms of rash, hyperthermia, or diarrhea in infants who received home versus hospital phototherapy.24 Positive findings reported in these studies could not be confidently attributed to the use of phototherapy as none of the studies compared infants exposed to phototherapy with infants who were not exposed to phototherapy.

Table 1

Comparisons of the Risk Scores/Indexes Across Studies

Risk Factors | Weighting for Risk Score/Index
Risk Factors | Keren, 2005 | Newman, 2005 | Newman, 2000 a
Exclusive breastfeeding | 5 | 6 | 6
Breast and bottle feeding | 4 | - | -
Family history of jaundice in newborn | - | - | 6
Bruising | - | 4 | 4
Asian race | - | 4 | 4
Cephalohematoma | - | 3 | 3
Mother age ≥25 years | - | 3 | 3
Male sex | - | 1 | 1
Black race | - | −2 | −2
Gestational age in weeks minus 40 weeks | - | 2 | 2
Gestational age <38 wk | 5 | - | -
3 points per 500 gram above 2000 gram in birth weight^b^ | 3 | - | -
Oxytocin used | 4 | - | -
Vacuum delivery | 4 | - | -

a Summarized in the previous report (see Appendix F)

b Calculation: (Birth weight in grams – 2001)/500, rounding down to the nearest integer

Table 2

Summary of Studies That Used Risk Predictive Instruments to Predict High TSB

Author, Year Country (single/multi center) | Design | N (cases) | Birth weight (g), gestational age (wk) | Risk score | High TSB cutoff (mg/dL) | Verification bias | Independent validation | AUC | RI Cutoff with Best Predictive Values | Quality
Keren, 2005 US (single center) | Retrospective cohort | 993 | ≥2000, ≥36 or ≥2500 if ≥35 | Personal history^d^ | NA (>95^th^ %tile) | No | No | 0.71 | ≥12 | B
Newman, 2005 - Study 2 US (multi center) | Retrospective cohort | 5706 | >2000, >36 | Personal history^b^ | 20 | No | No^f^ | 0.69 | ≥10 | B
Newman, 2005 - Study 1 US (multi center) | Nested case-control | 275 (67) | 2000, >36 | Personal history^b^ | 25 | No | Yes^c^ | 0.83 | n.d. | B
Newman, 2000^e^ US (multi center) | Nested case-control | 496 (73) | >2000, >36 | Personal and family history^a^ | 25 | No | No | 0.84 | ≥10 | -

GA=gestational age; N=Number analyzed; NA=Not applicable; NICU=neonatal intensive care unit; TSB=total serum bilirubin; RI=risk index; AUC=area under the curve.

a Score=6*Exclusive breastfeeding + 6*Family history of jaundice in newborn+4*Bruising + 4*Asian race + 3* Cephalohematoma + 3* Mother age ≥25 years + 1* Male sex –2* Black race + 2*(Gestational age in weeks - 40)

b Modified Score is the same as above, excluding the family history of jaundice in newborn term, i.e., (modified score) = 6*Exclusive breastfeeding at discharge + 4* Bruising + 4* Asian race + 3* Cephalohematoma + 3* Mother age ≥25 years + 1* Male sex –2 * Black race + 2*(Gestational age in weeks - 40)

c Independent validation of the score developed in Newman 2000. However, the score was “modified”, abolishing one of the most influential factors (family history of jaundice in newborn) because it was available only in 10% of infants.

d Score= [3 points per 500 g above 2000 g in BW]+5*GA<38 wk + 4* oxytocin used or not + 4* vacuum delivery + 5*exclusive breastfeeding + 4* breast and bottle feeding

e Summarized in the previous report (see Appendix F)

f Most likely all cases of significant hyperbilirubinemia in Newman 2005 (Study 2) were included in Newman 2005 (Study 1) and Newman 2000

Table 3

Summary of Studies That Used Early TSB to Predict Late High TSB

Author, Year Country (single/multi center) | Design | N_E_ (N_A_) | Birth weight (g), gestational age (wk) | Early TSB | | Late TSB | | Verification bias | Quality
Author, Year Country (single/multi center) | Design | N_E_ (N_A_) | Birth weight (g), gestational age (wk) | Timing (h) | Cutoff | Timing (h) | Cutoff | Verification bias | Quality
Keren, 2005 USA (single center) | Retrospective cohort^g^ | 996 (899) | ≥2000, ≥36 ≥2500, ≥35 | Pre-discharge^h^ | %tile 40, 75, 95 | Post-discharge^h^ | %tile 95 | No | B
Newman, 2005 - Study 2 USA (multi center) | Retrospective cohort^e^ | 5711 (5706) | >2000, >36 | <48 | %tile 40, 5, 95 | ≥48 | >20 mg/dL^f^ | No | B
Sarici, 2004 Turkey (Single center) | Prospective cohort | 366 (146)^b^ | ND, 35 to 42 | 6 and 30 | %tile 5, 30, 60, 95 | 150^c^ | %tile 95^d^ | No | B
Agarwal, 2002 India (single center) | Prospective cohort | 220 (213) | ND, ≥35 | 24 | 6mg/dL [≅%tile 75] | 72 (ND) | %tile 95 | Yes^a^ | C

%tile=percentile(s) in the Bhutani nomogram; h=hours; N_A_/N_E_=Number analyzed/enrolled; TSB=total serum bilirubin; wk=weeks

a Late TSB was measured only among those with “>10mg/dL” (unclear how this was deduced); 69% of infants were verified

b 146 near-term and 219 term infants were analyzed, i.e., 365 infants total; however only near-term infants were analyzed (not stated why)

c 4 measurements were taken on 4 days; last was on day 7, at 150 h of life

d In any measurement during the first week

e The paper by Newman 2005 describes a retrospective cohort (shown here) and a nested case-control study

f This is above the 95^th^ hour-specific percentile

g These infants were included in the Bhutani et al. publication that reports the nomogram for hour-specific TSB values

h If there were no post-discharge measurements, the latest pre-discharge measurement was used provided it was after 40 h (n=213); if there were no post-discharge measurements, the earliest post-discharge was used, provided it was <72 h (n=96)

Table 4

Summary of Studies That Used TcB to Identify Infants With TSB Suggesting Phototherapy

Author, Year Country (single/multi center) | Design | N_E_ (N_A_) | Birth weight (g), gestational age (wk) | Time of measurement | TcB | | | | TSB level suggesting photoRx | Verification bias | Quality
Author, Year Country (single/multi center) | Design | N_E_ (N_A_) | Birth weight (g), gestational age (wk) | Time of measurement | Device | Site | Cutoff | Δt from TSB | TSB level suggesting photoRx | Verification bias | Quality
Ho, 2006 Hong Kong-China (single center) | Retrospective cohort | 1621^a^ (997) | ND; >35 | Within first 3 days^b^ | JM-103^c^ | Mid-sternum | %tile 75, 95 | 30 min | 3 different cutoffs [high-, medium-, & low-risk infants]^d^ | No | C
Sanpavat, 2005 Thailand (single center) | Unclear if prospective or not | 392 (392) | ≥2000; ≥37 | ND | Bilicheck^f^ | Fore-head | %tile 10, 25, 50, 75, 85, 90, 95 | ND | - 25–48h: ≥10 mg/dL; - 49–72h: ≥13 mg/dL; - >72h ≥15 mg/dL | Yes^g^ | C

%tile=percentile(s) in the Bhutani nomogram; Δt=time interval between the two measurements; N_A_/N_E_=Number analyzed/enrolled; ND=no data; PhotoRx=phototherapy; TcB=transcutaneous bilirubin; TSB=total serum bilirubin; wk=weeks

a 1621 term or near-term infants fulfilled eligibility criteria and had TcB measurements above the 40^th^ hour-specific percentile. However, only 997 had paired measurements with TSB

b 97% of measurements obtained within the first 3 days of life

c Minolta Airshields

d Low risk infants: gestational age ≥38 wk and well; medium risk infants: ≥38 wk with risk factors or 35–37 6/7 wk and well; high risk infants 35–37 6/7 wk with risk factors

e Because only children with TcB measurement above the 40^th^ hour-specific percentile who had paired measurements were actually analyzed in the study

f SpecRx Inc

g Only 39% (n=154) of infants received TSB measurements (unclear how these were selected –“jaundice”)

Table 5

Outcomes Associated With the Implementation of TcB Screening and the Use of Hour-specific Bilirubin Nomogram in Term and Near-term Infants

Author, Year Country Hospital | Phases of Hyperbili Screening | Years | N | PhotoRx (%) | Exchange Transfusion | Mean LOS (days) | Readmission for Hyperbili/PhotoRx (per 1000 discharges) | Quality
Bhutani, 2006 US Pennsylvania Hospital | Universal TSB (prenomogram) | 1993–1995 | 7,929 | 4.5% | 6 (1:1,322) | - | 14 | C
Bhutani, 2006 US Pennsylvania Hospital | Universal TSB with nomogram | 1996–1998 | 8,186 | 5.4% | 5 (1:1,637) | - | 11 | C
Bhutani, 2006 US Pennsylvania Hospital | Systems-based approach (TSB/TcB+ nomogram) | 1999–2000 | 6,395 | 2.5% | 2 (1:3,198) | - | 5.5 | C
Eggert, 2006 US Intermountain Health Care, Salt Lake City, Utah | Before universal TSB/TcB (with modified nomogram) | March 1, 2001 to Dec 31, 2002 | 48,798 | - | 0 | - | 5.5 | C
Eggert, 2006 US Intermountain Health Care, Salt Lake City, Utah | After universal TSB/TcB (with modified nomogram) | Jan 1, 2003 to Dec 31, 2004 | 52,483 | - | 0 | - | 4.3 | C
Petersen, 2005 US University of Texas Medical Branch | Before TcB (with nomogram) | Aug 2002 to March 2003 | 405 births per mo | 5.9% per mo | - | 2.2 | 4.5 | C
Petersen, 2005 US University of Texas Medical Branch | After TcB (with nomogram) | May 2003 to Dec 2003 | 421 births per mo | 7.7% per mo | - | 2.1 | 1.8 | C

Hyperbili=hyperbilirubinemia; PhotoRx=phototheray; LOS=length of stay; TSB=total serum bilirubin; TcB=transcutaneous bilirubin; mo=month

Table 6

Adverse or Other Effects Reported in Phototherapy Studies on Term Infants

Study year country | Intervention (N) vs. Control (N) | Dose (time under phototherapy) | | | Adverse or other effects reported
Randomized studies
Djokomuljanto 2006 Malyasia | phototherapy with white curtain (n=51) vs. without white curtain (n=49) | Median duration of phototherapy: with white curtain: 12 h; Without white curtain: 34 h | | | No hypo or hyperthermia; no significant weight loss; no skin or gastrointestinal problems; no detectable abnormalities on neurological exam before discharge
Nuntnarumit 2002 Thailand | single vs. double phototherapy | Single phototherapy: 43.7 h±17.5; Double phototherapy: 34.9 h ± 12.6 | | | | 1X | 2X | P
Nuntnarumit 2002 Thailand | single vs. double phototherapy | Single phototherapy: 43.7 h±17.5; Double phototherapy: 34.9 h ± 12.6 | | | wt↓ (%/d) | 1.2±0.8 | 1.7±1.3 | 0.25
Nuntnarumit 2002 Thailand | single vs. double phototherapy | Single phototherapy: 43.7 h±17.5; Double phototherapy: 34.9 h ± 12.6 | | | Stooling (times/d) | 2.2±17.5 | 2.8±1.7 | 0.10
Nuntnarumit 2002 Thailand | single vs. double phototherapy | Single phototherapy: 43.7 h±17.5; Double phototherapy: 34.9 h ± 12.6 | | | Temp>38° C | 12.5% | 7.4% | 0.65
Sarici 2001 Turkey | fiberoptic (n=50) vs. conventional phototherapy (n=50) | Conventional | | 49.4 h ± 14.4 | 1 in each group had transient erythema; 3 in each group had mild watery stool; no other complications noted
Sarici 2001 Turkey | fiberoptic (n=50) vs. conventional phototherapy (n=50) | Fiberoptic | | 61 h ± 13.1 | 1 in each group had transient erythema; 3 in each group had mild watery stool; no other complications noted
Seidman 2003 Israel | Open randomized study: Conventional phototherapy (n=57); LED blue (n=25); LED blue-green (n=22) | Conventional | | 35.4 h (29.8–41.0) | No adverse or other effects (e.g., erythema) were noted.
Seidman 2003 Israel | Open randomized study: Conventional phototherapy (n=57); LED blue (n=25); LED blue-green (n=22) | LED blue | | 31.6 h (23.1–40.0) | No adverse or other effects (e.g., erythema) were noted.
Seidman 2003 Israel | Open randomized study: Conventional phototherapy (n=57); LED blue (n=25); LED blue-green (n=22) | LED blue-green | | 39.2 h (30.0–48.4) | No adverse or other effects (e.g., erythema) were noted.
Turan 2004 Turkey (1° aim was to compare NO and vascular endothelial growth factor) | phototherapy 15 cm away (15–18 μW/cm2/nm) (n=29) vs. 30–45 cm away (10–12 μW/cm2/nm) (n=32) | ND | | | | 15 cm | 30–45 cm
Turan 2004 Turkey (1° aim was to compare NO and vascular endothelial growth factor) | phototherapy 15 cm away (15–18 μW/cm2/nm) (n=29) vs. 30–45 cm away (10–12 μW/cm2/nm) (n=32) | ND | | | Baseline temperature | 36.43±0.21 | 36.49±0.34
Turan 2004 Turkey (1° aim was to compare NO and vascular endothelial growth factor) | phototherapy 15 cm away (15–18 μW/cm2/nm) (n=29) vs. 30–45 cm away (10–12 μW/cm2/nm) (n=32) | ND | | | Temperature at 6^th^ h phototherapy | 36.70±0.25* | 36.82±0.26*
Turan 2004 Turkey (1° aim was to compare NO and vascular endothelial growth factor) | phototherapy 15 cm away (15–18 μW/cm2/nm) (n=29) vs. 30–45 cm away (10–12 μW/cm2/nm) (n=32) | ND | | | Baseline heart rate | 140.96±13.28 | 142.06±12.21
Turan 2004 Turkey (1° aim was to compare NO and vascular endothelial growth factor) | phototherapy 15 cm away (15–18 μW/cm2/nm) (n=29) vs. 30–45 cm away (10–12 μW/cm2/nm) (n=32) | ND | | | Heart rate at 6^th^ h phototherapy | 146.75±8.14* | 144.62±9.60
Turan 2004 Turkey (1° aim was to compare NO and vascular endothelial growth factor) | phototherapy 15 cm away (15–18 μW/cm2/nm) (n=29) vs. 30–45 cm away (10–12 μW/cm2/nm) (n=32) | ND | | | Baseline mean blood pressure | 61.03±11.29 | 60.12±7.61
Turan 2004 Turkey (1° aim was to compare NO and vascular endothelial growth factor) | phototherapy 15 cm away (15–18 μW/cm2/nm) (n=29) vs. 30–45 cm away (10–12 μW/cm2/nm) (n=32) | ND | | | Mean blood pressure at 6^th^ h phototherapy | 57.65±8.46 | 55.50±8.07*
Turan 2004 Turkey (1° aim was to compare NO and vascular endothelial growth factor) | phototherapy 15 cm away (15–18 μW/cm2/nm) (n=29) vs. 30–45 cm away (10–12 μW/cm2/nm) (n=32) | ND | | | *P comparing baseline with 6^th^ h:<0.05; All other comparisons:NS
Comparative studies
Bader 2006 Israel | 10 infants evaluated before vs. during phototherapy: cardio-respiratory activity using polysomnography (PSG) | ND | | | | Before phototherapy | During phototherapy | P
Bader 2006 Israel | 10 infants evaluated before vs. during phototherapy: cardio-respiratory activity using polysomnography (PSG) | ND | | | Active sleep
Bader 2006 Israel | 10 infants evaluated before vs. during phototherapy: cardio-respiratory activity using polysomnography (PSG) | ND | | | Respiratory Rate | 54.3 ± 10.3 | 49.1 ± 10.8 | <0.05
Bader 2006 Israel | 10 infants evaluated before vs. during phototherapy: cardio-respiratory activity using polysomnography (PSG) | ND | | | Heart Rate | 125.9 ± 11.7 | 129.7 ± 15.3 | <0.05
Bader 2006 Israel | 10 infants evaluated before vs. during phototherapy: cardio-respiratory activity using polysomnography (PSG) | ND | | | Quiet sleep
Bader 2006 Israel | 10 infants evaluated before vs. during phototherapy: cardio-respiratory activity using polysomnography (PSG) | ND | | | Respiratory Rate | 46.0 ± 9.9 | 45.7 ± 12.0 | NS
Bader 2006 Israel | 10 infants evaluated before vs. during phototherapy: cardio-respiratory activity using polysomnography (PSG) | ND | | | Heart Rate | 123.1 ± 12.5 | 127.7 ± 14.4 | NS
Bader 2006 Israel | 10 infants evaluated before vs. during phototherapy: cardio-respiratory activity using polysomnography (PSG) | ND | | | Mean ratio of breath depth before/after apnea (active sleep)
Bader 2006 Israel | 10 infants evaluated before vs. during phototherapy: cardio-respiratory activity using polysomnography (PSG) | ND | | | | 1.1 ± 0.2 | 1.3 ± 0.3 | <0.02
Bader 2006 Israel | 10 infants evaluated before vs. during phototherapy: cardio-respiratory activity using polysomnography (PSG) | ND | | | 6 infants had apnea in and out of phototherapy. There was a trend in increase in central apnea duration while under phototherapy (P=0.07). An increased heart rate under phototherapy as compared to no phototherapy (P<0.02) was also noted.
Matichard 2006 France Comparative (retrospective collection of phototherapy exposure); subjects were examined for melanocytic nevi | Group 1 (n=18): received blue light phototherapy during the first few days Control (n=40): no phototherapy Excluded children with rarely to never burn skin (Fitzpatrick IV to VI) | | “Results not shown” | | Univariate analysis:; - Mean number of nevi ≥2 mm: 3.5/child (SD 3.05) in phototherapy vs. 1.45/child (SD 1.99) in no phototherapy(P=0.02); - Mean number of nevi 2–5 mm: 3.17/child (SD 2.67) in phototherapy vs. 1.23/child (SD 1.49) in no phototherapy(P=0.008); - Association between phototherapy and nevus count for nevi <2mm or >5mm was not significant; Multivariate analysis: An association between phototherapy and nevi sizes (2–5 mm, P<0.001; ≥ 2 mm, P=0.003) after adjusting for all other risk factors in the model (phototherapy, age, skin type I or II, color of skin, eye, and hair, freckles, sun exposure during vacation, and severe sunburn)
Zainab 2004 Malaysia | Home (n=18) vs. hospital (n=18) phototherapy | Home: 1.17 d ± 0.73; Hospital: 1.72 d ± 0.73 | | | | home | hospital
Zainab 2004 Malaysia | Home (n=18) vs. hospital (n=18) phototherapy | Home: 1.17 d ± 0.73; Hospital: 1.72 d ± 0.73 | | | No complications | 78% | 78%
Zainab 2004 Malaysia | Home (n=18) vs. hospital (n=18) phototherapy | Home: 1.17 d ± 0.73; Hospital: 1.72 d ± 0.73 | | | rash | 5.5% | 11%
Zainab 2004 Malaysia | Home (n=18) vs. hospital (n=18) phototherapy | Home: 1.17 d ± 0.73; Hospital: 1.72 d ± 0.73 | | | hyperthermia | 0 | 0
Zainab 2004 Malaysia | Home (n=18) vs. hospital (n=18) phototherapy | Home: 1.17 d ± 0.73; Hospital: 1.72 d ± 0.73 | | | Diarrhea >5x | 16.7% | 11%
Zainab 2004 Malaysia | Home (n=18) vs. hospital (n=18) phototherapy | Home: 1.17 d ± 0.73; Hospital: 1.72 d ± 0.73 | | | Differences between groups: NS
Cohort analysis of an RCT
Boo 2006 Singapore | Healthy term infants who need phototherapy | | 2 h | | After 2 h of phototherapy: 2/81 (2.5%) infants with initial core temperature of 36.5–37.5° decreased to <36.5° C; 29/81 (36%) infants with initial core temperature of 36.5–37.5° increased to >37.5° C