# Methods

This report will be used by the USPSTF to make recommendations concerning screening for hyperbilirubinemia in neonates. Tufts-NEMC EPC, the Center on Primary Care, Prevention and Clinical Partnerships at AHRQ, and the USPSTF jointly developed an analytic framework ( Figure 1 ) and a set of study inclusion/exclusion criteria that are suitable to meet the USPSTF objectives.

Figure 1 Hyperbilirubinemia Screening Analytic Framework

Key: GA=Gestational age; AAP=American Academy of Pediatrics; RF=Risk factor; Bili=Bilirubin; TcBili=Transcutaneous bilirubin; %ile=Percentile; TSB=Total serum bilirubin.

This figure depicts the analytic framework for screening for hyperbilirubinemia. The diagram starts on the left with text that reads “Infants ≥35 weeks GA prior to discharge home.” An arrow then goes to “Risk assessment using AAP RFs, serum bili, or TcBili,” whereupon it branches to arrow 1, arrow 2 and 3 (same arrow), and arrow 4. Arrow 1 goes directly to the end of the diagram on the far right. Arrow 4 curves down and to the right and ends at an oval reading “Adverse effects.” Arrow 2 and 3 forks in two directions. One direction leads to a box labeled “Low risk.” A vertical line connects this box to arrow 1 above it. The other direction leads to a box labeled “High risk.” From the latter box the arrow forks in two directions again. One direction leads to a box labeled “<95%ile for age in hours,” the other direction leads to a box labeled “≥95%ile for age in hours.” From the latter box the arrow goes to “Photo Rx,” whereupon it branches to arrow 5 and arrow 6. Arrow 6 curves down and ends at an oval labeled “Adverse effects.” Arrow 5 leads to a box labeled “Reduced rate of TSB >20,” which is connected to arrow 1 by a descending vertical line. The arrow then proceeds as a dotted line to “Reduced bilirubin encephalopathy,” which is also connected to arrow 1 by a descending vertical line. This is the end of the path. A legend at the bottom of the figure reads “GA=Gestational age; AAP=American Academy of Pediatrics; RF=Risk factor; Bili=Bilirubin; TcBili=Transcutaneous bilirubin; %ile=Percentile; TSB=Total serum bilirubin.”

The key questions (KQs) are:

KQ1: | Does screening using risk factor assessment and/or bilirubin testing reduce the incidence of acute or chronic bilirubin encephalopathy?
KQ2: | Does risk factor assessment accurately identify infants who may benefit from bilirubin testing?
KQ3: | Does bilirubin testing accurately identify infants who may benefit from phototherapy?
KQ4: | What are the harms of screening?
KQ5: | Does treatment reduce the risk of bilirubin encephalopathy in infants identified by screening?
KQ6: | What are the harms of treatment with phototherapy?

## Approach to Key Questions

This review focuses on the effectiveness of screening for hyperbilirubinemia to reduce the incidence of acute or chronic bilirubin encephalopathy. It also focuses on the benefits and harms of phototherapy. Populations of interests are healthy term or near-term infants (≥35 weeks gestation) and their mothers. Examples of screenings are system approach based on risk factors assessment, universal screening for bilirubin level (transcutaneous and/or serum), or combinations of both. Outcomes of interest are the rates of acute or chronic bilirubin encephalopathy (when data are available), or surrogate measures (e.g., bilirubin level ≥ 20, 25, 30 mg/dL), and any health outcomes or adverse events related to phototherapy.

## Study Selection

We included experimental and observational studies with comparison groups (concurrent or historical comparison groups, or before-and-after comparison) in our review. For adverse events or other effects associated with phototherapy, we also included case report or case series. As this is an update of our previous report,1 our literature search of Medline was restricted to studies published after September of 2001 (search date of our previous report). Only English language studies published in peer-reviewed journals were included. Review articles, letter to the editors, or comments were excluded.

General inclusion criteria for the studies were:

Study Design: | Experimental or observational studies
Population: | Healthy term or near-term infants (≥35 weeks gestation) regardless of countries
Intervention: | Screening for risk factors or serum bilirubin or transcutaneous bilirubin or combinations; phototherapy or exchange transfusion
Setting: | Hospital, primary care office, home (for followup studies).
Comparator: | No screening or different risk levels for developing hyperbilirubinemia defined by the screening programs; no phototherapy or exchange transfusion
Outcomes: | Rates of acute or chronic bilirubin encephalopathy; rates of serum bilirubin (≥ 20, 25, 30 mg/dL); risk for developing hyperbilirubinemia or undergoing phototherapy; health outcomes and adverse events related to phototherapy

Specific exclusion criteria per key question were:

KQ1: | None
KQ2: | None
KQ3: | Studies on clinical or maternal assessments of jaundice, cord blood bilirubin, end-tidal carbon monoxide (ETCO), or umbilical cord alpha-fetoprotein alone; studies reported correlation coefficients and/or Bland-Altman limit of agreement data only; no data on the timing of measurements; data were insufficient to determine the percentile of TSB
KQ4: | None
KQ5: | Treatments were not phototherapy
KQ6: | Side effects or adverse events were not reported; data on adverse events for exchange transfusion; no usable numerical data

## Search Strategy

We searched Medline for studies published from September, 2001 to December, 2006, using the MeSH terms and keywords, such as “jaundice”, “bilirubin”, “hyperbilirubinemia”, and “kernicterus”. For additional studies, we examined the bibliographies in existing studies and also consulted the Lead Experts from USPSTF. We updated our search in August of 2007.

## Data Extraction

One reviewer initially screened abstracts for possible inclusion. This initial screening used very broad criteria to ensure that all potentially relevant abstracts were included (i.e., any human studies with any kind of screening or treatment of hyperbilirubinemia were screened in). A second person reviewed all the potentially relevant abstracts using the formal study inclusion/exclusion criteria. The full papers of the eligible abstracts were retrieved and examined in detail. After full article evaluation, data from qualified studies were abstracted (Appendix B). Items of interest extracted were: study setting, population, control, description of screening strategy, definitions of bilirubin encephalopathy and elevated bilirubin, and methods of analyses. Any adverse events or other effects from screening or phototherapy were also extracted.

## Quality Assessment

We assessed the quality using criteria developed by the USPSTF.6 Each paper was assigned a quality rating of “good”, “fair”, or “poor” by two reviewers. The criteria of quality assessment for primary studies included the randomization techniques, clear definitions of outcomes, and consideration for potential confounders in cohort studies, or intention to-treat analysis for RCTs. A third reviewer reviewed those studies in which the quality rating was discordant between the first two reviewers. Final grade in those studies were reached via consensus. Because of the wide variability in reporting of adverse events or other effects (e.g., temperature changes, sizes of nevi), the findings from those studies were summarized but the quality of those studies was not assessed.

## Data Analysis and Presentation

Because of dissimilarities in the identified studies, no quantitative synthesis (meta-analysis) was performed. We assessed the ability of risk factor scores, transcutaneous or early bilirubin testing, or combinations thereof (index tests) to identify infants with high TSB (i.e., above the 95^th^ hour-specific percentile) and infants who may benefit from phototherapy (as defined in the individual studies). To this end, we calculated from each study the corresponding sensitivity and specificity pairs. Multiple sensitivity/specificity pairs may be calculated for studies that report different cutoffs for the index or reference tests.

We also characterized the diagnostic ability of each test using positive and negative likelihood ratios (LR+ and LR−, respectively). These quantities express the information conveyed by the test results. Briefly, LR+ quantifies the increase of the pre-test odds (e.g., identifying high TSB values when the screening test is positive). Conversely, LR− quantifies how much less likely a high TSB value is if the index test result is negative. LR+ and LR− values of 1 imply no diagnostic ability. By convention, LR+>10 and LR−<0.1 imply informative and useful tests.7 Instead of providing tables of likelihood ratios per study and cutoff used, we integrate the relevant information in the figures.

We recorded and reported the area under the curve (AUC) value from receiver operating characteristic (ROC) curve analyses. AUC values close to 1 imply better diagnostic ability. AUC values of 0.5 mean that the diagnostic ability of a test is no better than chance.

Whenever possible, direct comparisons are made; otherwise we performed qualitative indirect comparisons.

Intercooled Stata 8.2 (Stata Corp., College Station, TX) was used for calculations and graphics.