# Newman et al 2000 Study

Accuracy of Predischarge Risk Index as a Test for Predicting Later Development of Hyperbilirubinemia

Newman, Xiong, Gonzales, et al. (2000) reviewed the medical records of 73 neonates with maximum TSB of ≥ 25 mg/dl, compared with 423 randomly selected controls with TSB <25 mg/dl, in order to determine biological and health service predictors of extreme hyperbilirubinemia. The strongest predictors were found to be family history of jaundice in a newborn (OR=6.0), exclusive breastfeeding (OR=5.7), bruising (OR=4.0), Asian race (OR=3.5), cephalhematoma (OR=3.3), maternal age ≥ 25 years (OR=3.1), and lower gestational age (OR=0.6/wk). The authors developed a risk index with this data, assigning a numerical value to each characteristic. In the 32 percent of neonates with an index score of ≤ 7, the risk of developing a TSB level of ≥ 25 mg/dl was about 1 in 16,000. In the one percent of neonates with an index score of > 20, the risk of developing a TSB of ≥ 25 mg/dl was about two percent. If a score of ≤ 10 was used at a cutoff for low risk, 61 percent of newborns would be in the low risk group and about 1 in 4200 would develop a TSB ≥ 25 mg/dl. Even the remaining 39 percent classified as high risk would have only a 1 in 370 risk (0.27 percent) of developing a TSB ≥ 25 mg/dl. Figure 3.7 shows the ROC curve from the Newman, Xiong, Gonzales, et al. (2000) study.

Figure 3.7 Test Performance of Predischarge Risk Index

Data Source:Newman, 2000 [UI#20529193]

Newman, 2000 [#11074857] – Part I

Demographics | Inclusion Criteria | Exclusion Criteria | Study Design
Location: US Setting: Hospital Study period: 1995 to 1996 Mean GA (range): ≥36 wk Mean BW (range): > 2000 g Mean Apgar score at 1 min: ND Breastfed proportion: ND Male: Cases: 67% Controls: 54% Race: Cases: 44% White, 4% Black, 15% Hispanic, 32% Asian; 5% Others Controls: 49% White, 9% Black, 22% Hispanic, 17% Asian; 3% Others Enrolled subjects: 75 Cases; 427 Controls Evaluated subjects: 73 Cases; 423 Controls Number of centers: 11 | All: BW > 2000 g; GA > 36 weeks Cases: TSB within the first 30 days of life ≥ 25 mg/dl Controls: randomly selected sample with TSB < 25 mg/dl | Cases: GA < 36 weeks (2) Controls: hospitalization record not found (1); BW or GA didn’t meet criteria (3) | Case-control study

Newman, 2000 [#11074857] – Part II

Disease/Condition Type (N) | Strategies for Predicting Hyperbilirubinemia | Definition of True Positive | Reference Standard
Near-term or term infants (496) – Cases: infants with hyperbilirubinemia (73) Controls: infants without hyperbilirubinemia (423) | Risk index = 6 (Exclusive breastfeeding) + 6 (Family history of jaundice in a newborn)+ 4 (Bruising noted) + 4 (Asian race) + 3 (Cephalhematoma noted) + 3 (Maternal age ≥ 25 y) + 1 (Male sex) −2 (Black race) + 2 (40-GA) | Risk index > 10 in predicting maximum TSB ≥ 25 mg/dl in infants without early jaundice | Laboratory-base assay of TSB: data from the KPMCP integrated laboratory information system

Newman, 2000 [#11074857] – Part III

Results | | | | | | Biases or Limitations | Comments
Predischarge Risk Assessment: | | | | | | Case-control study (retrospective) is subject to selection bias | Study was government and privately funded Internal validity: B
Risk Zone or Risk Index | Total # of Subject | Outcome present | Outcome absent | Likelihood Ratio | PPV | Case-control study (retrospective) is subject to selection bias | Study was government and privately funded Internal validity: B
Risk Index ≤ 7 | 130 | 1 | 129 | 0.053 | 1/15653 | Case-control study (retrospective) is subject to selection bias | Study was government and privately funded Internal validity: B
Risk Index 8–10 | 121 | 6 | 115 | 0.36 | 1/2327 | Case-control study (retrospective) is subject to selection bias | Study was government and privately funded Internal validity: B
Risk Index 11–15 | 147 | 27 | 120 | 1.5 | 1/540 | Case-control study (retrospective) is subject to selection bias | Study was government and privately funded Internal validity: B
Risk Index 16–20 | 52 | 17 | 35 | 3.3 | 1/251 | Case-control study (retrospective) is subject to selection bias | Study was government and privately funded Internal validity: B
Risk Index > 20 | 11 | 8 | 3 | 18.2 | 1/47 | Case-control study (retrospective) is subject to selection bias | Study was government and privately funded Internal validity: B
For near-term or term infants without early jaundice (N=461), the sensitive, specificity, PPV, and NPV (Risk Index > 10 in predicting TSB ≥ 25 mg/dl) was 88%, 61%, 25%, and 97%, respectively. Of 23 cases exceeded the AAP PhotoRx threshold before their TSB ≥ 25 mg/dl, only 26% received PhotoRx within 8 hrs of exceeding the threshold. The use of PhotoRx within 8 hrs of the AAP guidelines in the control group and in additional group of 30 randomly selected newborns whose maximum TSB were 20–24.9 mg/dl was only 33%. No significant difference was found between cases and controls. | | | | | | Case-control study (retrospective) is subject to selection bias | Study was government and privately funded Internal validity: B