# Peer Reviewers

The peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers. The authors gratefully acknowledge the peer reviewers.

- Cheryl L. Aldridge, MSN, RN, CPNP
- National Association of Pediatric Nurse Practitioners
- Cherry Hill, NJ

- Charles Homer, MD, MPH
- Department of Society, Human Development
- Harvard School of Public Health
- Boston, Massachusetts

- Rachel Nonkin Avchen, MS, PHD
- Centers for Disease Control and Prevention
- National Center on Birth Defects and Developmental Disabilities
- Atlanta, Georgia

- M. Jeffrey Maisels, MB, BCh
- Department of Pediatrics
- William Beaumont Hospital
- Royal Oak, Michigan