# List of Excluded Studies

Arya VB, Agarwal R, Paul VK, Deorari AK. Efficacy of oral phenobarbitone in term “at risk” neonates in decreasing neonatal hyperbilirubinemia: a randomized double-blinded, placebo controlled trial. Indian Pediatrics. 2004;41:327–32. treatment was not phototherapy

Bader D, Yanir Y, Kugelman A, Wilhelm-Kafil M, Riskin A. Induction of early meconium evacuation: is it effective in reducing the level of neonatal hyperbilirubinemia? American Journal of Perinatology. 2005;22:329–33. treatment was not phototherapy

Barko HA, Jackson GL, Engle WD. Evaluation of a point-of-care direct spectrophotometric method for measurement of total serum bilirubin in term and near-term neonates. Journal of Perinatology. 2006; 26:100–105. cannot figure out TSB percentile

Bernaldo AJ, Segre CA. Bilirubin dosage in cord blood: could it predict neonatal hyperbilirubinemia? Sao Paulo Medical Journal = Revista Paulista de Medicina. 2004; 122:99–103. umbilical cord blood

Boo NY, Lee HT. Randomized controlled trial of oral versus intravenous fluid supplementation on serum bilirubin level during phototherapy of term infants with severe hyperbilirubinaemia.[erratum appears in J Paediatr Child Health 2002 Dec;38(6):625]. Journal of Paediatrics & Child Health. 2002; 38:151–55. no adverse events reported/assessed

Boo NY, Ishak S. Prediction of severe hyperbilirubinaemia using the Bilicheck transcutaneous bilirubinometer 8. Journal of Paediatrics & Child Health 43 (4):297 –302. 2007. cannot figure out TSB percentile

Borgard JP, Szymanowicz A, Pellae I, Szmidt-Adjide V, Rota M. Determination of total bilirubin in whole blood from neonates: results from a French multicenter study. Clinical Chemistry & Laboratory Medicine. 2006; 44:1103–10. r; limit of agreement data only

Briscoe L, Clark S, Yoxall CW. Can transcutaneous bilirubinometry reduce the need for blood tests in jaundiced full term babies? Archives of Disease in Childhood Fetal & Neonatal Edition. 2002; 86:F190–F192. cannot figure out TSB percentile

Chen CM, Liu SH, Lai CC, Hwang CC, Hsu HH. Changing position does not improve the efficacy of conventional phototherapy. Acta Paediatrica Taiwanica. 2002; 43:255–58. no adverse events reported/assessed

Chou SC, Palmer RH, Ezhuthachan S, Newman C, Pradell-Boyd B, Maisels MJ et al. Management of hyperbilirubinemia in newborns: measuring performance by using a benchmarking model. Pediatrics. 2003; 112:t-73. no comparisons

Dinesh D. Review of positive direct antiglobulin tests found on cord blood sampling. Journal of Paediatrics & Child Health. 2005; 41:504–7. umbilical cord blood

Duman N, Ozkan H, Serbetcioglu B, Ogun B, Kumral A, Avci M. Long-term follow-up of otherwise healthy term infants with marked hyperbilirubinaemia: should the limits of exchange transfusion be changed in Turkey? Acta Paediatrica. 2004; 93:361–67. no outcome

Ebbesen F, Rasmussen LM, Wimberley PD. A new transcutaneous bilirubinometer, BiliCheck, used in the neonatal intensive care unit and the maternity ward. Acta Paediatrica. 2002; 91:203–11. no data on timing of measurements

Ebbesen F, Agati G, Pratesi R. Phototherapy with turquoise versus blue light. Archives of Disease in Childhood Fetal & Neonatal Edition. 2003; 88:F430–F431. preterm infants

Engle WD, Jackson GL, Sendelbach D, Manning D, Frawley WH. Assessment of a transcutaneous device in the evaluation of neonatal hyperbilirubinemia in a primarily Hispanic population. Pediatrics. 2002; 110:t-7. no data on timing of measurements

Engle WD, Jackson GL, Stehel EK, Sendelbach DM, Manning MD. Evaluation of a transcutaneous jaundice meter following hospital discharge in term and near-term neonates. Journal of Perinatology. 2005; 25:486–90. no data on timing of measurements

Felc Z. Improvement of conventional transcutaneous bilirubinometry results in term newborn infants. American Journal of Perinatology. 2005; 22:173–79. r data only

Gourley GR, Li Z, Kreamer BL, Kosorok MR. A controlled, randomized, double-blind trial of prophylaxis against jaundice among breastfed newborns. Pediatrics. 2005; 116:385–91. treatment was not phototherapy

Grohmann K, Roser M, Rolinski B, Kadow I, Muller C, Goerlach-Graw A et al. Bilirubin measurement for neonates: comparison of 9 frequently used methods. Pediatrics. 2006; 117:1174–83. no data on timing of measurements

Gulcan H, Tiker F, Kilicdag H. Effect of feeding type on the efficacy of phototherapy 41. Indian Pediatrics 44 (1):32 -6. 2007 no adverse events reported/assessed

Ho EY, Lee SY, Chow CB, Chung JW. BiliCheck transcutaneous bilirubinometer: a screening tool for neonatal jaundice in the Chinese population. Hong Kong Medical Journal. 2006; 12:99–102. no data on timing of measurement

Hosono S, Ohno T, Kimoto H, Nagoshi R, Shimizu M, Nozawa M et al. Follow-up study of auditory brainstem responses in infants with high unbound bilirubin levels treated with albumin infusion therapy. Pediatrics International. 2002;44:488–92. treatment was not phototherapy

Janjindamai W, Tansantiwong T. Accuracy of transcutaneous bilirubinometer estimates using BiliCheck in Thai neonates. Journal of the Medical Association of Thailand. 2005;88:187–90. r data only

Johnson LH, Bhutani VK, Brown AK. System-based approach to management of neonatal jaundice and prevention of kernicterus. Journal of Pediatrics. 2002; 140:396–403. case reports of kernicterus (kernicterus registry)

Johnston RV, Anderson JN, Prentice C. Is sunlight an effective treatment for infants with jaundice? Medical Journal of Australia. 2003; 178:403. treatment was not phototherapy

Kaplan M, Herschel M, Hammerman C, Karrison T, Hoyer JD, Stevenson DK. Studies in hemolysis in glucose-6-phosphate dehydrogenase-deficient African American neonates. Clinica Chimica Acta. 2006; 365:177–82. ETCO

Kaplan M, Kaplan E, Hammerman C, Algur N, Bromiker R, Schimmel MS et al. Post-phototherapy neonatal bilirubin rebound: a potential cause of significant hyperbilirubinaemia. Archives of Disease in Childhood. 2006; 91:31–34. no adverse events reported/assessed

Kaplan M, Bromiker R, Schimmel MS, Algur N, Hammerman C. Evaluation of discharge management in the prediction of hyperbilirubinemia: the Jerusalem experience 35. Journal of Pediatrics 150 (4):412 -7. 2007. no comparison group

Kappas A, Drummond GS, Valaes T. A single dose of Sn-mesoporphyrin prevents development of severe hyperbilirubinemia in glucose-6-phosphate dehydrogenase-deficient newborns. Pediatrics. 2001; 108:25–30. G6PD infants only

Kappas A. A method for interdicting the development of severe jaundice in newborns by inhibiting the production of bilirubin. Pediatrics. 2004; 113:t-23. treatment was not phototherapy

Kazmierczak SC, Robertson AF, Briley KP, Kreamer B, Gourley GR. Transcutaneous measurement of bilirubin in newborns: comparison with an automated Jendrassik-Grof procedure and HPLC. Clinical Chemistry. 2004; 50:433–35. r; limit of agreement data only

Knupfer M, Pulzer F, Gebauer C, Robel-Tillig E, Vogtmann C. Predictive value of umbilical cord blood bilirubin for postnatal hyperbilirubinaemia. Acta Paediatrica. 2005; 94:581–87. umbilical cord blood

Lee CY, Chen SJ, Tang RB. Reevaluation of recent criteria for blood exchange transfusion in term infants with hyperbilirubinemia. Acta Paediatrica Taiwanica. 2002; 43:86–90. treatment was not phototherapy

Lim HH, Daniel LM, Lee J, Tan MC. Predicting significant hyperbilirubinaemia and early discharge for glucose-6-phosphate dehydrogenase deficient newborns.[erratum appears in Ann Acad Med Singapore. 2003 Jul; 32(4):570]. Annals of the Academy of Medicine, Singapore. 2003; 32:257–61. G6PD infants only

Maayan-Metzger A, Yosipovitch G, Hadad E, Sirota L. Transepidermal water loss and skin hydration in preterm infants during phototherapy. American Journal of Perinatology. 2001; 18:393–96. no adverse events reported/assessed

Madlon-Kay DJ. Maternal assessment of neonatal jaundice after hospital discharge. Journal of Family Practice. 2002; 51:445–48. maternal assessment of jaundice

Mahajan G, Kaushal RK, Sankhyan N, Sharma RL, Nakra M. Transcutaneous bilirubinometer in assessment of neonatal jaundice in northern India. Indian Pediatrics. 2005; 42:41–45. r data only

Maisels MJ, Kring E. Rebound in serum bilirubin level following intensive phototherapy. Archives of Pediatrics & Adolescent Medicine. 2002; 156:669–72. no adverse events reported/assessed

Maisels MJ, Ostrea EM, Jr., Touch S, Clune SE, Cepeda E, Kring E et al. Evaluation of a new transcutaneous bilirubinometer. Pediatrics. 2004; 113:1628–35. no data on timing of measurements

Maisels MJ, Kring E. The contribution of hemolysis to early jaundice in normal newborns. Pediatrics. 2006; 118:276–79. ETCO

Maisels MJ, Kring E. Transcutaneous bilirubin levels in the first 96 hours in a normal newborn population of > or = 35 weeks’ gestation. Pediatrics. 2006; 117:1169–73. no TSB measures

Makay B, Duman N, Ozer E, Kumral A, Yeilirmak D, Ozkan H. Randomized, controlled trial of early intravenous nutrition for prevention of neonatal jaundice in term and near-term neonates. Journal of Pediatric Gastroenterology & Nutrition. 2007; 44:354–58. not phototherapy

Mehta S, Kumar P, Narang A. A randomized controlled trial of fluid supplementation in term neonates with severe hyperbilirubinemia. Journal of Pediatrics. 2005; 147:781–85. treatment was not phototherapy

Miqdad AM, Abdelbasit OB, Shaheed MM, Seidahmed MZ, Abomelha AM, Arcala OP. Intravenous immunoglobulin G (IVIG) therapy for significant hyperbilirubinemia in ABO hemolytic disease of the newborn. Journal of Maternal-Fetal & Neonatal Medicine. 2004; 16:163–66. ABO hemolytic disease

Mohammadzadeh A, Bostani Z, Jafarnejad F, Mazloom R. Supine versus turning position on bilirubin level during phototherapy in healthy term jaundiced neonates. Saudi Medical Journal. 2004; 25:2051–52. no adverse events reported/assessed

Mohammadzadeh A, Farhat AS, Iranpour R. Effect of clofibrate in jaundiced term newborns. Indian Journal of Pediatrics. 2005; 72:123–26. treatment was not phototherapy

Mukhopadhyay K, Murki S, Narang A, Dutta S. Intravenous immunoglobulins in rhesus hemolytic disease. Indian Journal of Pediatrics. 2003; 70:697–99. hemolytic disease

Murki S, Dutta S, Narang A, Sarkar U, Garewal G. A randomized, triple-blind, placebo-controlled trial of prophylactic oral phenobarbital to reduce the need for phototherapy in G6PD-deficient neonates. Journal of Perinatology. 2005; 25:325–30. G6PD infants only

Newman TB, Liljestrand P, Escobar GJ. Jaundice noted in the first 24 hours after birth in a managed care organization. Archives of Pediatrics & Adolescent Medicine. 2002; 156:1244–50. clinical examination of jaundice

Newman TB, Liljestrand P, Jeremy RJ, Ferriero DM, Wu YW, Hudes ES et al. Outcomes among newborns with total serum bilirubin levels of 25 mg per deciliter or more. New England Journal of Medicine. 2006; 354:1889–900. no adverse events reported/assessed

Okuyama H, Yonetani M, Uetani Y, Nakamura H. End-tidal carbon monoxide is predictive for neonatal non-hemolytic hyperbilirubinemia. Pediatrics International. 2001; 43:329–33. ETCO

Patra K, Storfer-Isser A, Siner B, Moore J, Hack M. Adverse events associated with neonatal exchange transfusion in the 1990s. Journal of Pediatrics. 2004; 144:626–31. adverse events of exchange transfusion

Poland RL, Hartenberger C, McHenry H, Hsi A. Comparison of skin sites for estimating serum total bilirubin in in-patients and out-patients: chest is superior to brow. Journal of Perinatology. 2004; 24:541–43. r; limit of agreement data only

Randeberg LL, Roll EB, Nilsen LT, Christensen T, Svaasand LO. In vivo spectroscopy of jaundiced newborn skin reveals more than a bilirubin index. Acta Paediatrica. 2005; 94:65–71. r data only

Riskin A, Kugelman A, bend-Weinger M, Green M, Hemo M, Bader D. In the eye of the beholder: how accurate is clinical estimation of jaundice in newborns?[erratum appears in Acta Paediatr. 2005 Aug;94(8):1168 Note: Kuglman, A [corrected to Kugelman, A]]. Acta Paediatrica. 2003; 92:574–76. clinical examination of jaundice

Riskin A, bend-Weinger M, Bader D. How accurate are neonatologists in identifying clinical jaundice in newborns? Clinical Pediatrics. 2003;42:153–58. clinical examination of jaundice

Riskin A, David M, Peskin B, Tamir A, Vafsi O, Leibovitz Z et al. The role of umbilical cord alpha fetoprotein as a screening tool for neonatal hyperbilirubinemia. American Journal of Perinatology. 2004; 21:93–98. umbilical cord alpha fetoprotein

Robertson A, Kazmierczak S, Vos P. Improved transcutaneous bilirubinometry: comparison of SpectR(X) BiliCheck and Minolta Jaundice Meter JM-102 for estimating total serum bilirubin in a normal newborn population. Journal of Perinatology. 2002; 22:12–14. r; limit of agreement data only

Rolinski B, Kuster H, Ugele B, Gruber R, Horn K. Total bilirubin measurement by photometry on a blood gas analyzer: potential for use in neonatal testing at the point of care. Clinical Chemistry. 2001; 47:1845–47. r; limit of agreement data only

Rubegni P, Cevenini G, Sbano P, Perrone S, Buonocore G, Lazzeri L et al. Cutaneous colorimetric evaluation of serum concentrations of bilirubin in healthy term neonates: a new methodological approach. Skin Research & Technology. 2005; 11:70–75. r data only

Samanta S, Tan M, Kissack C, Nayak S, Chittick R, Yoxall CW. The value of Bilicheck as a screening tool for neonatal jaundice in term and near-term babies. Acta Paediatrica. 2004; 93:1486–90. cannot figure out TSB percentile

Sanpavat S. The use of clinical practice guideline on hyperbilirubinemia: rule or guideline. Journal of the Medical Association of Thailand. 2004; 87:1250–1252. review

Sanpavat S, Nuchprayoon I. Noninvasive transcutaneous bilirubin as a screening test to identify the need for serum bilirubin assessment. Journal of the Medical Association of Thailand. 2004; 87:1193–98. cannot figure out TSB percentile

Sarici SU, Yurdakok M, Serdar MA, Oran O, Erdem G, Tekinalp G et al. An early (sixth-hour) serum bilirubin measurement is useful in predicting the development of significant hyperbilirubinemia and severe ABO hemolytic disease in a selective high-risk population of newborns with ABO incompatibility. Pediatrics. 2002; 109:e53. ABO incompatibility

Sarin M, Dutta S, Narang A. Randomized controlled trial of compact fluorescent lamp versus standard phototherapy for the treatment of neonatal hyperbilirubinemia. Indian Pediatrics. 2006; 43:583–90. no usable data

Shetty AP. A study of hyperbilirubinemia and the effect of phototherapy among full term newborns with a view to develop a nursing care protocol based on identified needs. Nursing Journal of India. 2003; 94:149–50. no usable data

Shinwell ES, Sciaky Y, Karplus M. Effect of position changing on bilirubin levels during phototherapy. Journal of Perinatology. 2002; 22:226–29. no adverse events reported/assessed

Simpson KR. Kernicterus prevention. American Journal of Maternal Child Nursing. 2007; 32:132 review

Singh M, Batish MK, Singh M, Singh K, Locham KK, Garg R. Correlation of plasma color index with serum bilirubin in neonatal jaundice. Indian Pediatrics. 2001; 38:278–80. r data only

Slusher TM, Angyo IA, Bode-Thomas F, Akor F, Pam SD, Adetunji AA et al. Transcutaneous bilirubin measurements and serum total bilirubin levels in indigenous African infants. Pediatrics. 2004; 113:1636–41. r; limit of agreement data only

Stevenson DK, Fanaroff AA, Maisels MJ, Young BW, Wong RJ, Vreman HJ et al. Prediction of hyperbilirubinemia in near-term and term infants. Pediatrics. 2001; 108:31–39. ETCO

Szabo P, Wolf M, Bucher HU, Fauchere JC, Haensse D, Arlettaz R. Detection of hyperbilirubinaemia in jaundiced full-term neonates by eye or by bilirubinometer? European Journal of Pediatrics. 2004; 163:722–27. no data on timing of measurements

Szabo P, Wolf M, Bucher HU, Haensse D, Fauchere JC, Arlettaz R. Assessment of jaundice in preterm neonates: comparison between clinical assessment, two transcutaneous bilirubinometers and serum bilirubin values. Acta Paediatrica. 2004; 93:1491–95. cannot figure out TSB percentile

Thaithumyanon P, Visutiratmanee C. Double phototherapy in jaundiced term infants with hemolysis. Journal of the Medical Association of Thailand. 2002; 85:1176–81. hemolysis infants only

Wananukul S, Praisuwanna P. Transepidermal water loss during conventional phototherapy in nonhemolytic hyperbilirubinemia term infants. Journal of the Medical Association of Thailand. 2001; 84:Suppl-50. no adverse events reported/assessed

Wong CM, van Dijk PJ, Laing IA. A comparison of transcutaneous bilirubinometers: SpectRx BiliCheck versus Minolta AirShields. Archives of Disease in Childhood Fetal & Neonatal Edition. 2002; 87:F137–F140. cannot figure out TSB percentile

Wong V, Chen WX, Wong KY. Short- and long-term outcome of severe neonatal nonhemolytic hyperbilirubinemia. Journal of Child Neurology. 2006; 21:309–15. not relevant

Yap SH, Mohammad I, Ryan CA. Avoiding painful blood sampling in neonates by transcutaneous bilirubinometry. Irish Journal of Medical Science. 2002; 171:188–90. r; limit of agreement data only

Yasuda S, Itoh S, Isobe K, Yonetani M, Nakamura H, Nakamura M et al. New transcutaneous jaundice device with two optical paths. Journal of Perinatal Medicine. 2003; 31:81–88. r; limit of agreement data only