# Combined Evidence Tables

Agarwal, 2002 [UI#12196683]

Study characteristics | Inclusion/Exclusion Criteria | Population description | Test Protocol | Reference Standard | Definition of Positives
Birth yrs: May to September 2001 # Enrolled: 220 # Analyzed: 213 Mean GA (range): 38 (35–42) Mean BW (range): 2827 g %Male: 54% Race: Asian Mean Apgar (5 min): ND Comorbidity: ABO incompatibility (n=1); G6PD (n-3) Location: India Sites: Single Design: Prospective Funding: ND | Inclusion: GA ≥35 wks, absence of significant illness requiring NICU admission for >12 hr, absence of major congenital malformations; residing near the hospital and whose parents agreed to come for follow-up All infants were discharged as per unit policy after 72 hr Exclusion: NICU admission; Rh hemolysis | Setting: Healthy babies, GA ≥35 wks; residing near the hospital Patient selection process:^A^ Selected, based on the convenience | Device: Spectrophotometrer (Bil Micrometer – Auto 2 Type, Kohsoku Denki, Tokyo Japan) Tested sites: Venous whole blood Timing vs Reference Test: ND Time of measurements: 24 ±6 hr (range 20–30 hr) after birth, pre-discharge Number of measurements: Triplicate, and average of two closest values was taken | Device: Same as test device Tested sites: Venous whole blood Time of measurements: After discharge at 72 hr Number of measurements:^B^ Triplicate, and average of two closest values was taken | Definition of positive Reference Test: TSB ≥17 mg/dL at 72 hr Only perform post-discharge serum bilirubin if clinical estimation of serum bilirubin >10 mg/dL (unclear how this estimation was done). Clinically detectable jaundice was present in 146 (69%) infants Definition of positive Index Test: TSB >6 mg/dL

A consecutive/random sampling from general population/prescreening based on selection criteria (describe)

B Implies times the probe was applied on the baby – not how many readings the machine takes each time

Results (Concordance metrics): No data

Study | Comparison | Metric | Results | Comments

Results (Sensitivity, specificity and ROC analysis):

Study | Comparison | Index cutoff | Reference Cutoff | TP | FN | FP | TN | Sens | Spec | AUC-ROC | Comments
Agarwal, 2002 | Pre-discharge TSB vs. post-discharge TSB | >6 mg/dL | ≥17 mg/dL @ 72 hr | 21 | 1 | 56 | 135 | 95% | 70.6% | ND | ≥17 mg/dL @ 72 hr is ≥95 %tile on Bhutani’s nomogram
Agarwal, 2002 | Bhutani risk zone vs. post-discharge TSB | ≥Bhutani high intermediate or high-risk zone | ≥17 mg/dL @ 72 hr | 20 | 2 | 50 | 141 | 91% | 73.8% | ND | ≥17 mg/dL @ 72 hr is ≥95 %tile on Bhutani’s nomogram

Other results:

143 (67%) infants were in the low risk or low intermediate risk zone classified according to Bhutani’s nomogram. In other word, 70 infants were classified as in the high intermediate or high-risk zone. Subsequently hyperbilirubinemia developed in 20/70 (28.6%) of these infants. This also means that 2 (14%) of the 143 infants in the low risk or low intermediate risk zone developed hyperbilirubinemia.

Quality items:

Quality item | | Comments
Consecutive patients or random sampling Prospective study No verification bias Index test assessor blinded to Reference Test^A^ Index test assessor blinded to clinical Hx or other information (such as any lab values) Reference test assessor blinded to clinical Hx or other information (such as any lab values) Proper analysis of replicate measurements in different times Random order of test measurements Time delay between index and reference test measurements Adequate description of index test^B^ Adequate description of reference test^B^ | No Yes No Yes Yes Yes N/A N/A N/A Yes Yes | 69% infants had post-discharged serum bilirubin measurements
Overall Quality Grade (A to C) | C | 31% infants were unverified

A Or any other test in case multiple tests were evaluated

B Please make a judgment, based on the items recorded in the 1^st^ table

Bader, 2006 UI 16450744

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria/Comorbidities/modifying factors | Phototherapy procedures | Dose (time under phototherapy) (hours) | Adverse events, side effects
Birth years: nd # Enrolled: 10 # Evaluate: 10 Mean GA: 38.6 wks Mean BW: 3203 g %Male: nd Race: nd Country: Israel Sites: Single Funding: | Before phototherapy vs. during phototherapy study on cardio-respiratory activity using polysomnography (PSG) | Healthy term infants with physiologic (no hemolysis or G6PD) jaundice; >37 wk; Apgar >8, birth weight 2500 – 4000 g; excluded sepsis, anemia, dehydration | Nd PSG before phototherapy at 3.6±0.8 d PSG during phototherapy at 4.5±0.8 d | Mean TSB before phototherapy: 14.5±1.4 mg/dL | | Before phototherapy | During phototherapy | P
Birth years: nd # Enrolled: 10 # Evaluate: 10 Mean GA: 38.6 wks Mean BW: 3203 g %Male: nd Race: nd Country: Israel Sites: Single Funding: | Before phototherapy vs. during phototherapy study on cardio-respiratory activity using polysomnography (PSG) | Healthy term infants with physiologic (no hemolysis or G6PD) jaundice; >37 wk; Apgar >8, birth weight 2500 – 4000 g; excluded sepsis, anemia, dehydration | Nd PSG before phototherapy at 3.6±0.8 d PSG during phototherapy at 4.5±0.8 d | Mean TSB before phototherapy: 14.5±1.4 mg/dL | Active sleep
Birth years: nd # Enrolled: 10 # Evaluate: 10 Mean GA: 38.6 wks Mean BW: 3203 g %Male: nd Race: nd Country: Israel Sites: Single Funding: | Before phototherapy vs. during phototherapy study on cardio-respiratory activity using polysomnography (PSG) | Healthy term infants with physiologic (no hemolysis or G6PD) jaundice; >37 wk; Apgar >8, birth weight 2500 – 4000 g; excluded sepsis, anemia, dehydration | Nd PSG before phototherapy at 3.6±0.8 d PSG during phototherapy at 4.5±0.8 d | Mean TSB before phototherapy: 14.5±1.4 mg/dL | Respiratory Rate | 54.3 ± 10.3 | 49.1 ± 10.8 | <0.05
Birth years: nd # Enrolled: 10 # Evaluate: 10 Mean GA: 38.6 wks Mean BW: 3203 g %Male: nd Race: nd Country: Israel Sites: Single Funding: | Before phototherapy vs. during phototherapy study on cardio-respiratory activity using polysomnography (PSG) | Healthy term infants with physiologic (no hemolysis or G6PD) jaundice; >37 wk; Apgar >8, birth weight 2500 – 4000 g; excluded sepsis, anemia, dehydration | Nd PSG before phototherapy at 3.6±0.8 d PSG during phototherapy at 4.5±0.8 d | Mean TSB before phototherapy: 14.5±1.4 mg/dL | Heart Rate | 125.9 ± 11.7 | 129.7 ± 15.3 | <0.05
Birth years: nd # Enrolled: 10 # Evaluate: 10 Mean GA: 38.6 wks Mean BW: 3203 g %Male: nd Race: nd Country: Israel Sites: Single Funding: | Before phototherapy vs. during phototherapy study on cardio-respiratory activity using polysomnography (PSG) | Healthy term infants with physiologic (no hemolysis or G6PD) jaundice; >37 wk; Apgar >8, birth weight 2500 – 4000 g; excluded sepsis, anemia, dehydration | Nd PSG before phototherapy at 3.6±0.8 d PSG during phototherapy at 4.5±0.8 d | Mean TSB before phototherapy: 14.5±1.4 mg/dL | Quiet sleep
Birth years: nd # Enrolled: 10 # Evaluate: 10 Mean GA: 38.6 wks Mean BW: 3203 g %Male: nd Race: nd Country: Israel Sites: Single Funding: | Before phototherapy vs. during phototherapy study on cardio-respiratory activity using polysomnography (PSG) | Healthy term infants with physiologic (no hemolysis or G6PD) jaundice; >37 wk; Apgar >8, birth weight 2500 – 4000 g; excluded sepsis, anemia, dehydration | Nd PSG before phototherapy at 3.6±0.8 d PSG during phototherapy at 4.5±0.8 d | Mean TSB before phototherapy: 14.5±1.4 mg/dL | Respiratory Rate | 46.0 ± 9.9 | 45.7 ± 12.0 | NS
Birth years: nd # Enrolled: 10 # Evaluate: 10 Mean GA: 38.6 wks Mean BW: 3203 g %Male: nd Race: nd Country: Israel Sites: Single Funding: | Before phototherapy vs. during phototherapy study on cardio-respiratory activity using polysomnography (PSG) | Healthy term infants with physiologic (no hemolysis or G6PD) jaundice; >37 wk; Apgar >8, birth weight 2500 – 4000 g; excluded sepsis, anemia, dehydration | Nd PSG before phototherapy at 3.6±0.8 d PSG during phototherapy at 4.5±0.8 d | Mean TSB before phototherapy: 14.5±1.4 mg/dL | Heart Rate | 123.1 ± 12.5 | 127.7 ± 14.4 | NS
Birth years: nd # Enrolled: 10 # Evaluate: 10 Mean GA: 38.6 wks Mean BW: 3203 g %Male: nd Race: nd Country: Israel Sites: Single Funding: | Before phototherapy vs. during phototherapy study on cardio-respiratory activity using polysomnography (PSG) | Healthy term infants with physiologic (no hemolysis or G6PD) jaundice; >37 wk; Apgar >8, birth weight 2500 – 4000 g; excluded sepsis, anemia, dehydration | Nd PSG before phototherapy at 3.6±0.8 d PSG during phototherapy at 4.5±0.8 d | Mean TSB before phototherapy: 14.5±1.4 mg/dL | Mean ratio of breath depth before/after apnea (active sleep)
Birth years: nd # Enrolled: 10 # Evaluate: 10 Mean GA: 38.6 wks Mean BW: 3203 g %Male: nd Race: nd Country: Israel Sites: Single Funding: | Before phototherapy vs. during phototherapy study on cardio-respiratory activity using polysomnography (PSG) | Healthy term infants with physiologic (no hemolysis or G6PD) jaundice; >37 wk; Apgar >8, birth weight 2500 – 4000 g; excluded sepsis, anemia, dehydration | Nd PSG before phototherapy at 3.6±0.8 d PSG during phototherapy at 4.5±0.8 d | Mean TSB before phototherapy: 14.5±1.4 mg/dL | | 1.1 ± 0.2 | 1.3 ± 0.3 | <0.02
Birth years: nd # Enrolled: 10 # Evaluate: 10 Mean GA: 38.6 wks Mean BW: 3203 g %Male: nd Race: nd Country: Israel Sites: Single Funding: | Before phototherapy vs. during phototherapy study on cardio-respiratory activity using polysomnography (PSG) | Healthy term infants with physiologic (no hemolysis or G6PD) jaundice; >37 wk; Apgar >8, birth weight 2500 – 4000 g; excluded sepsis, anemia, dehydration | Nd PSG before phototherapy at 3.6±0.8 d PSG during phototherapy at 4.5±0.8 d | Mean TSB before phototherapy: 14.5±1.4 mg/dL | 6 infants had apnea in and out of phototherapy, trend towards increase in central apnea duration while under phototherapy (P=0.07), and increased heart rate under phototherapy as compared to no phototherapy (P<0.02).

Statistical analyses and adjustment for confounders | Bias/limitations Comments

Bhutani, 2006 [UI#16881988]

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria | Managements of Hyperbilirubinemia (or Interventions) | Definitions of the Comparison group(s)
Birth yrs: 1993–1995, 1996–1998, 1999–2000; 2001–2003 birth cohorts # Enrolled: 11,114 (1993–1995), 10,701 (1996–1998), 7,178 (1999–2000), ND (2001–2003) # Evaluate: 7,929 (1993–1995), 8,186 (1996–1998), 6,395 (1999–2000), 11,995 (2001–2003) Mean GA (range): ≥35 wks Mean BW (range): ≥2500 g for GA ≥35 wk, or ≥2000 g for GA ≥36 wk %Male: ND Race: ND Mean Apgar (5 min): ND Country: US Sites: Single Funding: Private | Comparisons of historical birth cohorts in the same urban hospital Note: For the purpose of this review, we focus only on the birth cohort from 1996–1998 (universal TSB screening the postdischarge follow-up as Bhutani’s hour-specific bilirubin nomogram was implemented), and on the birth cohort from 1999–2000 (an organized institutional systems-based management of newborn jaundice was implemented). | Term or near-term infants Exclusion criteria: low BW preterm infants admitted to well baby nursery and any infant admitted to and treated in the intensive care nursery for neonatal illness | Universal TSB screening (1993–1995): (a) universal TSB, (b) unfettered nursing access to TSB orders, (c) individualized lactation support Universal TSB screening and postdischarge follow-up as per the hour-specific bilirubin nomogram (1996–1998): Institutional approach consisted of (a) universal TSB, (b) unfettered nursing access to TSB orders, (c) lactation support program, (d) nursing and parent education program for newborn jaundice Systems-based guideline (1999–2000): (a) visual recognition of jaundice, (b) measurement of bilirubin values, (c) lactation and nutrition support, and (d) parent education including the need for follow-up. Well baby care was provided by >18 practicing pediatricians, several pediatric nurse practitioners, and home care nursing agencies. All babies were recommended for jaundice follow-up within 24 or 48 hrs. This is a framework rather than a rigid rule that allowed for individual physician practice variations. Data on clinical and demographic risk factors for hyperbilirubinemia were recorded pre-discharge. Interventions with PhotoRx followed AAP (1994) guideline. Home-based PhotoRx was used on an occasional basis (<15%) by a small group of physicians. | 1993–1995 (universal TSB screening without nomogram) 1996–1998 (universal TSB screening with nomogram) 1999–2000 (systems-based approach) 2001–2003 (established program, follow-up)

Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | | Bias/limitations Comments
Use of intensive PhotoRx Use of exchange transfusion | No statistical testing Frequencies only | - Use of intensive PhotoRx and exchange transfusion: | | | | | A: strong, B: moderate, C: weak | A | B | C
Use of intensive PhotoRx Use of exchange transfusion | No statistical testing Frequencies only | Phases | Years | Well Baby Discharges (N) | Hospital-based Intensive PhotoRx (%) | Exchange Transfusion | Selection | x
Use of intensive PhotoRx Use of exchange transfusion | No statistical testing Frequencies only | Universal TSB (pre-nomogram) | 1993–1995 | 7,929 | 356 (4.5%) | 6 (1:1,322) | Study design | | | x
Use of intensive PhotoRx Use of exchange transfusion | No statistical testing Frequencies only | Universal TSB with nomogram | 1996–1998 | 8,186 | 446 (5.4%) | 5 (1:1,637) | Confounder | | x
Use of intensive PhotoRx Use of exchange transfusion | No statistical testing Frequencies only | Systems-based approach | 1999–2000 | 6,395 | 159 (2.5%) | 2 (1:3,198) | Blinding | | | x
Use of intensive PhotoRx Use of exchange transfusion | No statistical testing Frequencies only | Established program | 2001–2003 | 11,995 | 156 (1.3%) | 1 (1:11,995) | Data collection | | | x
Use of intensive PhotoRx Use of exchange transfusion | No statistical testing Frequencies only | Precise data for home PhotoRx administration were not available. However, the usage and prescriptions for home PhotoRx by hime nursing agencies were not increased during 1995 to 2000. There was no effort to promote home PhotoRx and the behavior of practice pediatricians appeared unchanged.; - During the nomogram development phase and the initiation of a systems-based program, a steady and significant decline in readmission was noted from 14 (in 1994) to 5.5 infants per 1000 well babies discharged in 2001 to 2003. | | | | | Withdraw and dropout | | x
Use of intensive PhotoRx Use of exchange transfusion | No statistical testing Frequencies only | | | | | | Analyses | | | x
Use of intensive PhotoRx Use of exchange transfusion | No statistical testing Frequencies only | | | | | | Intervention integrity | | | x
Use of intensive PhotoRx Use of exchange transfusion | No statistical testing Frequencies only | | | | | | Overall: C Unclear when and how the clinical and demographic risk factors for hyperbilirubinemia were used in management of jaundice; Unclear whether TcB measurements were used and how often they were used in systems-based approach. Author stated that “the behavior of practice pediatricians appeared unchanged” but not sure how this “appearance” was observed.

Boo, 2006 UI 16924356

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria/Comorbidities/modifying factors | Phototherapy procedures | Dose (time under phototherapy) (hours) | Adverse events, side effects
Birth years: 2005 # Enrolled: 106 # Evaluate: 106 Mean GA: 38.8 wks Mean BW: 3042 g %Male: 57% Race: Asian Country: Singapore Sites: Single Funding: | RCT of clingfilm vs. no clingfilm with X-over; only data from the no clingfilm arm were extracted | Healthy term infants who needs phototherapy; eligible infants with severe hyperbilirubinemia recruited only after TSB decreased to <17.5 mg/dL | No clothing except for diaper; phototherapy light panel (Madela, Switzerland) 25 cm above infant | 2 h | 2/81 (2.5%) infants with initial core temperature of 36.5–37.5° decreased to <36.5° C after 2 h of phototherapy; 29/81 (36%) infants with initial core temperature of 36.5–37.5° increased to >37.5° C after 2 h of phototherapy

Statistical analyses and adjustment for confounders | Bias/limitations Comments

Djokomuljanto, 2006 U 16877479

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria/Comorbidities/modifying factors | Phototherapy procedures | Dose (time under phototherapy) (hours) | Adverse events, side effects
Birth year: 2005 # Enrolled: 100 # Evaluate: 97 Mean GA: wks Mean BW: 3040g %Male: 56% Race: Country: Malaysia Sites: Single Funding: | RCT, subjects were enrolled based on the convenience of the main investigator (when he was working or on call); phototherapy with white curtain (n=51) vs. phototherapy without white curtain (n=49); followup 24 h after stopping phototherapy | Uncomplicated hyperbilirubinemia requiring only single phototherapy; included subjects with G6PD↓ and ABO incompatibility; excluded patients with TSB close to exchange transfusion criteria; all breastfeeding; subjects who were not rooming-in received formula at night | TSB at start of phototherapy: 15.4 mg/dL | Median duration of phototherapy: with white curtain: 12 h; Without white curtain: 34 h | No hypo or hyperthermia; no significant weight loss; no skin or gastrointestinal problems; no detectable abnormalities on neurological exam before discharge

Statistical analyses and adjustment for confounders | Bias/limitations Comments

Eggert, 2006 [UI#16651290]

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria | Managements of Hyperbilirubinemia (or Interventions) | Definitions of the Comparison group(s)
Birth yrs: March 1, 2001 to December 31, 2002 (pre universal TSB/TcB screening); January 1, 2003 to December 31, 2004 (post universal TSB/TcB screening) # Enrolled: ND # Evaluate: 48,798 (March 1, 2001 to December 31, 2002); 52,483 (January 1, 2003 to December 31, 2004) Mean GA (range): ≥35 wks Mean BW (range): ND %Male: ND Race: ND Mean Apgar (5 min): ND Country: US Sites: Multi Funding: ND | Historic cohorts | All infants delivered at ≥35 weeks’s gestation, within the 18-hospital system during 2 periods of time: March 1, 2001 to December 31, 2002, and January 1, 2003 to December 31, 2004 | A bilirubin screening program, instituted in December 2002, called for a TSB or TcB bilirubin measurement to be performed on every infant, either at the recognition of clinical jaundice or before discharge, regardless whether jaundice was observed. Two (out of 18) hospitals used a screening jaundice meter for TcB estmation of bilirubin levels (BiliCheck). Modified Bhutani’s hour-specific bilirubin nomogram was used because high number of infants had bilirubin values in the intermediate- and high-risk zones of the Bhutani’s nomogram. If ≥40 %tile, the care provider was notified and intervention, evaluation, and follow-up was arranged as deemed necessary. | Post universal TSB/TcB screening vs. pre universal TSB/TcB screening

Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | | Bias/limitations Comments
Readmissions for hyperbilirubinemia: taking the birth cohort of patients at ≥35 weeks’s gestation seen in the well nursery and then querying case mix for any admission with a matching Master Patient Index number and a diagnosis of jaundice. | Chi-square test | - The incidence of severe hyperbilirubinemia among infants ≥35 weeks’s gestation | | | | | A: strong, B: moderate, C: weak | A | B | C
| Chi-square test | | No. of Infants | TSB, mg/dL | | | Selection | | x
| Chi-square test | | No. of Infants | ≥20 | ≥25 | ≥30 | Study design | | | x
| Chi-square test | March 1, 2001 to Dec 31, 2002 | 48,798 | 1:77 | 1:1522 | 1:9742 | Confounder | | | x
| Chi-square test | Jan 1, 2003 to Dec 31, 2004 | 52,483 | 1:142 | 1:4037 | 1:17494 | Blinding | | | x
| Chi-square test | | P-value | <.0001 | <.005 | .24 | Data collection | | x
| Chi-square test | - The incidence of hospital readmission for hyperbilirubinemia | | | | | Withdraw and dropout | | x
| Chi-square test | | No. of Infants | | No. Readmitted (%) | | Analyses | | | x
| Chi-square test | March 1, 2001 to Dec 31, 2002 | 48,798 | | 268 (0.55) | | Intervention integrity | | x
| Chi-square test | Jan 1, 2003 to Dec 31, 2004 | 52,483 | | 226 (0.43) | | Overall: C Did not control for potential confounding
| Chi-square test | P-value | | | <.005 | | Overall: C Did not control for potential confounding
| Chi-square test | - 13 infants developed extreme hyperbilirubinemia (≥25 mg/dL). Age at discharged ranged from 23 to 48 hours. Age at readmission ranged from 3 to 11 days. Peak TSB ranged from 25.1 to 36.7 mg/dL. Two had hemolysis and one had sepsis. All treated by PhotoRx, but none underwent exchange transfusion. None had abnormal signs of brainstem auditory evoked response. | | | | | Overall: C Did not control for potential confounding

Ho, 2006 [UI#16849367]

Study characteristics | Inclusion/Exclusion Criteria | Population description | Test Protocol | Reference Standard | Definition of Positives
Birth yrs: April to September 2005 # Enrolled: 1,621 # Analyzed: 997 Mean GA (range): 39 (35–42) wks Mean BW (range): ND %Male: ND Race: 95.2% Chinese Mean Apgar (5 min): ND Country: Hong Kong Sites: Single Design: Retrospective Funding: ND | Inclusion: Healthy term or near-term newborns with a GA of >35 wks Paired TSB was measured if the TcB was >40^th^ %tile on Bhutani monogram Exclusion: Sick newborns who required admission to special care baby or neonatal ICU Infants received PhotoRx | Setting: Healthy term or near-term newborns with a GA of >35 wks, with TcB was >40^th^ %tile Patient selection process:^A^ Selected, based on pre-screening | Device: JM-103 Minolta Airshields Tested sites: mid-sternum Timing vs Reference Test: 30 min Time of measurements: 97% were taken within the first 3 days of life (median age = 32.9 hrs, ranged 12.1–139.6 hr) Number of measurements: 1 | Device: Photometric analyser Tested sites: blood Time of measurements: Within 30 min if the initial TcB level was >40^th^ %tile Number of measurements:^B^ 1 | Definition of positive Reference Test: AAP low risk for PhotoRx AAP medium risk for PhotoRx AAP high risk for PhotoRx Definition of positive Index Test: >75 %tile by TcB >95^th^ %tile by TcB

A consecutive/random sampling from general population/prescreening based on selection criteria (describe)

B Implies times the probe was applied on the baby – not how many readings the machine takes each time

Results (Concordance metrics):

Study | Comparison | Metric | Results | Comments
Ho, 2006 | TcB vs. TSB | Bland and Altman LOA | - Mean difference = 21.7 μmol/l (SD 21.2, p<0.001); - 95% limits of agreement: −19.9 to 63.3 μmol/l; - The range of difference increased in patient with TSB level >200 μmol/l

Results (Sensitivity, specificity and ROC analysis):

Study | Comparison | Index cutoff | Reference Cutoff | TP | FN | FP | TN | Sens | Spec | AUC-ROC | Comments
Ho, 2006 | TcB vs. AAP Low risk | >40^th^ %tile | AAP Low risk | Improper analysis | Improper analysis | Improper analysis | Improper analysis | Improper analysis | Improper analysis | | Because they have the used 40%tile as inclusion criterion, and to decide when to take TSB measurements, these analyses are improper.
Ho, 2006 | TcB vs. AAP Medium risk | >40^th^ %tile | AAP Medium risk | Improper analysis | Improper analysis | Improper analysis | Improper analysis | Improper analysis | Improper analysis | | Because they have the used 40%tile as inclusion criterion, and to decide when to take TSB measurements, these analyses are improper.
Ho, 2006 | TcB vs. AAP High risk | >40^th^ %tile | AAP High risk | Improper analysis | Improper analysis | Improper analysis | Improper analysis | Improper analysis | Improper analysis | | Because they have the used 40%tile as inclusion criterion, and to decide when to take TSB measurements, these analyses are improper.
Ho, 2006 | TcB vs. AAP Low risk | >75^th^ %tile | AAP Low risk | 1 | 0 | 441 | 555 | 100 | 55.7
Ho, 2006 | TcB vs. AAP Low risk | >95^th^ %tile | AAP Low risk | 1 | 0 | 96 | 900 | 100 | 90.4
Ho, 2006 | TcB vs. AAP Medium risk | >75^th^ %tile | AAP Medium risk | 8 | 0 | 434 | 555 | 100 | 56.1
Ho, 2006 | TcB vs. AAP Medium risk | >95^th^ %tile | AAP Medium risk | 6 | 2 | 92 | 897 | 75 | 90.7
Ho, 2006 | TcB vs. AAP High risk | >75^th^ %tile | AAP High Risk | 52 | 8 | 390 | 547 | 86.7 | 58.4
Ho, 2006 | TcB vs. AAP High risk | >95^th^ %tile | AAP High Risk | 27 | 33 | 70 | 867 | 45 | 92.7f

Quality items:

Quality item | | Comments
Consecutive patients or random sampling Prospective study No verification bias Index test assessor blinded to Reference Test^A^ Index test assessor blinded to clinical Hx or other information (such as any lab values) Reference test assessor blinded to clinical Hx or other information (such as any lab values) Proper analysis of replicate measurements in different times Random order of test measurements Time delay between index and reference test measurements Adequate description of index test^B^ Adequate description of reference test^B^ | No No Yes Yes Yes Yes N/A N/A Yes Yes | They included only infants with paired measurements; Technically they have no verification bias if one disregards the 40^th^ %tile for the index test (TcB). However, see general comment below.
Overall Quality Grade (A to C) | C | Spectrum effects make the sensitivity and specificity difficult to interpret. This study focused on 1) children with TcB >40%tile (n=1621); 2) among them, those with paired measurements (997/1621 with TcB >40%tile). Moreover, the authors did improper analyses – see comment on results section

A Or any other test in case multiple tests were evaluated

B Please make a judgment, based on the items recorded in the 1^st^ table

Keren, 2005 [UI#15781937]

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria | Managements of Hyperbilirubinemia (or Interventions) | Definitions of the Comparison group(s)
Birth yrs: 1993–1997 # Enrolled: 996 # Evaluate: 899 Mean GA (range): 20% <38 wks, 55% 38–39 wks; 25% ≥ 40 wks Mean BW (range): 3,300 g %Male: 52% Race: 43% White, 39% Black, 4% Hispanic, 8% Asian; 5% Other Mean Apgar (5 min): ND Location: US Sites: Single Funding: Government | Retrospective cohort study | BW ≥2000 g if GA ≥36 weeks; BW ≥ 2500 g if GA ≥35 weeks Infants who participated in the hospital’s early discharge follow-up program (n=2,976), which was offered to all mothers discharged within 48 hours after vaginal deliveries or 72 hours after caesarean sections who could not have their infant seen by a provider within a day or two; Coombs negative Infants with both pre- and post-discharge TSBs measured in the study period (n=899) Exclusion: PhotoRx during the birth hospitalization (n=18), treated in the intensive care nursery for nay period of time prior to discharge (n=118) | Hospital-supervised early discharge follow-up program for healthy term or near-term infants As part of the early discharge follow-up program, an effort was made to obtain TSB levels in the hospital for all infants prior to discharge and on follow up. In 199–94, most infants had pre-discharge TSBs but only about 40% had both pre- and post-discharge TSBs. In 1995–97, more than 75% of all infants in the program had both TSB measurements. No PhotoRx during birth hospitalization | Not applicable

Keren, 2005 [UI#15781937] - Q2 Results

Outcome Definition | Statistical analyses and confounders adjusted | | Results | | | | | Bias/limitations Comments
Significant hyperbilirubinemia: post-discharge TSB >95^th^ centile on Bhutani hour specific bilirubin nomogram (nearly identical to the PhotoRx threshold curve recommended for “medium risk” infants in the AAP’s 2004 clinical practice guideline | Clinical risk factor score: | | - Predictive properties of the clinical risk factor score using various cut-off points for a positive test: | | | | | A: strong, B: moderate, C: weak | A | B | C
| | Score | Risk factor score | Test + (n) | Post-discharge TSB >95^th^ centile (n) | Sensitivity (95% CI) | Specificity (95% CI) | Selection | x
| BW (g)– | | ≥0 | 884 | 97 | 1.0 (0.96–1.00) | 0 (0–0) | Study design | | x
| 2000–2500 | 0 | ≥8 | 777 | 95 | 0.98 (0.93–1.00) | 0.13 (0.11–0.16) | Confounder | x
| 2501–3000 | 3 | ≥12 | 547 | 83 | 0.86 (0.77–0.92) | 0.41 (0.38–0.45) | Blinding | | x
| 3001–3500 | 6 | ≥16 | 244 | 52 | 0.54 (0.43–0.64) | 0.76 (0.72–0.79) | Data collection | x
| 3501–4000 | 9 | ≥20 | 86 | 21 | 0.22 (0.14–0.31) | 0.92 (0.90–0.94) | Withdraw and dropout | x
| 4001–4500 | 12 | ≥24 | 7 | 2 | 0.02 (0–0.07) | 0.99 (0.99–1.00) | Analyses | x
| 4501–5000 | 15 | - Likelihood ratios (LR) and post-test probabilities (PTP) for specific clinical risk score levels: | | | | | Intervention integrity | x
| GA <38 wk | 5 | Risk score | Post-discharge TSB >95^th^ centile (n) | Post-discharge TSB ≤95^th^ centile (n) | LR | PTP | Overall: B* Did not assess the predictability of the risk score in an independent sample *This quality grading is for Keren, 2005 - Q2 Results only
| Oxytocin | 4 | 0–7 | 2 | 105 | 0.15 | 0.02 | Overall: B* Did not assess the predictability of the risk score in an independent sample *This quality grading is for Keren, 2005 - Q2 Results only
| Vacuum delivery | 4 | 8–11 | 12 | 218 | 0.45 | 0.05 | Overall: B* Did not assess the predictability of the risk score in an independent sample *This quality grading is for Keren, 2005 - Q2 Results only
| Exclusive BF | 5 | 12–15 | 31 | 272 | 0.92 | 0.10 | Overall: B* Did not assess the predictability of the risk score in an independent sample *This quality grading is for Keren, 2005 - Q2 Results only
| Breast and bottle feeding | 4 | 16–19 | 31 | 127 | 1.98 | 0.20 | Overall: B* Did not assess the predictability of the risk score in an independent sample *This quality grading is for Keren, 2005 - Q2 Results only
| Breast and bottle feeding | 4 | 20–23 | 19 | 60 | 2.57 | 0.24 | Overall: B* Did not assess the predictability of the risk score in an independent sample *This quality grading is for Keren, 2005 - Q2 Results only
| Breast and bottle feeding | 4 | ≥24 | 2 | 5 | 3.25 | 0.29 | Overall: B* Did not assess the predictability of the risk score in an independent sample *This quality grading is for Keren, 2005 - Q2 Results only
| Factors associated with the outcome in univariate analyses at the p<0.2 level of significance were considered for inclusion in multivariable logistic regression model. To translate the final logistic regression model into a clinical risk factor score, each infant was assigned points, equal to the sum of the odds ratios (ORs (multiplied by 2 and the rounded down) corresponding to risk factors present for that infant. | | Note: 15 infants were missing data on clinical risk factors and therefore could not be assigned a clinical risk factor score; - Area under the ROC curve = 0.71 (95% CI 0.66–0.76) | | | | | Overall: B* Did not assess the predictability of the risk score in an independent sample *This quality grading is for Keren, 2005 - Q2 Results only

Keren, 2005 [UI#15781937] – Q3 Results

Outcome Definition | Statistical analyses and confounders adjusted | Results
Significant hyperbilirubinemia: post-discharge TSB >95^th^ centile on Bhutani hour specific bilirubin nomogram (nearly identical to the PhotoRx threshold curve recommended for “medium risk” infants in the AAP’s 2004 clinical practice guideline | When more than one pre-discharge TSB, the TSB measurement closet to the time of hospital discharge was selected as the predictor TSB. To approximate commonly occurring newborn lengths of stay, pre-discharge TSB was reassigned to a post-discharge TSB for 213 (7.5%) infants, and a post-discharge TSB was reassigned to a pre-discharge TSB for 96 (3.4%) infants. | - Predictive properties of the pre-discharge TSB risk zone using various cut-off points for a positive test:
| | Risk zone | Test + (n) | TSB >95^th^ centile (n) | Sensitivity (95% CI) | Specificity (95% CI)
| | ≥0^th^ | 899 | 98 | 1.0 (0.96–1.00) | 0 (0–0)
| | ≥40^th^ | 727 | 97 | 0.99 (0.94–1.00) | 0.21 (0.19–0.24)
| | ≥75^th^ | 329 | 87 | 0.89 (0.81–0.94) | 0.70 (0.66–0.73)
| | ≥95^th^ | 56 | 30 | 0.31 (0.22–0.41) | 0.97 (0.95–0.98)
| | - Likelihood ratios (LR) and post-test probabilities (PTP) for specific pre-discharge TSB risk zones:
| | Pre-discharge TSB %tile | TSB >95^th^ centile (n) | TSB ≤95^th^ centile (n) | LR | PTP
| | 0–40 | 1 | 171 | 0.05 | 0.006
| | 40–75 | 10 | 388 | 0.21 | 0.03
| | 75–95 | 57 | 216 | 2.16 | 0.21
| | 95–100 | 30 | 26 | 9.43 | 0.54
| | - Area under the ROC curve = 0.83 (95% CI 0.80–0.86)

Quality items (for Keren, 2005 – Q3 Results):

Quality item | | Comments
Consecutive patients or random sampling Prospective study No verification bias Index test assessor blinded to Reference Test^A^ Index test assessor blinded to clinical Hx or other information (such as any lab values) Reference test assessor blinded to clinical Hx or other information (such as any lab values) Proper analysis of replicate measurements in different times Random order of test measurements Time delay between index and reference test measurements Adequate description of index test^B^ Adequate description of reference test^B^ | No No Yes Yes Yes Yes N/A N/A Yes Yes Yes | Only infants with both pre- and post-discharge TSBs measured were studied When more than one pre-discharge TSB, the TSB measurement closet to the time of hospital discharge was selected as the predictor TSB. To approximate commonly occurring newborn lengths of stay, pre-discharge TSB was reassigned to a post-discharge TSB for 213 (7.5%) infants, and a post-discharge TSB was reassigned to a pre-discharge TSB for 96 (3.4%) infants.
Overall Quality Grade (A to C) | B

A Or any other test in case multiple tests were evaluated

B Please make a judgment, based on the items recorded in the 1^st^ table

Matichard, 2006 UI 17178986

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria/Comorbidities/modifying factors | Phototherapy procedures | Dose (time under phototherapy) (hours) | Outcome Definition
Birth years: 1994–1995 # Enrolled: 58 # Evaluate: 58 Mean GA: nd Mean BW: nd %Male: 48% Race: white Country: France Sites: Single Funding: nd | Comparative (retrospective collection of phototherapy exposure); subjects were examined for melanocytic nevi | Group 1 (n=18): received blue light phototherapy during the first few days Control (n=40): no phototherapy Excluded children with Fitzpatrick IV through VI (rarely to never burns) | nd | “Results not shown” | Melanocytic nevus: a brown to black macule or papule; freckles and café au lait macules were excluded

Statistical analyses and adjustment for confounders | Results | Bias/limitations Comments
Univariate analysis: t test and median Wilcoxon test Multivariate analysis including phototherapy, age, skin type I or II, color of skin, eye, and hair, freckles, sun exposure during vacation, and severe sunburn | Univariate analysis:; - Mean number of nevi ≥2 mm: 3.5/child (SD 3.05) in phototherapy vs. 1.45/child (SD 1.99) in no phototherapy (P=0.02); - Mean number of nevi 2–5 mm: 3.17/child (SD2.67) in phototherapy vs. 1.23/child (SD 1.49) in no phototherapy (P=0.008); - Association between phototherapy and nevus count for nevi <2mm or >5mm was not significant; Multivariate analysis:; - An association between phototherapy and nevi sizes (2–5 mm, P<0.001; ≥ 2 mm, P=0.003) after adjusting for all other risk factors in the model | Unclear how the subjects in the phototherapy group were selected Did not control for number of melanocytic nevi in parents

Newman, 2005 [UI#15699303] – Study 1

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria | Managements of Hyperbilirubinemia (or Interventions) | Definitions of the Comparison group(s)
Birth yrs: Jan 1, 1997 to Dec 31, 1998 # Enrolled: 53,997 # Evaluate: 275 Mean GA (range): ≥36 wks Mean BW (range): ≥2000 g %Male: ND Race: ND Mean Apgar (5 min): ND Location: US Sites: Multi Funding: NIH; private | Nested case-control study | Cohort: BW ≥2000 g; GA ≥36 weeks (N=53,997) Cases: infants with a maximum TSB level ≥25 mg/dL in the first 30 days after birth (N=67) Control: randomly sampled from the cohort (N=208) | For the entire cohort (N=53,997): 14,053 (26%) with at least 1 TSB level sent Average length of hospital stay: 45.7 hours Highest recorded TSB level – ≥15 mg/dL: 5,455 (10.1%) ≥20 mg/dL: 1,098 (2.0%) ≥25 mg/dL: 68 (0.13%) Treatment with (inpatient) PhotoRx: 1,455 (2.7%) | Birth year 1995–1996 cohort, in Newman, 2000 (UI#11074857) previous described See Appendix F

Outcome Definition | Statistical analyses and confounders adjusted | Results | | Bias/limitations Comments
Hyperbilirubinemia: a TSB level ≥25 mg/dL (428 μmol/L) in the first 30 days after birth | Modified risk index for predicting hyperbilirubinemia in infants who do not have early jaundice: Modified risk index = 6 (Exclusive BF at hospital discharge) + 4 (Bruising noted) + 4 (Asian race) + 3 (Cephalohematoma noted) + 3 (Maternal age ≥ 25 y) + 1 (Male sex) − 2 (Black race) + 2 (40-GA) Note: The modified risk index is identical to the risk index used in Newman, 2000 except that the item for jaundice in a previous sibling (or family history of jaundice in a newborn) was deleted | - Comparing the original derivation cohort (1995–1996) with the validation cohort (1997–1998): | | A: strong, B: moderate, C: weak | A | B | C
Hyperbilirubinemia: a TSB level ≥25 mg/dL (428 μmol/L) in the first 30 days after birth | | Cohort | Area under the ROC curve (95% CI) | Selection | | x
Hyperbilirubinemia: a TSB level ≥25 mg/dL (428 μmol/L) in the first 30 days after birth | | 1995–1996 | 0.84 (0.79–0.89) | Study design | | x
Hyperbilirubinemia: a TSB level ≥25 mg/dL (428 μmol/L) in the first 30 days after birth | | 1997–1998 | 0.83 (0.77–0.89) | Confounder | | x
Hyperbilirubinemia: a TSB level ≥25 mg/dL (428 μmol/L) in the first 30 days after birth | | P=0.08 for the difference in areas Eliminating the family history variable had little effect on the prediction. The area under the ROC curve for the 1995–1996 cases declined from the previous reported value of 0.84 to 0.83. | | Blinding | | x
Hyperbilirubinemia: a TSB level ≥25 mg/dL (428 μmol/L) in the first 30 days after birth | | | | Data collection | | x
Hyperbilirubinemia: a TSB level ≥25 mg/dL (428 μmol/L) in the first 30 days after birth | | | | Withdraw and dropout | | x
Hyperbilirubinemia: a TSB level ≥25 mg/dL (428 μmol/L) in the first 30 days after birth | | | | Analyses | | x
Hyperbilirubinemia: a TSB level ≥25 mg/dL (428 μmol/L) in the first 30 days after birth | | | | Intervention integrity
Hyperbilirubinemia: a TSB level ≥25 mg/dL (428 μmol/L) in the first 30 days after birth | | | | Overall: B Some infants received phototherapy No cut-offs of the modified risk index was used

Newman, 2005 [UI#15699303] – Study 2

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria | Managements of Hyperbilirubinemia (or Interventions) | Definitions of the Comparison group(s)
Birth yrs: 1995–1998 # Enrolled: 5,711 # Evaluate: 5,706 Mean GA (range): ≥36 wks Mean BW (range): ≥2000 g %Male: ND Race: ND Mean Apgar (5 min): ND Location: US Sites: Multi Funding: NIH; private | Retrospective cohort | Newborns discharged before 48 hours after birth who had a TSB level measured before 48 hours (n=5711) Exclusion: TSB level ≥20 mg/dL before 48 hours (n=5) | Not described, but this is a combined 1995–1996 (in Newman, 2000 UI# 11074857, see Appendix F) and 1997–1998 birth cohorts (Newman, 2005 – Study 1) so it is assumed same managements of hyperbilirubinemia as previously described | Not applicable

Newman, 2005 [UI#15699303] – Study 2

Outcome Definition | Statistical analyses and confounders adjusted | Results | | | Bias/limitations Comments
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | Age-specific %tile was estimated using Bhutani monogram, categorizing gin to 4 %tile groups: <40th, 40th–74th, 75th–94th, and ≥95th %tile TSB levels was also transformed into age- specific z scores by assuming TSB levels up to the 95th %tile were approximately normally distributed Partial risk index was use: partial risk index = 4 (Asian race) + 3 (Cephalohematoma noted) + 3 (Maternal age ≥ 25 y) + 1 (Male sex) −2 (Black race) + 2 (40-GA) Note: The partial risk index did not include breastfeeding or bruising that was included in the modified risk index used in Newman, 2005 [UI#15699303] – Study 1 | - % Developing a TSB ≥20 mg/dL, predicted by TSB %tile groups before 48 hours: | | | A: strong, B: moderate, C: weak | A | B | C
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | TSB %tile at <48 hr | No. of infants | No. (%) of infants with a TSB of ≥20 mg/dL at age 48 hr or older | Selection | | x
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | <40^th^ | 994 | 5 (0.50) | Study design | | x
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | 40–74.9 | 1508 | 11 (0.73) | Confounder | x
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | 75–94.9 | 1780 | 58 (3.26) | Blinding | | x
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | ≥95^th^ | 1424 | 196 (13.76) | Data collection | | x
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | - Combination of the partial risk index with early TSB levels enhanced prediction: Within each TSB %tile category, 5- to 15- fold increase in risk of developing a TSB level of 20 mg/dL or higher for those with a partial risk index ≥10 compared with those with a partial risk index <4; For example: | | | Withdraw and dropout | x
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | TSB %tile at <48 hr + Partial risk index | % of infants with a TSB of ≥20 mg/dL at age ≥48 hr | | Analyses | x
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | ≥95^th^ + Partial risk index ≥10 | 36% | | Intervention integrity
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | ≥95^th^ + Partial risk index <4 | 6% | | Overall: B* * This quality grading is for risk index results only (Q2) Only infants with TSB measured before 48 hours were selected (potential selection bias) Some infants received phototherapy, and not sure the TSB measurements were taken before or after phototherapy Only partial risk index was used
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | - The risk of developing a TSB level of 20 mg/dL or higher for a 36-week newborn with an early TSB level at the 75^th^ to 94^th^ %tile was greater than that for a full-term newborn with a TSB level at the 95^th^ %tile or higher; - Area under the ROC curve for prediction of developing a TSB level of 20 mg/dL or higher at age 48 hours or older:
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | Prediction method | Area under the ROC curve (95% CI)
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | Partial risk index | 0.69 (ND)
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | TSB %tile category at <48 hr | 0.79 (0.77–0.81)
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | TSB z score | 0.83 (0.80–0.85)*
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | TSB z score + Partial risk index | 0.86 (0.84–0.88)**
Developed a TSB level of 20 mg/dL (342 μmol/L) or higher at age 48 hours or older | | *P<0.001, compared with TSB %tile category alone **P=0.001, compared with TSB z score alone

Quality items (for TSB %tile at <48 hr results only, or Q3):

Quality item | | Comments
Consecutive patients or random sampling Prospective study No verification bias Index test assessor blinded to Reference Test^A^ Index test assessor blinded to clinical Hx or other information (such as any lab values) Reference test assessor blinded to clinical Hx or other information (such as any lab values) Proper analysis of replicate measurements in different times Random order of test measurements Time delay between index and reference test measurements Adequate description of index test^B^ Adequate description of reference test^B^ | No No Yes Yes Yes Yes Unclear N/A Unclear Yes Yes | Not described Not described
Overall Quality Grade (A to C) | B

A Or any other test in case multiple tests were evaluated

B Please make a judgment, based on the items recorded in the 1^st^ table

Nuntnarumit, 2002 UI 12549790

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria/Comorbidities/modifying factors | Phototherapy procedures | Dose (time under phototherapy) (hours) | Adverse events, side effects
Birth years: 2001–2002 # Enrolled: 51 # Evaluate: 51 Mean GA: 38.8 wks Mean BW: 3104 g %Male: Race: Asian Country: Thailand Sites: Single Funding: nd | RCT of single vs. double phototherapy | Term newborns, birth weight ≥ 2500 g and GA > 37 wk, need phototherapy per AAP guideline; exclude ventilator support, on phototherapy before enrollment, direct hyperbilirubinemia | Single phototherapy: 3 daylights and 2 blue lights, 38 cm away; double phototherapy: added a lower light of 8 lamps of 20- watt daylight fluorescents, 32 cm away | Single phototherapy: 43.7±17.5 h; Double phototherapy: 34.9±12.6 h | | 1X | 2X | P
Birth years: 2001–2002 # Enrolled: 51 # Evaluate: 51 Mean GA: 38.8 wks Mean BW: 3104 g %Male: Race: Asian Country: Thailand Sites: Single Funding: nd | RCT of single vs. double phototherapy | Term newborns, birth weight ≥ 2500 g and GA > 37 wk, need phototherapy per AAP guideline; exclude ventilator support, on phototherapy before enrollment, direct hyperbilirubinemia | Single phototherapy: 3 daylights and 2 blue lights, 38 cm away; double phototherapy: added a lower light of 8 lamps of 20- watt daylight fluorescents, 32 cm away | Single phototherapy: 43.7±17.5 h; Double phototherapy: 34.9±12.6 h | wt↓ (%/d) | 1.2±0.8 | 1.7±1.3 | 0.25
Birth years: 2001–2002 # Enrolled: 51 # Evaluate: 51 Mean GA: 38.8 wks Mean BW: 3104 g %Male: Race: Asian Country: Thailand Sites: Single Funding: nd | RCT of single vs. double phototherapy | Term newborns, birth weight ≥ 2500 g and GA > 37 wk, need phototherapy per AAP guideline; exclude ventilator support, on phototherapy before enrollment, direct hyperbilirubinemia | Single phototherapy: 3 daylights and 2 blue lights, 38 cm away; double phototherapy: added a lower light of 8 lamps of 20- watt daylight fluorescents, 32 cm away | Single phototherapy: 43.7±17.5 h; Double phototherapy: 34.9±12.6 h | Stooling (times/d) | 2.2±17.5 | 2.8±1.7 | 0.10
Birth years: 2001–2002 # Enrolled: 51 # Evaluate: 51 Mean GA: 38.8 wks Mean BW: 3104 g %Male: Race: Asian Country: Thailand Sites: Single Funding: nd | RCT of single vs. double phototherapy | Term newborns, birth weight ≥ 2500 g and GA > 37 wk, need phototherapy per AAP guideline; exclude ventilator support, on phototherapy before enrollment, direct hyperbilirubinemia | Single phototherapy: 3 daylights and 2 blue lights, 38 cm away; double phototherapy: added a lower light of 8 lamps of 20- watt daylight fluorescents, 32 cm away | Single phototherapy: 43.7±17.5 h; Double phototherapy: 34.9±12.6 h | Temp >38° C | 12.5% | 7.4% | 0.65

Statistical analyses and adjustment for confounders | Bias/limitations Comments

Petersen, 2005 [UI#15738516]

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria | Managements of Hyperbilirubinemia (or Interventions) | Definitions of the Comparison group(s)
Birth yrs: Aug 2002 to March 2003 (before TcB) and May 2003 to Dec 2003 (after TcB) # Enrolled: 6603 # Analyzed: 6603 Mean GA (range): ND Mean BW (range): ND %Male: 51.3% (before TcB); 53.2% (after TcB) Race: 71.5% Hispanic, 16% Caucasian, 9.8% Afrecan- American; 2.7% Other Mean Apgar (5 min): ND Country: US Sites: Single Funding: ND | Retrospective cohorts (comparison of two historical birth cohorts) | “Normal newborn” (determined by the diagnosis-related group designation) born within the study periods. None of the newborns was treated with home PhotoRx or required exchange transfusion. | TcB testing (BiliCheck; Respironics) was formally initiated in April 2003 The decisions to measure TcB or serum bilirubin and to initiate PhotoRx were determined by the attending physician if clinically significant jaundice was suspected. The decision to start PhotoRx or obtain additional bilirubin measurements was made using the Bhutani nomogram. | Comparing newborns born after TcB introduction (May 2003 to Dec 2003) to those born before TcB used (Aug 2002 to March 2003)

Outcome Definition | Statistical analyses and confounders adjusted | Results | | | Bias/limitations Comments
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | - After initiation of TcB testing, the mean (SD) number of readmission for hyperbilirubinemia decreased from 4.5 (2.8) to 1.8 (1.7) per 1000 Births per month (P=0.044); - The mean number of serum bilirubin per newborn did not change after introduction of TcB testing (1.51 vs. 1.56 serum bili per newborn before vs. after TcB, respectively); - Both the number and proportion of newborns treated by PhotoRx in the nursery increased significantly: | | | A: strong, B: moderate, C: weak | A | B | C
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | | | | Selection | x
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | | | | Study design | | | x
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | | | | Confounder | | | x
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | | | | Blinding | | | x
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | | | | Data collection | | x
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | | | | Withdraw and dropout | x
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | | | | Analyses | | x
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | | | | Intervention integrity | | | x
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | | | | Overall: C Not sure if the same attending physician made decisions in the two study periods. No information on how the physician determined the baby had significant jaundice.
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | | Newborns treated by PhotoRx [Mean (SD)] | | Overall: C Not sure if the same attending physician made decisions in the two study periods. No information on how the physician determined the baby had significant jaundice.
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | Time frame | Number per month | % | Overall: C Not sure if the same attending physician made decisions in the two study periods. No information on how the physician determined the baby had significant jaundice.
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | Before TcB | 23.6 (5.2) | 5.9 (1.3) | Overall: C Not sure if the same attending physician made decisions in the two study periods. No information on how the physician determined the baby had significant jaundice.
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | After TcB | 32.1 (3.9) | 7.7 (1.3) | Overall: C Not sure if the same attending physician made decisions in the two study periods. No information on how the physician determined the baby had significant jaundice.
Number readmission for hyperbilirubinemia Number of serum bilirubin testing Number of newborns received PhotoRx | Wilcoxon rank-sum two sample test | P value | 0.0089 | 0.014 | Overall: C Not sure if the same attending physician made decisions in the two study periods. No information on how the physician determined the baby had significant jaundice.

Sanpavat, 2005 [UI#16536103]

Study characteristics | Inclusion/Exclusion Criteria | Population description | Test Protocol | Reference Standard | Definition of Positives
Birth yrs: Nov. 2003 to May 2004 # Enrolled: 392 # Analyzed: 392 Mean GA (range): 38.6 wks Mean BW (range): ≥2500 g %Male: 52% Race: nd Mean Apgar (5 min): nd Country: Bangkok Sites: Single Design: Unclear Funding: University | Inclusion: Infants born by C-section whose birth weight was ≥2500 g and GA ≥37 weeks Exclusion: Sick newborns, congenital anomaly, infants of diabetic mothers, infants who had asphyxia, hypothermia, hypoglycemia, polycythemia, concealed hemorrhage, and infants who were discharged before 72 hours of age | Setting: Healthy term infants born by C-section Patient selection process:^A^ Consecutive | Device: Bilicheck (SpecRx, Inc, Norcross, GA, USA) Tested sites: forehead Timing vs Reference Test: nd Time of measurements: Every 24 hours until 3–4 days after birth or until jaundice, determined by TSB, was severe enough to require PhotoRx, whichever condition came first Number of measurements: 5 | Device: nd Tested sites: blood Time of measurements: “jaundice” Number of measurements:^B^ 1 | Definition of positive Reference Test: TSB levels indicate the need for PhotoRx:
| | Setting: Healthy term infants born by C-section Patient selection process:^A^ Consecutive | | Device: nd Tested sites: blood Time of measurements: “jaundice” Number of measurements:^B^ 1 | Age (hr) | PhotoRx | Double PhotoRx
| | Setting: Healthy term infants born by C-section Patient selection process:^A^ Consecutive | | Device: nd Tested sites: blood Time of measurements: “jaundice” Number of measurements:^B^ 1 | ≤24*
| | Setting: Healthy term infants born by C-section Patient selection process:^A^ Consecutive | | Device: nd Tested sites: blood Time of measurements: “jaundice” Number of measurements:^B^ 1 | 25–48 | 10–12 | ≥15
| | Setting: Healthy term infants born by C-section Patient selection process:^A^ Consecutive | | Device: nd Tested sites: blood Time of measurements: “jaundice” Number of measurements:^B^ 1 | 49–72 | ≥13 | ≥16
| | Setting: Healthy term infants born by C-section Patient selection process:^A^ Consecutive | | Device: nd Tested sites: blood Time of measurements: “jaundice” Number of measurements:^B^ 1 | >72 | ≥15 | ≥17
| | Setting: Healthy term infants born by C-section Patient selection process:^A^ Consecutive | | Device: nd Tested sites: blood Time of measurements: “jaundice” Number of measurements:^B^ 1 | *abnormal: investigation, phototherapy and repeat TSB within 4–6 hr Definition of positive Index Test: TcB hour-specific percentile monogram, developed from TcB of 284 normal infants in this study (without ABO incompatibility, G6PD deficiency, requirement of PhotoRx) >10, >25, >50, >75, >85, >90, >95 %tile

A consecutive/random sampling from general population/prescreening based on selection criteria (describe)

B Implies times the probe was applied on the baby – not how many readings the machine takes each time

Results (Concordance metrics): No data

Study | Comparison | Metric | Results | Comments

Results (Sensitivity, specificity and ROC analysis):

Study | Comparison | Index cutoff | Reference Cutoff | TP | FN | FP | TN | Sens | Spec | AUC- ROC | Comments
Sanpavat 2005 | TcB %tile vs. TSB | >95 %tile | Sever hyperbilirubinemia that required PhotoRx | | | | | 75 | 89.4 | | 32/392 (8.2%) had significant hyperbilirubinemia required PhotoRx
Sanpavat 2005 | TcB %tile vs. TSB | >90 %tile | Sever hyperbilirubinemia that required PhotoRx | | | | | 96.9 | 78.8 | | 32/392 (8.2%) had significant hyperbilirubinemia required PhotoRx
Sanpavat 2005 | TcB %tile vs. TSB | >85 %tile | Sever hyperbilirubinemia that required PhotoRx | | | | | 100 | 57.2 | | 32/392 (8.2%) had significant hyperbilirubinemia required PhotoRx
Sanpavat 2005 | TcB %tile vs. TSB | >75 %tile | Sever hyperbilirubinemia that required PhotoRx | | | | | 100 | 48.3 | | 32/392 (8.2%) had significant hyperbilirubinemia required PhotoRx
Sanpavat 2005 | TcB %tile vs. TSB | >50 %tile | Sever hyperbilirubinemia that required PhotoRx | | | | | 100 | 24.4 | | 32/392 (8.2%) had significant hyperbilirubinemia required PhotoRx
Sanpavat 2005 | TcB %tile vs. TSB | >25 %tile | Sever hyperbilirubinemia that required PhotoRx | | | | | 100 | 5.0 | | 32/392 (8.2%) had significant hyperbilirubinemia required PhotoRx
Sanpavat 2005 | TcB %tile vs. TSB | >10 %tile | Sever hyperbilirubinemia that required PhotoRx | | | | | 100 | 5.0 | | 32/392 (8.2%) had significant hyperbilirubinemia required PhotoRx

Other results:

Cases of hyperbilirubinemia were ABO incompatibility (n=51), G6PD (n=34), Combined ABO incompatibility and G6PD (n=3)

Quality items:

Quality item | | Comments
Consecutive patients or random sampling Prospective study No verification bias Index test assessor blinded to Reference Test^A^ Index test assessor blinded to clinical Hx or other information (such as any lab values) Reference test assessor blinded to clinical Hx or other information (such as any lab values) Proper analysis of replicate measurements in different times Random order of test measurements Time delay between index and reference test measurements Adequate description of index test^B^ Adequate description of reference test^B^ | Y Unclear N Y Y Y Unclear N/A Unclear Y N | Only 154 infants (39%) had TSB measured; PhotoRx was determined by TSB levels only
Overall Quality Grade (A to C) | C

A Or any other test in case multiple tests were evaluated

B Please make a judgment, based on the items recorded in the 1^st^ table

Sarici, 2001 UI 11765155

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria/Comorbidities/modifying factors | Phototherapy procedures | Dose (time under phototherapy) (hours) | | Adverse events, side effects reported
Birth years: nd # Enrolled: 109 # Evaluate: 100 Mean GA: 39 wks Mean BW: 3380 g %Male: 54% Race: Country: Turkey Sites: Single Funding | RCT: fiberoptic (n=50) vs. conventional phototherapy (n=50); followup for 24 h post phototherapy | Healthy term newborn ≥2500 g with non- hemolytic jaundice; formula feeding during phototherapy | Phototherapy initiated when TSB ≥ 15 mg/dL; Fiberoptic group placed on fiberoptic pad; conventional group placed under standard unit (5 daylight fluorescent lamps) Prone position in both groups with eye patches only in the conventional group | Conventional | 49.4 ± 14.4 | 1 in each group had transient erythema; 3 in each group had mild watery stool; no other complications noted
Birth years: nd # Enrolled: 109 # Evaluate: 100 Mean GA: 39 wks Mean BW: 3380 g %Male: 54% Race: Country: Turkey Sites: Single Funding | RCT: fiberoptic (n=50) vs. conventional phototherapy (n=50); followup for 24 h post phototherapy | Healthy term newborn ≥2500 g with non- hemolytic jaundice; formula feeding during phototherapy | | Fiberoptic | 61 ± 13.1 | 1 in each group had transient erythema; 3 in each group had mild watery stool; no other complications noted

Statistical analyses and adjustment for confounders | Bias/limitations Comments

Sarici, 2004 [UI#15060227]

Study characteristics | Inclusion/Exclusion Criteria | Population description | Test Protocol | Reference Standard | Definition of Positives
Birth yrs: Nov. 2001 to May 2002 # Enrolled: 366 # Analyzed: (146 near-term- see below) Mean GA (range): Term – 39.7(38–42) wks Near-term – 36.6 (35–37) wks Mean BW (range): Term – 3194 g Near-term – 2777 g %Male:Term – 52% Near-term – 53% Race: ND Mean Apgar (5 min): Term – 9.6 Near-term – 9.4 Country: Turkey Sites: Single Design: Prospective Funding: ND | Inclusion: All newborns with a GA 35–42 completed weeks were consecutively enrolled **Note: data on predictive values only reported for near-term (35–37 weeks) infants only (N=146) Exclusion: Preterm infants, GA <35 weeks; postterm infants, GA >42 weeks SGA or LGA, determined on the basis of Colorado intrauterine growth charts Multiple gestation, any congenital malformation, respiratory distress, G6PD, clinical or culture-proven sepsis, and inability to initiate or maintain oral feeding within 3 hours after birth due to various reasons Evidence of hemolysis, ABO incompatibility with a first-day (6^th^-hour) serum bilirubin level of ≥6 mg/dL | Setting: All newborns GA 35–42 Patient selection process:^A^ Consecutive | Device: Colorimetic method (diazotized sulfanilic acid reaction, Germany) Tested sites: Serum Timing vs Reference Test: 24 hours Time of measurements: 6^th^ hour of life, before discharge Number of measurements: 1 | Device: Same as test protocol Tested sites: Serum Time of measurements: Daily for 4 days; and the last measurement was performed on the7^th^ day (150^th^ hour) of life Number of measurements:^B^ 1 | Definition of positive Reference Test: Any of the first week’s serum bilirubin measurements in the ≥95^th^ %tile of the monogram Definition of positive Index Test: Percentile cutoffs on the monogram for the 6^th^ hour or 30^th^ hour of serum bilirubin measurement: 5^th^, 30^th^, 60^th^; 95^th^%tiles

A consecutive/random sampling from general population/prescreening based on selection criteria (describe)

B Implies times the probe was applied on the baby – not how many readings the machine takes each time

Results (Concordance metrics): No data

Study | Comparison | Metric | Results | Comments

Results (Sensitivity, specificity and ROC analysis):

Study | Comparison | Index cutoff | Reference Cutoff | TP | FN | FP | TN | Sens | Spec | AUC-ROC | Comments
Sarici, 2004 | For near-term infants (35–37 wks) only: 6^th^ hour serum bilirubin %tile vs. first week (day 1 to7) daily serum biliruin %tile | 95^th^ %tile | ≥95^th^ %tile in any of the first week’s serum bilirubin | 6 | 31 | 2 | 107 | 16.2 | 98.2 | ND | Unclear why only near-term infants were analyzed here No data for term infants
Sarici, 2004 | For near-term infants (35–37 wks) only: 6^th^ hour serum bilirubin %tile vs. first week (day 1 to7) daily serum biliruin %tile | 60^th^ %tile | ≥95^th^ %tile in any of the first week’s serum bilirubin | 27 | 10 | 32 | 77 | 72.9 | 70.6 | ND | Unclear why only near-term infants were analyzed here No data for term infants
Sarici, 2004 | For near-term infants (35–37 wks) only: 6^th^ hour serum bilirubin %tile vs. first week (day 1 to7) daily serum biliruin %tile | 30^th^ %tile | ≥95^th^ %tile in any of the first week’s serum bilirubin | 33 | 4 | 70 | 39 | 89.1 | 35.7 | ND | Unclear why only near-term infants were analyzed here No data for term infants
Sarici, 2004 | For near-term infants (35–37 wks) only: 6^th^ hour serum bilirubin %tile vs. first week (day 1 to7) daily serum biliruin %tile | 5^th^ %tile | ≥95^th^ %tile in any of the first week’s serum bilirubin | 37 | 0 | 102 | 7 | 100 | 6.4 | ND | Unclear why only near-term infants were analyzed here No data for term infants
Sarici, 2004 | For near-term infants (35–37 wks) only: 30^th^ hour serum bilirubin %tile vs. first week (day 1 to7) daily serum biliruin %tile | 95^th^ %tile | ≥95^th^ %tile in any of the first week’s serum bilirubin | 13 | 24 | 2 | 107 | 35.1 | 98.2 | ND | Unclear why only near-term infants were analyzed here No data for term infants
Sarici, 2004 | For near-term infants (35–37 wks) only: 30^th^ hour serum bilirubin %tile vs. first week (day 1 to7) daily serum biliruin %tile | 60^th^ %tile | ≥95^th^ %tile in any of the first week’s serum bilirubin | 28 | 9 | 31 | 78 | 75.7 | 71.6 | ND | Unclear why only near-term infants were analyzed here No data for term infants
Sarici, 2004 | For near-term infants (35–37 wks) only: 30^th^ hour serum bilirubin %tile vs. first week (day 1 to7) daily serum biliruin %tile | 30^th^ %tile | ≥95^th^ %tile in any of the first week’s serum bilirubin | 34 | 3 | 69 | 40 | 91.9 | 36.7 | ND | Unclear why only near-term infants were analyzed here No data for term infants
Sarici, 2004 | For near-term infants (35–37 wks) only: 30^th^ hour serum bilirubin %tile vs. first week (day 1 to7) daily serum biliruin %tile | 5^th^ %tile | ≥95^th^ %tile in any of the first week’s serum bilirubin | 37 | 0 | 102 | 7 | 100 | 6.4 | ND | Unclear why only near-term infants were analyzed here No data for term infants

Other results:

Daily mean serum bilirubin levels of the term and pre-term babies did not differ significantly in the first 4 days. The mean serum bilirubin levels on the 5^th^ and 7^th^ days of life were significantly higher in the near-term babies than in the term babies (p=0.04 and P<0.01, respectively). However, serum bilirubin values of the newborns in the near-term group demonstrated a gradual increase during the first days of life and tended to persist high through the end of the first week.

In this study, near-term infants (35–37 wks) were 2.4 times more likely to develop significant hyperbilirubinemia (≥95^th^ %tile of the nomogram) than term infant (38–42 wks): 37/149 (24.8%) vs. 23/219 (10.5%)

Quality items:

Quality item | | Comments
Consecutive patients or random sampling Prospective study No verification bias Index test assessor blinded to Reference Test^A^ Index test assessor blinded to clinical Hx or other information (such as any lab values) Reference test assessor blinded to clinical Hx or other information (such as any lab values) Proper analysis of replicate measurements in different times Random order of test measurements Time delay between index and reference test measurements Adequate description of index test^B^ Adequate description of reference test^B^ | Yes Yes Yes Yes Yes Yes N/A N/A N/A Yes Yes | BUT: Data on term infants are not presented for predictive abilities.
Overall Quality Grade (A to C) | B | They do not present data on term infants on predictive ability. 12.5% lost-to follow-up; their characteristics were not described

A Or any other test in case multiple tests were evaluated

B Please make a judgment, based on the items recorded in the 1^st^ table

Sarin, 2006 UI 16891677

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria/Comorbidities/modifying factors | Phototherapy procedures | Dose (time under phototherapy) (hours) | Adverse events, side effects
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | RCT of compact fluorescent lamp vs. standard phototherapy; data on infants not extracted because data on preterm and term could not be segregated; data on effects on staff were extracted; 50/64 nurses in the neonatal unit answered a questionnaire: Does the light cause a) a glare and hurt the eyes? B) giddiness C) a headache? Answers were: no, minimal, moderate, or extreme | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | Effect of compact fluorescent on staff
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | | no | minimal | Moderate or extreme
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | Eyes hurt | nd | nd | 38%
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | Giddiness | nd | nd | 14%
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | Headache | nd | nd | 6%
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | Effect of standard fluorescent on staff
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | | no | minimal | Moderate or extreme
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | Eyes hurt | nd | nd | 38%
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | Giddiness | nd | nd | 14%
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | Headache | nd | nd | 6%
Birth years: nd # Enrolled: 100 # Evaluate: 100 Mean GA: Preterm and Term Mean BW: g %Male: Race: Country: India Sites: Single Funding: nd | | | Compact fluorescent (Phoenix India Ltd) (4 compact special blue and 2 compact white tubes) vs. standard (4 special blue tube and 2 white tubes); maintain irradiance >15 μW/cm2/nm at all times | Mean irradiance: 18.39±2.38 (compact) vs. 17.77±1.81(standard) μW/cm2/nm; phototherapy from start to end: 40.66±23.94 (compact) vs 40.78±21.83 (standard) h. | Difference between groups: NS

Statistical analyses and adjustment for confounders | Bias/limitations Comments

Seidman, 2003 UI 12673261

Study characteristics | Study design and followup duration | Inclusion/Exclusion Criteria/Co-morbidities/modifying factors | Phototherapy procedures | | Dose (time under Phototherapy) (hours) | | Adverse events, side effects reported
Birth years: 1998–1999 # Enrolled: 114 # Evaluate: 114 Mean GA: 39.4±1.7 Mean BW: nd %Male: nd Race: Country: Israel Sites: Multi Funding: government/university | Open randomized study: Conventional phototherapy (n=57); LED blue (n=25); LED blue-green (n=22) No postdischarge followup noted | Jaundiced but otherwise healthy term infants; breastfeeding | Open crib, unclothed except for a diaper, eyes covered; Bilirubin (mg/dL) at start of phototherapy: | | Conventional | 35.4 (29.8–41.0) | No side effects (e.g., erythema) were noted. Nurses did not complain of nausea or dizziness under the blue LED light. “Parents/nurses noted blue-green lights gave a more disturbing hue to the newborn’s skin than the blue or halogen-quartz lamps.”
Birth years: 1998–1999 # Enrolled: 114 # Evaluate: 114 Mean GA: 39.4±1.7 Mean BW: nd %Male: nd Race: Country: Israel Sites: Multi Funding: government/university | Open randomized study: Conventional phototherapy (n=57); LED blue (n=25); LED blue-green (n=22) No postdischarge followup noted | Jaundiced but otherwise healthy term infants; breastfeeding | Conventional | 15.1 (14.0–16.2) | LED blue | 31.6 (23.1–40.0)
Birth years: 1998–1999 # Enrolled: 114 # Evaluate: 114 Mean GA: 39.4±1.7 Mean BW: nd %Male: nd Race: Country: Israel Sites: Multi Funding: government/university | Open randomized study: Conventional phototherapy (n=57); LED blue (n=25); LED blue-green (n=22) No postdischarge followup noted | Jaundiced but otherwise healthy term infants; breastfeeding | LED blue | 14.3 (12.6–16.0) | LED blue-green | 39.2 (30.0–48.4)
Birth years: 1998–1999 # Enrolled: 114 # Evaluate: 114 Mean GA: 39.4±1.7 Mean BW: nd %Male: nd Race: Country: Israel Sites: Multi Funding: government/university | Open randomized study: Conventional phototherapy (n=57); LED blue (n=25); LED blue-green (n=22) No postdischarge followup noted | Jaundiced but otherwise healthy term infants; breastfeeding | LED blue-green | 14.2 (12.3–16.1)

Statistical analyses and confounders adjusted | Bias/limitations Comments

Turan, 2004 UI 15346824

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria/Comorbidities/modifying factors | Phototherapy procedures | Dose (time under phototherapy) (hours) | Adverse events, side effects
Birth years: 2000–2001 # Enrolled: 61 # Evaluate: 61 Mean GA: 38.6 wks Mean BW:3356 g %Male: nd Race: nd Country: Turkey Sites: Single Funding: University and industry | RCT of phototherapy 15 cm away (15–18 μW/cm2/nm) (n=29) vs. 30–45 cm away (10–12 μW/cm2/nm) (n=32); primary aim of the study was to compare NO and vascular endothelial growth factor levels (data not extracted here) | ≥ 37 wk GA | Phototherapy initiated per AAP guidelines: phototherapy15 cm away vs. phototherapy30–45 cm away; eyes covered, diaper | nd | | 15 cm | 30–45 cm
Birth years: 2000–2001 # Enrolled: 61 # Evaluate: 61 Mean GA: 38.6 wks Mean BW:3356 g %Male: nd Race: nd Country: Turkey Sites: Single Funding: University and industry | | ≥ 37 wk GA | Phototherapy initiated per AAP guidelines: phototherapy15 cm away vs. phototherapy30–45 cm away; eyes covered, diaper | nd | Baseline temperature | 36.43±0.21 | 36.49±0.34
Birth years: 2000–2001 # Enrolled: 61 # Evaluate: 61 Mean GA: 38.6 wks Mean BW:3356 g %Male: nd Race: nd Country: Turkey Sites: Single Funding: University and industry | | ≥ 37 wk GA | Phototherapy initiated per AAP guidelines: phototherapy15 cm away vs. phototherapy30–45 cm away; eyes covered, diaper | nd | Temperature at 6^th^ h phototherapy | 36.70±0.25* | 36.82±0.26*
Birth years: 2000–2001 # Enrolled: 61 # Evaluate: 61 Mean GA: 38.6 wks Mean BW:3356 g %Male: nd Race: nd Country: Turkey Sites: Single Funding: University and industry | | ≥ 37 wk GA | Phototherapy initiated per AAP guidelines: phototherapy15 cm away vs. phototherapy30–45 cm away; eyes covered, diaper | nd | Baseline heart rate | 140.96±13.28 | 142.06±12.21
Birth years: 2000–2001 # Enrolled: 61 # Evaluate: 61 Mean GA: 38.6 wks Mean BW:3356 g %Male: nd Race: nd Country: Turkey Sites: Single Funding: University and industry | | ≥ 37 wk GA | Phototherapy initiated per AAP guidelines: phototherapy15 cm away vs. phototherapy30–45 cm away; eyes covered, diaper | nd | Heart rate at6^th^ h phototherapy | 146.75±8.14* | 144.62±9.60
Birth years: 2000–2001 # Enrolled: 61 # Evaluate: 61 Mean GA: 38.6 wks Mean BW:3356 g %Male: nd Race: nd Country: Turkey Sites: Single Funding: University and industry | | ≥ 37 wk GA | Phototherapy initiated per AAP guidelines: phototherapy15 cm away vs. phototherapy30–45 cm away; eyes covered, diaper | nd | Baseline mean blood pressure | 61.03±11.29 | 60.12±7.61
Birth years: 2000–2001 # Enrolled: 61 # Evaluate: 61 Mean GA: 38.6 wks Mean BW:3356 g %Male: nd Race: nd Country: Turkey Sites: Single Funding: University and industry | | ≥ 37 wk GA | Phototherapy initiated per AAP guidelines: phototherapy15 cm away vs. phototherapy30–45 cm away; eyes covered, diaper | nd | Mean blood pressure at6^th^ h phototherapy | 57.65±8.46 | 55.50±8.07*
Birth years: 2000–2001 # Enrolled: 61 # Evaluate: 61 Mean GA: 38.6 wks Mean BW:3356 g %Male: nd Race: nd Country: Turkey Sites: Single Funding: University and industry | | ≥ 37 wk GA | Phototherapy initiated per AAP guidelines: phototherapy15 cm away vs. phototherapy30–45 cm away; eyes covered, diaper | nd | *P comparing baseline with 6^th^ h: <0.05; All other comparisons: NS

Statistical analyses and adjustment for confounders | Bias/limitations Comments

Zainab, 2004 UI 15727387

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria/Comorbidities/modifying factors | Phototherapy procedures | Dose (time under phototherapy) (hours) | Adverse events, side effects
Birth years: 2002 # Enrolled: 36 # Evaluate: 36 Mean GA: Term Mean BW: 3040 g %Male: Race: 95% Malays, 5% Chinese Country: Malaysia Sites: Single Funding: | Comparative study of home (n=18) vs. hospital (n=18) phototherapy | >37 wk GA; birth weight 2500–4000 g, Apgar5 ≥7, >2 d but <7 d at start of phototherapy, TSB >10.5 but <18.4 mg/dL; no G6PD or hemolysis | Home: Bluelite mobile unit with reflectors on both sides of the neonate, distance30 cm, irradiance ≥ 15.5 μW/cm2/nm; Hospital: self-made unit with top (50 cm, 14–16 μW/cm2/nm ) and bottom (30 cm, 18–19 μW/cm2/nm) lights; Phototherapy per AAP guideline (1985) with modification, phototherapy stopped when TSB <11.7 mg/dL | Home: 1.17±0.73 d; Hospital: 1.72±0.73 d Mean TSB at start of phototherapy: 13.9 mg/dL | | home | hospital
Birth years: 2002 # Enrolled: 36 # Evaluate: 36 Mean GA: Term Mean BW: 3040 g %Male: Race: 95% Malays, 5% Chinese Country: Malaysia Sites: Single Funding: | Comparative study of home (n=18) vs. hospital (n=18) phototherapy | >37 wk GA; birth weight 2500–4000 g, Apgar5 ≥7, >2 d but <7 d at start of phototherapy, TSB >10.5 but <18.4 mg/dL; no G6PD or hemolysis | | Home: 1.17±0.73 d; Hospital: 1.72±0.73 d Mean TSB at start of phototherapy: 13.9 mg/dL | No complications | 78% | 78%
Birth years: 2002 # Enrolled: 36 # Evaluate: 36 Mean GA: Term Mean BW: 3040 g %Male: Race: 95% Malays, 5% Chinese Country: Malaysia Sites: Single Funding: | Comparative study of home (n=18) vs. hospital (n=18) phototherapy | >37 wk GA; birth weight 2500–4000 g, Apgar5 ≥7, >2 d but <7 d at start of phototherapy, TSB >10.5 but <18.4 mg/dL; no G6PD or hemolysis | | Home: 1.17±0.73 d; Hospital: 1.72±0.73 d Mean TSB at start of phototherapy: 13.9 mg/dL | rash | 5.5% | 11%
Birth years: 2002 # Enrolled: 36 # Evaluate: 36 Mean GA: Term Mean BW: 3040 g %Male: Race: 95% Malays, 5% Chinese Country: Malaysia Sites: Single Funding: | Comparative study of home (n=18) vs. hospital (n=18) phototherapy | >37 wk GA; birth weight 2500–4000 g, Apgar5 ≥7, >2 d but <7 d at start of phototherapy, TSB >10.5 but <18.4 mg/dL; no G6PD or hemolysis | | Home: 1.17±0.73 d; Hospital: 1.72±0.73 d Mean TSB at start of phototherapy: 13.9 mg/dL | hyperthermia | 0 | 0
Birth years: 2002 # Enrolled: 36 # Evaluate: 36 Mean GA: Term Mean BW: 3040 g %Male: Race: 95% Malays, 5% Chinese Country: Malaysia Sites: Single Funding: | Comparative study of home (n=18) vs. hospital (n=18) phototherapy | >37 wk GA; birth weight 2500–4000 g, Apgar5 ≥7, >2 d but <7 d at start of phototherapy, TSB >10.5 but <18.4 mg/dL; no G6PD or hemolysis | | Home: 1.17±0.73 d; Hospital: 1.72±0.73 d Mean TSB at start of phototherapy: 13.9 mg/dL | Diarrhea >5x | 16.7% | 11%
Birth years: 2002 # Enrolled: 36 # Evaluate: 36 Mean GA: Term Mean BW: 3040 g %Male: Race: 95% Malays, 5% Chinese Country: Malaysia Sites: Single Funding: | Comparative study of home (n=18) vs. hospital (n=18) phototherapy | >37 wk GA; birth weight 2500–4000 g, Apgar5 ≥7, >2 d but <7 d at start of phototherapy, TSB >10.5 but <18.4 mg/dL; no G6PD or hemolysis | | Home: 1.17±0.73 d; Hospital: 1.72±0.73 d Mean TSB at start of phototherapy: 13.9 mg/dL | Differences between groups: NS

Statistical analyses and adjustment for confounders | Bias/limitations Comments