# Data Abstraction Form

Evidence Table Template, General

Author, year [UI#]

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria | Managements of Hyperbilirubinemia (or Interventions) | Definitions of the Comparison group(s)
Birth years: # Enrolled: # Evaluated: Mean GA (range): wks Mean BW (range): g % Male: Race: Mean Apgar (5 min): Country: Sites: Single/Multi Funding:

Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
| | | A: strong, B: moderate, C: weak | A | B | C
| | | Selection
| | | Study design
| | | Confounder
| | | Blinding
| | | Data collection
| | | Withdraw and dropout
| | | Analyses
| | | Intervention integrity

Evidence Table Template, Key Question 3

Author, year [UI#]

Study characteristics | Inclusion/Exclusion Criteria | Population description | Test Protocol | Reference Standard | Definition of Positives
Birth years: # Enrolled: # Analyzed: Mean GA (range): wks Mean BW (range): g % Male: Race: Mean Apgar (5 min): Country: Sites: Single/Multi Design: Prospective/Retrospective Funding: | Inclusion: Exclusion: | Setting: Patient selection process: A | Device: Tested sites: Timing vs Reference Test: Time of measurements: Number of measurements: | Device: Tested sites: Time of measurements: Number of measurements: B | Definition of positive Reference Test: Definition of positive Index Test:

A consecutive/random sampling from general population/prescreening based on selection criteria (describe)

B Implies times the probe was applied on the baby – not how many readings the machine takes each time

Results (Concordance metrics)

Study | Comparison | Metric | Results | Comments

Results (Sensitivity, specificity, and ROC analysis)

Study | Comparison | Index cutoff | Reference Cutoff | TP | FN | FP | TN | Sens | Spec | AUC-ROC | Comments

Other results:

Quality Items

Quality item | | Comments
Consecutive patients or random sampling Prospective study No verification bias Index test assessor blinded to Reference Test^A^ Index test assessor blinded to clinical Hx or other information (such as any lab values) Reference test assessor blinded to clinical Hx or other information (such as any lab values) Proper analysis of replicate measurements in different times Random order of test measurements Time delay between index and reference test measurements Adequate description of index test^B^ Adequate description of reference test^B^
Overall Quality Grade (A to C)

A Or any other test in case multiple tests were evaluated

B Please make a judgment, based on the items recorded in the 1^st^ table

Evidence Table Template, Key Question 6

Author, year [UI#]

Study characteristics | Study design and follow-up duration | Inclusion/Exclusion Criteria/Comorbidities/modifying factors | Phototherapy procedures | Dose (time under phototherapy) (hours) | Adverse events, side effects
Birth years: # Enrolled: # Evaluated: Mean GA: wks Mean BW: g % Male: Race: Country: Sites:Single/Multi Funding:

Statistical analyses and adjustment for confounders | Bias/limitations Comments