# AMEDLINE® Search Strategy

Human and Animal Search 1996 to August Week 1 2007

1 | exp Hyperbilirubinemia/(3156)
2 | exp Hyperbilirubinemia, Hereditary/(463)
3 | exp Bilirubin/(3958)
4 | exp Jaundice, Neonatal/(936)
5 | exp Kernicterus/(213)
6 | (bilirubin or hyperbilirubin$).tw. (8617)
7 | kernicterus.tw. (225)
8 | jaundice.tw. (6056)
9 | exp Hyperbilirubinemia, Neonatal/(1023)
10 | neonat$.tw. (60251)
11 | 1 or 2 or 3 or 6 or 7 or 8 (15348)
12 | limit 11 to newborn infant <birth to 1 month> (2104)
13 | (6 or 8) and 10 (1411)
14 | 4 or 5 or 9 or 12 or 13 (2473)
15 | limit 14 to human (2402)
16 | limit 15 to english language (2105)
17 | “20010925”.em. (0)
18 | “20010926”.em. (0)
19 | “20010927”.em. (10624)
20 | “20010928”.em. (0)
21 | “20010929”.em. (0)
22 | “20010930”.em. (0)
23 | 20011$.em. (120344)
24 | 2002$.em. (507152)
25 | 2003$.em. (531876)
26 | 2004$.em. (584306)
27 | 2005$.em. (595731)
28 | 2006$.em. (633204)
29 | 2007$.em. (407921)
30 | or/17–29 (3391158)
31 | 16 and 30 (1251)
32 | limit 31 to (guideline or meta analysis or practice guideline or “review”) (194)
33 | 31 not 32 (1057)
34 | limit 33 to (addresses or bibliography or biography or case reports or comment or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or periodical index) (322)
35 | 33 not 34 (735)
36 | limit 35 to yr=”2007” (46)
37 | from 36 keep 1–46 (46)