# Appendix C. Evidence Tables

Evidence Table C1. Randomized Trials Of Vision Screening In Older Adults

Study, Year, Title | Screening intervention | Purpose of study | Study design | Setting | Inclusion criteria | Exclusion criteria | Number of treatment & control subjects (number approached, number eligible, number enrolled) | Subject age, gender, diagnosis | Country & setting | Sponsor | Measures | Interventions or exposures | Results | Duration of follow-up | Loss to follow-up | Compliance to treatment | Adverse events & withdrawals due to AE's | Quality score
Cumming et al, 2007 ^69^ Improving vision to prevent falls in frail older people | Visual acuity was measured using the Early Treatment Diabetic Retinopathy Study Chart at 2.4 m-test distance Contrast sensitivity was measured using the CSV-1000E Chart 1 at 2.4m-test distance Visual fields were measured using a Humphrey automated visual field unit with a frequency doubling technology visual field instrument Intraocular pressure was assessed using a Perkins applanation tonometer An eye exam was performed using slit lamp biomicroscopy and direct opthalmoscopy | To determine the efficacy of vision and eye exams with subsequent treatment of vision problems, for preventing falls and fractures | Randomized controlled trial | Community based - patients received in-home care and/or at study clinic | Age >70 years; living independently in the community; no cataract surgery or new eyeglasses prescription in the 3 months preceding study entry; if cognitively impaired, a caregiver was needed to complete the monthly falls calendar | NR | NR/NR/616 enrolled | Mean age 80.6 years 68% female Mean baseline visual acuity (intervention group only) 20/30 | Australia Study clinic and/or homes | National Health and Medical Research Council of Australia | Primary outcome: incidence of falls over 12 months of follow-up | A: Vision tests and eye exams, including treatment (e.g. glasses) and/or referrals to other health care providers B: Standard care (no vision testing or eye exams) | Primary outcome: Falls, treated vs. untreated group Rate ratio 1.57 (95% CI 1.20 to 2.05; p=0.001) Other outcomes: patients requiring treatment (intervention group only) new glasses - 92/309 (29.8%) referral to ophthalmologist - 64*/309 (20.7%) refused new glasses/referral - 11/309 (3.6%) *Some persons were referred for more than 1 type of treatment | 12 months | 84/616 (14%) | 146/309 in control group needed treatment or referral (11 declined treatment or referral) All receiving new eyeglasses complied (n=92) Followed through with referrals (n=64*) 7/15 persons that were referred for cataract surgery had surgery by the end of the follow up period *Some persons were referred for more than 1 type of treatment | NR | Fair
Eekhof et al, 2000 ^66^ Effects of screening for disorders among the elderly: an intervention study in general practice | Assessment of difficulty in recognizing a face at 4 meters and/or reading normal letters in a newspaper, and/or impaired vision with both by Snellen eye chart or not being able to read normal newspaper letters at 25 cm distance | Compare initial screening for four disorders versus no screening in persons 75 years or older | Cluster randomized controlled trial | Primary care clinic | 75 years or older | Too ill, suffering from dementia, or not able to participate for other reasons | 12 general practices enrolled 1470 patients screened 1368 eligible Number randomized unclear, 1121 evaluated (576 in initial screening, 545 no initial screening) | Mean age: 81 years Female: 64% vs. 68% Non-white: Not reported | The Netherlands General practice clinics | NR | Visual disorders, defined as having difficulty in recognizing a face at 4 m, and/or reading normal letters in a newspaper, and/or impaired vision with both eyes (Snellen <0.3), or not being able to read normal newspaper letters at 25 cm | A: Screening in first and second year for hearing disorder, visual disorder, urinary incontinence, and mobility disorder B: No screening in first year, screening in second year | Immediate versus delayed vision screening Visual disorder in 2nd year: 51% vs. 47% (p=0.68) | 1 year | 16% (93/576) patients who underwent immediate screening did not participate in second year; otherwise unclear | 36/59 persons referred to ENT or ophthalmologist followed through with referral | NR | Fair
Moore et al, 1997 ^67^ A randomized trial of office-based screening for common problems in older persons | Vision screening: Question to assess difficulty performing everyday activities, followed by Snellen eye chart if positive | Compare a structured screening intervention to usual care in persons 70 years or older | Cluster randomized controlled trial | Primary care clinic | 70 years or older, English speaking, not acutely or terminally ill, and able to answer questions | NR | 26 internal medicine and family practice groups enrolled 316 patients screened 309 eligible 261 enrolled (112 to screening and 149 to usual care) | Mean age: 77 vs. 76 years Female: 65% vs. 59% Non-white: 21% vs. 19% | US Primary care clinics | Robert Wood Johnson Clinical Scholars Program and the National Institute on Aging Geriatric Academic Program | Self-reporting improvement in vision | A: Screening based on structured screening form (for vision a screening question followed by Snellen eye chart if positive response) B: Usual care | Vision screening versus usual care Improvement in vision at 6 months: 20% (20/99) vs. 24% (31/131), p=0.45 | 6 months | 12% (31/261) at 6 months | NR | NR | Fair
Smeeth et al, 2003 ^68^ Screening older people for impaired vision in primary care: cluster randomized trial | Detailed health assessment by a trained nurse, including Glasgow eye chart and pinhole testing if visual acuity less than 6/18 in either eye (targeted screening only consisted of a brief health assessment) | Compare universal screening (assessment and visual acuity) with targeting screening in persons 75 years or older | Cluster randomized controlled trial | Primary care clinic | 75 years or older | Resident in a long stay hospital or nursing home or terminally ill | 106 general practices enrolled 4340 patients screened 3249 randomized (1565 to universal screening and 1684 to targeted screening) | Median age: 80 vs. 80 years Female: 60% vs. 63% Non-white: Not reported Proportion reporting difficulty seeing newsprint: 8% vs. 10% | UK Primary care clinics | Medical Research Council | Visual acuity less than 6/18 | A: Universal screening: Brief and detailed health assessment including measurement of visual acuity w Glasgow acuity chart (reported as Snellen equivalent acuity), referral to an ophthalmologist for pinhole vision <6/18, or referral to an optometrist if pinhole vision corrected to better than 6/18 B: Targeted screening: Brief screening assessment, with detailed assessment only for specified range / level of problems | Universal vs. targeted vision screening: Visual acuity less than 6/18 in either eye: RR 1.07 (95% CI 0.84 to 1.36, p=0.58) National Eye Institute visual function questionnaire (mean score, 0 to 100 scale): 86.0 vs. 85.6 (p=0.69) | 3 to 5 years (median 3.9 years) | 56% (1807/3249) did not complete outcome assessment (1465 deaths) | 80% of those referred to an optician saw one at least once; 55% eligible for referral to ophthalmologist referred and uptake 88% | NR | Good-Fair

Abbreviations: CI = confidence interval, NR = not reported, RR = relative risk.

Evidence Table 2. Quality Ratings of Randomized Controlled Trials on Vision Screening in Older Adults

Study, Year | Random assignment | Allocation concealed | Groups similar at baseline | Eligibility criteria specified | Blinding: outcome assessors or data analysts | Intention-to-treat analysis | Reporting of attrition, contamination, etc | Differential loss to follow-up or overall high loss to follow-up | Appropriate analysis including cluster correlation | Funding source | External validity | Quality score
Cumming et al, 2007 ^69^ Improving vision to prevent falls in frail older people | Randomized but method not described | Yes | Yes | Yes | Can't tell | Yes | Yes | No | NA | National Health and Medical Research Council of Australia | Number screened and eligible not reported Mean severity of visual acuity impairment not reported | Fair
Eekhof et al, 2000 ^66^ Effects of screening for disorders among the elderly: an intervention study in general practice | Yes | NA (cluster) | Yes | Yes | Can't tell | No | Yes | Yes | No | Can't tell | Appears highly applicable to screening settings in primary care | Fair
Moore et al, 1997 ^67^ A randomized trial of office-based screening for common problems in older persons | Yes | NA (cluster) | Yes | Yes | Can't tell | No | Yes | Yes | No | Robert Wood Johnson Clinical Scholars Program; National Institute on Aging Geriatric Academic Program | Appears highly applicable to screening settings in primary care | Fair
Smeeth et al, 2003 ^68^ Screening older people for impaired vision in primary care: cluster randomized trial | Yes | NA (cluster) | Yes | Yes | Can't tell | No | Yes | Yes | Yes | MRC/Dept of Health (UK) | Appears highly applicable to screening settings in primary care | Good-Fair

Abbreviations: NA = not available.

Evidence Table C3. Studies Of Diagnostic Test Accuracy

Study, Year | Type of study | Screening test | Reference standard | Setting | Screener | Age of enrollees | N | Proportion with condition | Subjects | Sensitivity | Specificity | Area under receiver operating curve | Index text | Quality score
Any eye disease
Ariyasu et al, 1996 ^74^ Sensitivity, specificity, and predictive values of screening tests for eye conditions in a clinic-based population | Cross-sectional | Near visual acuity Distance visual acuity Amsler grid | Detailed ophthalmologic assessment | Eye clinic | Ophthalmologist | “Most patients” 20 to 59 years old | 317 | 43% refractive error, 16% cataract, 4% macular degeneration, 4% strabismus, 2% amblyopia | Patients attending for first time an eye clinic in Southern California | Amsler grid: 19% (40/206) Near visual acuity: 20/30 or worse: 83% (145/174); 20/40 or worse: 75% (130/174); 20/50 or worse: 67% (116/174); 20/60 or worse: 59% (102/174) Distance visual acuity: 20/30 or worse: 74% (191/258); 20/40 or worse: 65% (168/258); 20/50 or worse: 55% (143/258); 20/60 or worse: 59% (122/258) | Amsler grid: 92% (46/50) Near visual acuity: 20/30 or worse: 53% (20/38); 20/40 or worse: 74% (28/38); 20/50 or worse: 82% (31/38); 20/60 or worse: 84% (32/38) Distance visual acuity: 20/30 or worse: 73% (41/56); 20/40 or worse: 89% (50/56); 20/50 or worse: 96% (54/56); 20/60 or worse: 98%(55/56) | Near visual acuity: 0.74 +/- 0.04 Distance visual acuity: 0.83 +/- 0.04 (patients 40 years or older only) | Amsler grid Near visual acuity Distance visual acuity | Poor-Fair
Ivers et al, 2001 ^77^ Sensitivity and specificity of tests to detect eye disease in an older population | Cross-sectional | Presenting distance visual acuity (with current distance glasses) Pinhole distance visual acuity Presenting reading acuity (with current reading glasses) | Detailed ophthalmologic assessment | Unclear | Ophthalmologist | 49 years or older | 3654 | 34.50% | Population based sample from the Blue mountains area west of Sydney, Australia | Presenting distance visual acuity: 20/30 or worse: 47%; 20/40 or worse: 27%; 20/60 or worse: 14% Pinhole distance visual acuity: 20/30 or worse: 34%; 20/40 or worse: 15%; 20/60 or worse: 9% Presenting reading acuity: 20/30 or worse: 98%; 20/40 or worse: 89%; 20/50 or worse: 59% | Presenting distance visual acuity: 20/30 or worse: 74%; 20/40 or worse: 87%; 20/60 or worse: 94% Pinhole distance visual acuity: 20/30 or worse: 86%; 20/40 or worse: 96%; 20/60 or worse: 97% Presenting reading acuity: 20/30 or worse: 3%; 20/40 or worse: 19%; 20/50 or worse: 59% | Presenting distance visual acuity: 0.72 Pinhole distance visual acuity: 0.66 Presenting reading acuity: 0.72 | Presenting distance visual acuity (logMAR chart) Pinhole distance visual acuity Presenting reading acuity (with current reading glasses) | Poor-Fair
Wang et al, 1998 ^80^ Evaluation of screening schemes for eye disease in a primary care setting | Cross-sectional | Questionnaire Pinhole visual acuity | Detailed ophthalmologic assessment | Primary care clinic | Unclear | 40 years or older | 405 | 50.7% (13% cataract, ARMD and refractive error not reported) | Patients attending a primary care clinic in Maryland | Questionnaire (questions weighted in logistic regression): 90% (95% CI 86–94%) Presenting visual acuity ≤ 20/40: 61%(95% CI 54–68%) Questionnaire with visual acuity as 2nd screening: 57% (95% CI 50–64%) | Questionnaire (questions weighted in logistic regression): 44% (95% CI 36–50%) Presenting visual acuity ≤ 20/40: 72% (95% CI 66–78%) Question-naire with visual acuity as 2nd screening: 79% (95% CI 73–85%) | NR | Screening questionnaire Presenting distance visual acuity, followed by pinhole visual acuity if worse than 20/30 | Poor-Fair
Woods et al, 1998 ^81^ Screening for ophthalmic disease in older subjects using visual acuity and contrast sensitivity | Cross-sectional | Distance visual acuity Near visual acuity | Detailed ophthalmologic assessment | Eye clinic | Ophthalmologist | 50 years or older | 2522 | 12% (50 to 64 years) and 23% (>64 years) macular degeneration, 4.9% and 27.2% cataract | Population-based sample from residents at least 50 years old in New South Wales, Australia | Distance visual acuity <6/9: 74% Near visual acuity <6/9: 77% | Distance visual acuity <6/9: 87% Near visual acuity <6/9: 68% | NR | Distance visual acuity (Snellen) Near visual acuity (Snellen) | Fair
Cataract
Ivers et al, 2001 ^77^ Sensitivity and specificity of tests to detect eye disease in an older population | Cross-sectional | Presenting distance visual acuity (with current distance glasses) Pinhole distance visual acuity Presenting reading acuity (with current reading glasses) | Detailed ophthalmologic assessment | Eye clinic | Ophthalmologist | 49 years or older | 3654 | Posterior subcapsular cataract: 3.9%, cortical cataract: 19.1%, nuclear cataract: 47.0%; any eye condition: 34.50% | Population based study from the Blue mountains area west of Sydney, Australia | (Results reported for posterior subcapsular cataract, cortical cataract, and nuclear cataract, respectively) Presenting distance visual acuity: 20/30 or worse: 61%, 57%, 44%; 20/40 or worse: 41%, 33%, 25%; 20/60 or worse: 28%, 17%, 13% Pinhole distance visual acuity: 20/30 or worse: 53%, 40%, 31%; 20/40 or worse: 26%, 15%, 13%; 20/60 or worse: 20%, 10%, 8% Presenting reading acuity: 20/30 or worse: 100%, 98%, 97%; 20/40 or worse: 89%, 90%, 88%; 20/50 or worse: 63%, 65%, 57% | (Results reported for posterior subcapsular cataract, cortical cataract, and nuclear cataract, respectively) Presenting distance visual acuity: 20/30 or worse: 67%, 72%, 77%; 20/40 or worse: 83%, 86%, 90%; 20/60 or worse: 92%, 94%, 96% Pinhole distance visual acuity: 20/30 or worse: 80%, 83%, 89%; 20/40 or worse: 93%, 94%, 98%; 20/60 or worse: 96%, 96%, 99% Presenting reading acuity: 20/30 or worse: 3%, 3%, 3%; 20/40 or worse: 16%, 18%, 20%; 20/50 or worse: 53%, 57%, 59% | (Results reported for posterior subcapsular cataract, cortical cataract, and nuclear cataract, respectively) Presenting distance visual acuity: 0.67, 0.69, 0.65 Pinhole distance visual acuity: 0.68, 0.69, 0.67 Presenting reading acuity: 0.63, 0.64, 0.61 | Presenting distance visual acuity (logMAR chart) Pinhole distance visual acuity Presenting reading acuity (with current reading glasses) | Poor-Fair
McMurdo et al, 1988 ^78^ The detection of visual disability in the elderly | Cross-sectional | Geriatrician examination | Ophthalmologist examination | Primary care clinic | Geriatrician | 64 to 97 years | 50 | 18% (9/50) with previously undiagnosed cataract | Patients attending a day clinic | Geriatrician examination: 100% (9/9) | Geriatrician examination: 100% (0/41) | NR | Geriatrician examination | Poor-Fair
Early ARMD
Ivers et al, 2001 ^77^ Sensitivity and specificity of tests to detect eye disease in an older population | Cross-sectional | Presenting distance visual acuity (with current distance glasses) Pinhole distance visual acuity Presenting reading acuity (with current reading glasses) | Detailed ophthalmologic assessment | Eye clinic | Ophthalmologist | 49 years or older | 3654 | 4.50% | Population based study from the Blue mountains area west of Sydney, Australia | Presenting distance visual acuity: 20/30 or worse: 56%; 20/40 or worse: 34%; 20/60 or worse: 13% Pinhole distance visual acuity: 20/30 or worse: 45%; 20/40 or worse: 21%; 20/60 or worse: 10% Presenting reading acuity: 20/30 or worse: 99%; 20/40 or worse: 95%; 20/50 or worse: 70% | Presenting distance visual acuity: 20/30 or worse: 66%; 20/40 or worse: 82%; 20/60 or worse: 92% Pinhole distance visual acuity: 20/30 or worse: 79%; 20/40 or worse: 92%; 20/60 or worse: 95% Presenting reading acuity: 20/30 or worse: 3%; 20/40 or worse: 16%; 20/50 or worse: 53% | Presenting distance visual acuity: 0.65 Pinhole distance visual acuity: 0.64 Presenting reading acuity: 0.67 | Presenting distance visual acuity (logMAR chart) Pinhole distance visual acuity Presenting reading acuity (with current reading glasses) | Poor-Fair
McMurdo et al, 1988 ^78^ The detection of visual disability in the elderly | Cross-sectional | Geriatrician examination | Ophthalmologist examination | Primary care clinic | Geriatrician | 64 to 97 years | 50 | 8% (4/50) with previously undiagnosed macular degeneration | Patients attending a day clinic | Geriatrician examination: 75% (3/4) | Geriatrician examination: 100% (0/46) | NR | Geriatrician examination | Poor-Fair
Refractive error
Ivers et al, 2001 ^77^ Sensitivity and specificity of tests to detect eye disease in an older population | Cross-sectional | Presenting distance visual acuity (with current distance glasses) | Corrected visual acuity | Unclear | Ophthalmologist | 49 years or older | 3654 | 4.50% | Population based study from the Blue mountains area west of Sydney, Australia | Presenting distance visual acuity: 20/30 or worse: 82%; 20/40 or worse: 49%; 20/60 or worse: 22% | Presenting distance visual acuity: 20/30 or worse: 78%; 20/40 or worse: 89%; 20/60 or worse: 94% | Presenting distance visual acuity: 0.88 Pinhole visual acuity: 0.62 Presenting reading acuity: 0.60 | Presenting distance visual acuity (logMAR chart) Pinhole distance visual acuity Presenting reading acuity (with current reading glasses) | Poor-Fair
Visual loss or visual acuity impairment
Eekhof et al, 2000 ^75^ Screening for hearing and visual loss among elderly with questionnaires and tests: which method is the most convincing for action? | Cross-sectional | Screening questions (“Are you able to recognize a face from a distance of 4 m” and “Are you able to read normal newspaper letters”) | Snellen chart and low vision chart (testing vision at reading distance) | Primary care clinics | Primary care provider | 75 years or older | 1121 | Snellen chart <0.3: 10.8% | Patients 75 years and older at 12 general practice clinics in the Netherlands | “Are you able to recognize a face from a distance of 4 m”: 60% (73/122) “Are you able to read normal newspaper letters”: 83% (123/149) | “Are you able to recognize a face from a distance of 4 m”: 81% (814/999) “Are you able to read normal newspaper letters”: 67% (643/965) | NR | Screening questions | Fair
Hiller et al, 1983 ^76^ Validity of a survey question as a measure of visual acuity impairment | Cross-sectional | Screening question (“Do you have trouble with your vision even when wearing glasses or contact lenses?”) | Snellen chart | mobile eye exam clinic | Ophthalmologist | 25 to 74 years (sub-group results for 65 to 74 years) | 3997 (1,466 - 65 to 74 years old) | Snellen 20/25 or worse: 69% | Patients enrolled in population-based sample of community-dwelling adults in the U.S. who reported ever wearing glasses or contact lenses | “Trouble seeing”: 22% (224/1012) for visual acuity 20/25 or worse, 34% (74/216) for 20/50 or worse, 48% (21/44) for 20/100 or worse | “Trouble seeing”: 89% (409/454) for visual acuity 20/25 or worse, 84% (1051/1250) for 20/50or worse, 82% (1170/1422) for 20/100 or worse | NR | Screening question | Fair
Teh et al, 2006 ^79^ Utility of a patient-response screening question for visual impairment | Cross-sectional | Screening question (“Do you have a problem with vision that affects your everyday life?”) | Snellen chart | Geriatric assessment clinic | Unclear | 60 years or older | 112 | Snellen 6/12 or worse: 81% | Patients 60 and older in a geriatric assessment clinic in Singapore | “Do you have a problem with vision that affects your everyday life?”: 68% (62/91) | “Do you have a problem with vision that affects your everyday life?”: 43% (9/21) | NR | Screening question | Poor-fair

Abbreviations: ARMD = age-related macular degeneration; CI = confidence interval.

Evidence Table C4. Quality Ratings, Studies of Diagnostic Test Accuracy

Study, Year | Appropriate spectrum of patients | Adequate sample size (>500) | Credible reference standard used | Reference standard applied to all patients | Screening test adequately described | Reference standard interpreted independently | Quality score
Ariyasu et al, 1996 ^74^ Sensitivity, specificity, and predictive values of screening tests for eye conditions in a clinic-based population | Can't tell | No | Yes | Can't tell | Yes | No | Poor-Fair
Eekhof et al, 2000 ^75^ Screening for hearing and visual loss among elderly with questionnaires and tests: which method is the most convincing for action? | Can't tell | Yes | Yes | Yes | Yes | Can't tell | Fair
Hiller et al, 1983 ^76^ Validity of a survey question as a measure of visual acuity impairment | Yes | Yes | Yes | Can't tell | Yes | Can't tell | Fair
Ivers et al, 2001 ^77^ Sensitivity and specificity of tests to detect eye disease in an older population | Can't tell | Yes | Yes | Can't tell | Yes | Can't tell | Poor-Fair
McMurdo et al, 1988 ^78^ The detection of visual disability in the elderly | Can't tell | No | Yes | Yes | Yes | Yes | Fair
Teh et al, 2006 ^79^ Utility of a patient-response screening question for visual impairment | Can't tell | No | Yes | Can't tell | Yes | Can't tell | Poor-Fair
Wang et al, 1998 ^80^ Evaluation of screening schemes for eye disease in a primary care setting | Can't tell | No | Yes | No | Yes | Can't tell | Poor
Woods et al, 1998 ^81^ Screening for ophthalmic disease in older subjects using visual acuity and contrast sensitivity | Can't tell | Yes | Yes | No | Yes | Can't tell | Poor-Fair

Evidence Table C5. Treatment - Randomized Controlled Trials

Study, Year, Title | Purpose of study | Study design | Inclusion criteria | Exclusion criteria | Number screened/ eligible/enrolled | Subject age, gender, diagnosis | Country & setting | Sponsor | Measures | Intervention | Results | Duration of follow-up | Loss to follow-up | Adverse events & withdrawals due to adverse effects | Quality score | Comments
ARMD (Dry)
AREDS Research Group, 2001 ^114^ A randomized, placebo-controlled clinical trial of high-dose supplementation with vitamins C and E, beta carotene and zinc for age-related macular degeneration and vision loss: AREDS Report No. 8 | To evaluate the effect of high-dose vitamins C and E, beta carotene and zinc supplements on AMD progression and visual acuity | Placebo-controlled trial | BCVA 20/32 or better in at least one eye; at least 1 eye free from eye disease that could complicate assessment of ARMD, lens opacity progression or VA | Previous ocular surgery on disease-free eye; illness or disorders that would make long-term follow-up or compliance with study protocol unlikely or difficult | NR/4754/3640 | Median age 56 years 56% female 96% White; 3% Black; <1% other Mean BCVA at baseline better than 20/32 for all participants | US; multicenter | National Eye Institute, National Institutes of Health, Bausch and Lomb | Primary outcome: progression to advanced ARMD Secondary outcomes: loss of VA, development of wet ARMD | Antioxidant multivitamin - 500 mg vitamin C+400 IU vitamin E+5 mg beta carotene/day zinc 80mg/day antioxidant multivitamin + zinc placebo | Progression to advanced ARMD: antioxidants vs placebo: OR 0.77 (0.56 to 1.05; p=0.03) zinc vs placebo: OR 0.71 (0.51 to 0.98; p=0.005) antioxidants + zinc vs placebo: OR 0.68 (0.49 to 0.93; p=0.002) Loss of ≥3 lines of VA: antioxidants vs placebo: OR 0.87 (0.67 to 1.15; p=0.20) zinc vs placebo: OR 0.82 (0.63 to 1.08; p=0.07) antioxidants + zinc vs placebo: OR 0.77 (0.58 to 1.03; p=0.02) ORs adjusted for age, sex, race, baseline ARMD category and smoking status | mean 6.3 years | 692/3640 (6 year data): 19% | Hospitalizations (due to infection) antioxidants vs no antioxidants: 29/1823 (1.6%) vs 15/1798 (0.8%); p<0.05 Hospitalizations (due to genitourinary cause) zinc vs no zinc: 134.1783 (7.5%) vs 90/1838 (4.9%); p<0.01 | Good
Feher et al, 2005 ^124^ Improvement of visual functions and fundus alterations in early age-related macular degeneration treated with a combination of acetyl-L-carnitine, n-3 fatty acids and coenzyme Q10 | To determine how a combination of acetyl-L-carnitine, n-3 fatty acids and coenzyme Q10 influenced visual function in patients with early ARMD | Placebo-controlled trial | Age 55–70 years; diagnosis of early bilateral ARMD; visual acuity between 8/10 and 4/10 (Snellen decimal scale); agree to discontinue current vitamin regimen; be highly motivated, alert, oriented, mentally competent and able to understand and comply with the requirements of the study | Diagnosis of late ARMD; exudative retinal disease; clinically significant corneal opacity or cataracts; inherited retinal dystrophies or degenerative myopia; unstable glaucoma; PVR, rhegmatogenous retinal detachment; optic nerve disease; active intraocular inflammatory disease; refractive error >+4 diopters and -6 diopters; significant cardiovascular or cerebrovascular diseases; severe or uncontrolled hepatic, renal, pulmonary and thyearoid disease or diabetes; history of HIV infection, hepatitis B or C or other immunosuppressive disorders; history of alcoholism, drug abuse or severe mental disorders; Practicing vegetarian or had an abnormal diet (<1600 or >3500 kcal/day); poor general health or unstable diseases; known or suggested hypersensitivity to study compounds; use of corticosteroid, phenothiazine and antimalarial drugs within 1 month of study and during 12-month study period | NR/NR/106 | Mean age 63.2 years (SD 2.70) 67% female Diagnosis - inclusion criteria specified early ARMD | Hungary; single-center, ophthalmology clinic | NR | Primary outcome: visual field mean defect Secondary outcomes: visual acuity (Snellen and ETDRS charts; logMAR); foveal sensitivity; changes in fundus alteration | 100mg ALC + 530mg n-3 fatty acids + 10mg CoQ10 2×/day placebo (soy oil) 2×/day | Visual acuity in most affected eye (secondary outcome): mean change from baseline at 12 months (Snellen chart) patients ‘improved or unchanged’: 77% (37/48) treatment vs. 55% (29/53) placebo patients ‘deteriorated’: 23% (11/48) vs. 44% (24/53) NSD in less affected eyes | 12 months | NR; withdrawals 5/101 (5%) | AEs not reported; 3 withdrawals dues to AEs (2 treated group; 1 placebo group) | Fair
Kaiser et al, 1995 ^123^ Visaline in the treatment of age-related macular degeneration | To assess the effect of a multivitamin supplement on ARMD progression | Double-blind, placebo-controlled RCT | Age >50 years who had previously consulted an ophthalmologist for ‘nonserous’ ARMD; BCVA 20/100 to 20/25 | Presence of ‘serous’ ARMD; diabetes mellitus; endocrine problems; cardiac dysrhythmia; status following cardiac infarction; uncontrolled hypotension; presence of other ocular diseases | NR/NR/20 | Mean age 72 years 65% female Mean far VA 0.57 | Switzerland; single center, clinic | NR | Change in visual acuity | 1.5mg buphenine HCl, 10mg beta carotene, 10mg tocopherol acetate, 50mg ascorbic acid 2 tablets, 2×/day placebo | Change in mean far VA: multivitamin 0.07 (SD 0.05) vs placebo 0.05 (SD 0.07); p=NS | 6 months | NR | NR | Fair
Newsome et al, 1988 ^118^ Oral zinc in macular degeneration | To assess the effect of zinc on ARMD progression | Double-blind, placebo-controlled RCT | Presence of ARMD evidence by ophthalmoscopically visible drusen with varying degrees of pigmentary change; VA in at least one eye 20/80 or better | Presence of serious eye disease or cataract judged to be clinically sufficient to reduce vision more than one line; diabetes mellitus or other know systemic or metabolic disease; congenital condition that might interfere with the interpretation of results | NR/NR/174 | Mean age 67.9 years 65% female 32% VA >20/25 | United States; setting NR | Utah State University; Mary Katherine Peterson Foundation | Change in visual acuity | zinc 100mg bid placebo | Proportion of patients with loss of 3 lines or more: zinc 6/80 (7.5%) vs placebo 11/71 (15.5%) Change in VA (letters lost): zinc -4.1 vs placebo -7.1 | 24 months | 23/174 (13.2%) | NR | Fair
Richer, 1996 ^120^ ARMD Study Group Multicenter ophthalmic and nutritional age-related macular degeneration study - part 2: antioxidant intervention and conclusions | To assess the effect of a broad-spectrum antioxidant supplement on ARMD | Double-blind PCT | Previous loss of at least 1 line of VA attributable to ARMD | Confounding ocular or systemic disease with ocular manifestations | NR/NR/71 | Mean age 72 years 7% female Mean far VA (LogMAR, right eyes) 0.26 | United States; multiple VA eye clinics | US Department of Veteran Affairs; Twin Laboratories; Stereo Optical; Eye Communications Inc; Illinois College of Optometry; Pacific University College of Optometry; Ezell Foundation | Change in visual acuity | Antioxidant multivitamin (beta carotene 20,000 IU, vitamin E 200 IU, vitamin C 750 mg, citrus bioflavonoid complex 125 mg, quercitin (bioflavonoid) 50 mg, bilberry extract (bioflavonoid) 5 mg, rutin (bioflavonoid) 50 mg, zinc picolinate 12.5 mg, selenium 50 mcg, taurine 100 mg, n-acetyl cysteine 100mg, l-glutathione 5 mg, vitamin B2 25 mg, chromium 100 mcg) qd placebo | Mean visual acuity at 18 months (Log MAR): antioxidant 0.33 (SE 0.07) vs placebo 0.29 (SE 0.05) | 18 months | 59/71 enrolled pts still in study at 18 months | Withdrawals due to AEs: antioxidant 1/35 (2.9%) vs placebo 0/24 (0%) | Fair
Richer et al, 2004 ^121^ Double-masked, placebo-controlled, randomized trial of lutein and antioxidant supplementation in the intervention of atrophic age-related macular degeneration: the Veterans LAST study | To determine whether nutritional supplementation with lutein or lutein together with antioxidants, vitamins and minerals improves visual function and symptoms in atrophic ARMD | Double-blind, placebo-controlled RCT | Diagnosis of atrophic ARMD and at least one vision-degrading visual-psychosocial abnormality associated with ARMD in one or both eyes; clear non-lenticular ocular media, free of advanced glaucoma and diabetes or any other ocular or systemic disease that could affect central or parafoveal macular visual function | Recent (within 6 months) cataract or retinal surgery, use of photosensitizing drugs or did not meet ophthalmic/visual entrance criteria; previous (within 6 months) use of lutein supplements | 109/NR/90 | Mean age 73 years 4% female Mean VA (right eye, LogMAR) 0.377 | United States; vision clinic | Department of Veteran Affairs | Change in visual acuity | 10mg lutein, with or without additional multivitamin | Change in Snellen letter equivalent: lutein alone +5.4 letters vs lutein/multivitamin +3.5 letters vs placebo -2.1 letters Change in visual acuity: lutein alone -0.10 vs lutein+multivitamin -0.03 vs placebo -0.14 | 12 months | 4/90 (4%) | No significant between-group differences, no further data provided Cardiac AEs trended lower in the lutein+multivitamin group vs the other group combined | Fair
Stur et al, 1996 ^122^ Oral zinc and the second eye in age-related macular degeneration | To investigate the short-term effect of oral zinc substitution on the development of age-related macular degeneration in the second eye with exudative ARMD in the first eye | Double-blind, placebo-controlled RCT | Age >50 years with exudative ARMD in one eye with no evidence on exudative ARMD and VA 20/40 or better in second eye | Dense senile cataract and/or any other eye disease that could produce significant and permanent loss of VA during the follow up period; physical status preventive of required follow-up examinations; history of serious systemic or metabolic disease | NR/NR/112 | Mean age 71.5 years 57% female Mean VA (LogMAR) 0.0745 | Austria; single outpatient clinic | NR | Change in visual acuity | 200mg zinc sulfate placebo | Change in VA at 24 months: zinc -0.013 (SD 0.01) vs placebo -0.024 (SD 0.01); p=0.52 | 2 years | 14/112 (12.5%) | Withdrawals due to AEs: zinc 6/56 (10.7%) vs placebo 2/56 (3.8%) Neovascularization: zinc 9/56 (16.1%) vs placebo 5/56 (8.9%) | Fair
ARMD (Wet)
Laser photocoagulation
Macular Photocoagulation Study Group, 1982 ^128^ Argon laser photocoagulation for senile macular degeneration | To determine if argon laser photocoagulation is useful in preventing severe vision loss in eyes with evidence of macular degeneration | RCT; blinding unclear | Age ≥50 years; presence of drusen; angiographic evidence of choroidal neovascular membrane; BCVA 20/100 or better; symptoms related to neovascular membrane; no prior photocoagulation in study eye; no other ocular disease that could affect VA; ability to provide informed consent | NR | NR/NR/224 | Mean age not reported: 52/224 age 50–64; 104/224 (46%) age 65–75; 68/224 (30%) age >75 years 51% female BCVA 20/32 or better: 105/224 | United States; 12 ophthalmology clinics | National Eye Institute; National Institutes of Health | Change in visual acuity | laser photocoagulation vs no treatment | Increase in lines of VA or no change from baseline at 18 months: treatment group 61/100 (61.0%) vs no-treatment group 30/98 (30.6%) Loss of 2–5 lines of VA at 18 months: treatment group 23/100 (23.0%) vs no-treatment group 16/98 (16.3%) Loss of 6–9 lines of VA at 18 months: treatment group 8/100 (8.0%) vs no-treatment group 24/98 (24.5%) Loss of 10 or more lines of VA at 18 months: treatment group 8/100 (8.0%) vs no-treatment group 16/98 (16.3%) | 2 years | Authors state no pts lost to follow-up; however 20/224 were still being followed at 2 years (study endpoint) | Withdrawals: 119/224 (53%) at 1 year | Poor
Macular Photocoagulation Study Group, 1990 ^129^ Krypton laser photocoagulation for neovascular lesions of age-related macular degeneration | To determine whether krypton laser photocoagulation would be of benefit in preventing visual acuity loss in eyes with ARMD | RCT; blinding unclear | Age ≥50 years; presence of drusen in the macula of at least one eye; BCVA 20/4000 | NR | NR/NR/496 | Mean age not reported: 26/496 (5%) age 50–59 years; 147/496 (29%) age 60–69 years; 240/496 (48%) age 70–79 years; 83/497 (17%) age ≥80 years 53% female BCVA 20/40 or better: 157/496 (32%) Median length of follow-up: 48 months | United States; 13 ophthalmology clinics | National Eye Institute; National Institutes of Health | Change in visual acuity | laser photocoagulation vs no treatment | Increase in lines of VA or no change from baseline at 36 months: treatment group 47/174 (27.0%) vs no-treatment group 29/169 (17.2%) Loss of 2–5 lines of VA at 36 months: treatment group 41/174 (23.6%) vs no-treatment group 42/169 (24.9%) Loss of 6–9 lines of VA at 36 months: treatment group 55/174 (31.6%) vs no-treatment group 54/169 (32.0%) Loss of 10 or more lines of VA at 36 months: treatment group 31/174 (17.8%) vs no-treatment group 44/169(26.0%) | 3 years; mean length of follow up 48 mos | 150/494 were still being followed at 3 years (study endpoint) | Withdrawals: 259/496 (52%) at 2 years (median follow-up) AEs reported in treated group only Treatment beyond center of avascular zone: 46/247 (18.6%) Increased hemorrhage: 22/247 (8.9%) Perforation of Bruch's mem-brane: 9/247 (3.6%) Retrobulbar hemorrhage: 4/247 (1.6%) Retinal pigment epithelium rip: 3/247 (1.2%) | Poor
Macular Photocoagulation Study Group, 1991 ^130^ Laser photocoagulation of subfoveal neovascular lesions in age-related macular degeneration | To determine the effect of laser photocoagulation of subfoveal neovascularization in eyes with ARMD but without previous photocoagulation of the macula | RCT; blinding unclear | Age ≥50 years; documented presence of leaking choroidal neovascular lesion under geometric center of foveal avascular zone (FAZ) or within 150 μm of center contiguous w scar from earlier treatment of choroidal neo-vascularization; no prior laser treatment to FAZ center; size of neo-vascular lesion and old treatment scar such that portion of the retina within 1 disc diameter of FAZ center would remain untreated and old and new treated area would not exceed 6 disc areas; BCVA 20/40 to 20/320; no other ocular disease that could compromise VA; no current or past use of systemic steroids; ability to return for follow-up and provide informed consent | NR | NR/NR/373 | Mean age not reported: 16/373 (4%) age 50–59 years; 80/373 (21%) age 60–69 years; 186/373 (50%) age 70–79 years; 91/373 (24%) age ≥80 years 56% female BCVA 20/20 or better: 106/373 (28%); 20/25–20/100: 190/373 (51%); 20/250 or worse: 76/373 (20%) | United States; 13 ophthalmology clinics | National Eye Institute; National Institutes of Health | Change in visual acuity | laser photocoagulation vs no treatment | Loss of <2 lines of VA at 24 months: treatment group 37/114 (32.5%) vs no-treatment group 20/112 (17.9%) Loss of 2–3 lines of VA at 24 months: treatment group 27/114 (23.7%) vs no-treatment group 20/112 (17.9%) Loss of 4–5 lines of VA at 24 months: treatment group 27/114 (23.7%) vs no-treatment group 31/112 (27.7%) Loss of ≥6 lines of VA at 24 months: treatment group 23/114 (20.2%) vs no-treatment group 41/112 (36.6%) | 2 years | 6/192 were still being followed at 2 years | AEs reported in treated group only New hemorrhage: 48/184 (26%) Retinal or vitreous hemorrhage identified during treatment: 6/184 (3.3%) Perforation of Bruch's membrane: 4/184 (2.2%) Retinal hole, retinal pigment epithelium rip, retrobulbar hemorrhage all <1% | Poor
Macular Photocoagulation Study Group, 1991 ^131^ Laser photocoagulation of subfoveal recurrent neovascular lesions in age-related macular degeneration | To determine the effect on vision of laser treatment of subfoveal neovascular lesions compared with no treatment | RCT; blinding unclear | Age ≥50 years; documented presence of leaking choroidal neovascular lesion with well-demarcated boundaries no larger that 3.5 standard disc areas; new vessels under the geometric center of foveal avascular zone; BCVA 20/40 to 20/320; no prior photocoagulation in macula of study eye; no other eye disease that could compromise VA; no current or past use of systemic steroids; ability to return for 5 years of follow-up and provide informed consent | NR | NR/NR/206 | Mean age not reported: 4/206 (2%) age 50–59 years; 57/206 (28%) age 60–69 years; 112/206 (54%) age 70–79 years; 33/206 (16%) age ≥80 years 52% female BCVA 20/20 or better: 70/206(34%); 20/25–20/100: 73/206 (35%); 20/250 or worse: 63/206 (31%) | United States; 13 ophthalmology clinics | National Eye Institute; National Institutes of Health | Change in visual acuity | laser photocoagulation vs no treatment | Loss of <2 lines of VA at 24 months: treatment group 10/35 (28.6%) vs no-treatment group 15/46 (32.6%) Loss of 2–3 lines of VA at 24 months: treatment group 10/35 (28.6%) vs no-treatment group 10/46 (21.7%) Loss of 4–5 lines of VA at 24 months: treatment group 12/35 (34.3%) vs no-treatment group 8/46 (17.4%) Loss of ≥6 lines of VA at 24 months: treatment group 3/35 (8.6%) vs no-treatment group 13/46 (28.3%) | 2 years | 35/370 were still being followed at 2 years | AEs reported in treated group only New hemorrhage: 30/97 (26%) Retinal or vitreous hemorrhage identified during treatment: 6/97 (3.3%) Perforation of Bruch's membrane: 2/97 (2.2%) Retinal pigment epithelium rip: 2/97 (2.1%) | Poor
Moorfields et al, 1982 ^132^ Treatment of senile disciform macular degeneration: a single-blind randomized trial by argon laser photocoagulation | To determine the effects of argon laser photocoagulation in the treatment of neovascular disciform macular degeneration in the elderly | RCT | Age 50–80 years; presence of vascular disciform lesion with a well-defined neovascular membrane, with edges between 100 and 1500 μm from the center of the fovea; detachment of the sensory retina with associated visual symptoms; presence of drusen in the affected and fellow eye | Presence of subretinal exudates or hemorrhages precluding an adequate view of the subretinal structures and new vessel membrane; disease preventing adequate fundus examination and laser photocoagulation; other diseases associated with visual loss; previous photocoagulation in the eye under consideration; myopia of greater than 3 diopters; inability or unwillingness to provide informed consent | NR/NR/128 | Baseline characteristics not reported Inclusion criteria required age 50–80 years; no description of BCVA at baseline | UK; setting NR | National Institutes of Health | Change in visual acuity | laser photocoagulation vs no treatment | Loss of <2 lines of VA at 24 months: treatment group 3/51 (5.9%) vs no-treatment group 3/50 (6.0%) Loss of 2–3 lines of VA at 24 months: treatment group 11/51(21.6%) vs no-treatment group 10/50 (20.0%) Loss of 4–5 lines of VA at 24 months: treatment group 14/51 (27.4%) vs no-treatment group 16/50 (32.0%) Loss of ≥6 or more lines of VA at 24 months: treatment group 9/51 (17.6%) vs no-treatment group 14/50 (28%) | 2 years | 27/128 (21%) | Withdrawals: 27/128 (21%) | Poor
Photodynamic therapy
TAP Study Group, 1999 ^135^ Photodynamic therapy of subfoveal choroidal neovascularization in age-related macular degeneration: one-year results of 2 randomized clinical trials - TAP Report 1 (TAP) Other publications: Kaiser, 2006, TAP and VIP Report 3 | To determine if photodynamic therapy with verteporfin can safely reduce the risk of vision loss in patients with subfoveal choroidal neo-vascularization | Double-blind, placebo-controlled RCT | Age ≥50 years; choroidal neovascularization secondary (CNV) to ARMD; CNV under the geometric center of the foveal avascular zone; evidence of classic CNV; area of CNV at least 50% of the area of the total neovascular lesion; greatest linear dimension of lesion ≤5400 μm; BC TAP protocol VA 73–34 letters; willing and able to provide informed consent | Tear of retinal pigment epithelium; any significant ocular disease that has or could compromise vision in the study eye and confound analysis of the primary outcome; inability to obtain photographs to document CNV, including difficulty with venous access; history of treatment for CNV in study eye other than nonfoveal confluent laser photocoagulation; participation in another ophthalmic clinical trial or use of any other investigational drugs within 12 weeks prior to the start of study treatment; active hepatitis or clinically significant liver disease; porphyearia or porohyearin sensitivity; prior photodynamic therapy for CNV; intraocular surgery within 2 months of study entry or capsulotomy within 1 month in study eye | NR/NR/609 | Mean age 75.3 years 56% female 98% White, 2% other Mean BCVA: 20/80-2 89% subfoveal lesion(s) | United States and Europe; 22 ophthalmology clinics | QLT PhotoTherapeutics Inc; CIBA Vision, Bulach Switzerland | Loss of letters of VA | verteporfin or placebo IV + photodynamic therapy | Loss of ≥6 lines of VA at 12 months: verteporfin 59/402 (14.7%) vs placebo 49/207 (23.7%); RR 0.62 (CI 0.44 to 0.87) Loss of ≥3 lines of VA at 12 months: verteporfin 156/402 (38.8%) vs placebo 111/207 (53.6%); RR 0.72 (CI 0.61 to 0.86) | 1 year | 36/609 (5.9%) | Acute severe loss of VA: verteporfin 3/402 (0.7%) vs placebo 0/207 (0%) Infusion-related back pain: verteporfin 9/402 (2.2%) vs placebo 0/207 (0%) | Good
VIM Study Group, 2005^171^ Verteporfin therapy of subfoveal minimally classic choroidal neovascularization in age-related macular degeneration (VIM) | To compare the treatment effect and safety of photodynamic therapy w verteporfin using a standard or reduced light fluence rate to placebo in patients w subfoveal minimally classic choroidal neo-vascularization with ARMD | Double-blind, placebo-controlled RCT | BCVA of at least 30 (TAP protocol) for lesions of 4 MPS disc areas or less and of 30 to 65 for lesions 4–5 MPS disc areas; evidence of CNV due to ARMD in which at least 50% of the lesion was CNV; fluorescent pattern of some classic CNV that was less than 50% of the entire area of the lesion | NR | NR/NR/117 | Mean age 78 years Mean BCVA: 20/80 92% subfoveal lesion(s) | United States and Europe; 19 ophthalmology clinics | QLT PhotoTherapeutics Inc; Novartis Ophthalmics AG, Bulach, Switzerland | Loss of at least 15 letters of VA at 12 months | verteporfin or placebo IV + photodynamic therapy | Loss of ≥3 lines of VA at 12 months: verteporfin SF 10/36 (27.8%) vs. verteporfin RF 5/36 (13.9%) vs. placebo 18/38 (47%) Loss of ≥6 lines of VA at 12 months: verteporfin SF 3/36 (8%) vs verteporfin RF 0/36 (0%) vs. placebo 6/38 (16%) Loss of ≥3 lines of VA at 24 months: verteporfin SF 17/32 (8%) vs verteporfin RF 9/34 (26.4%) vs. placebo 18/37 (48.6%) Loss of ≥6 lines of VA at 24 months: verteporfin SF 4/32 (12.5%) vs. verteporfin RF 6/34 (17.6%) vs. placebo 13/37 (35.1%) | 2 years | 14/117 (12.0%) | Acute severe loss of VA: verteporfin 1/77 (1.3%) vs placebo 1/40 (2.5%) Infusion-related back pain: verteporfin 9/77 (11.7%) vs placebo 1/40 (2.5%) | Good
VIP Study Group, 2001^170^ Verteporfin therapy of subfoveal choroidal neovascularization: two-year results of a randomized clinical trial including lesions with occult with no classic choroidal neovascularization - Verteporfin in Photodynamic Therapy Report 2 (VIP) | To determine if photodynamic therapy with verteporfin can safely reduce the risk of vision loss compared with a placebo | Double-blind, placebo-controlled RCT | Age ≥50 years; choroidal neovascularization secondary (CNV) to ARMD; CNV under the geometric center of the foveal avascular zone; evidence of classic CNV; area of CNV at least 50% of the area of the total neovascular lesion; greatest linear dimension of lesion ≤5400 μm; BC TAP protocol VA 73-34 letters; willing and able to provide informed consent | Features of any condition other than age-related macular degeneration associated with CNV in study eye; tear of retinal pigment epithelium; any significant ocular disease that has or could compromise vision in the study eye and confound analysis of the primary outcome; inability to obtain photographs to document CNV, including difficulty with venous access; history of treatment for CNV in study eye other than nonfoveal confluent laser photocoagulation; participation in another ophthalmic clinical trial or use of any other investigational drugs within 12 weeks prior to the start of study treatment; active hepatitis or clinically significant liver disease; porphyearia or porohyearin sensitivity; prior photodynamic therapy for CNV; intraocular surgery within 2 months of study entry or capsulotomy within 1 month in study eye | NR/NR/339 | Mean age 75 years 99% White; 1% other Mean BVCA: 20/50+1 83.4% subfoveal lesion(s) | United States and Europe; 28 ophthalmology clinics | QLT PhotoTherapeutics Inc; CIBA Vision, Bulach, Switzerland | Loss of fewer than 8 letters of VA | verteporfin or placebo IV + photodynamic therapy | Loss of ≥3 lines of VA at 12 months: verteporfin 114/225 (50.7%) vs placebo 62/114 (54.3%); RR 0.44 (CI 0.25 to 0.77) | 2 years | 47/339 (13.9%) | Acute severe loss of VA: verteporfin 10/225 (4.4%) vs placebo 0/114 (0%) Infusion-related back pain: verteporfin 5/225 (2.2%) vs placebo 0/114 (0%) | Good
VEGF inhibitors
Gragoudas et al, 2004 ^144^ Pegaptanib for neovascular age-related macular degeneration (VISION; 2 trials) Other publications: VEGF Inhibitor Study Group, 2006; Leys, 2007 | To test the short-term safety and effectiveness of pegaptanib | 2 concurrent, pro-spective double-blind RCTs | ≥50 years with subfoveal sites of choroidal neovascularization secondary to ARMD and best corrected visual acuity of 20/40-20/320 in study eye and 20/800 or better in other eye | Patients were ineligible to participate in the study if they had atrophy exceeding 25% of the total lesion area or subfoveal scarring in the study eye; history of previous subfoveal thermal laser therapy or previous or concomitant therapy with any investigational agent to treat AMD (except vitamins and minerals); other exclusion criteria were likelihood of requiring cataract surgery within 2 years; other potential causes of CNV, including myopia of 8 diopters or more or axial length of 25 mm or more, ocular histoplasmonthsis syndrome, angioid streaks, choroidal rupture, or multifocal choroiditis; any intraocular surgery within 3 months or extrafoveal/juxtafoveal laser within 2 weeks of study entry; previous posterior vitrectomy or scleral buckling surgery; and presence of retinal pigment epithelial tears or rips; diabetic retinopathy; history or evidence of severe cardiac disease; a myocardial infarction within 6 months; ventricular tachyarrhythmia requiring ongoing treatment or unstable angina; history or evidence of peripheral vascular disease; stroke within 12 months of study entry; acute ocular or periocular infection; previous therapeutic radiation to the eye, head, or neck; any treatment with an investigational agent in the past 60 days for any condition; and known serious allergies to fluorescein dye or to components of the pegaptanib formulation. | NR/NR/1208 | Mean age NR; Age range 50–64 years: 6%; 65–74 years: 32%; 75–84 years: 52%; ≥85 years: 10% 58% female 96% White; 4% Other Mean visual acuity, study eye: 51.8 letters (SD 12.8) | N. America, S. America, Europe, Israel, Australia 117 sites | Eyetech Pharmaceuticals and Pfizer | Change in visual acuity, measured by loss of <15 letters at week 54 | 0.3mg, 1.0mg or 3.0mg pegaptanib every 6 weeks up to 48 weeks (9 txs) sham injection | Patients with loss of >3 lines of VA at 54 weeks: 0.3mg pegaptanib 88/294 (29.9%) vs. 1.0mg pegaptanib 87/300 (29.0%) vs. 3.0mg pegaptanib 103/296 (34.8%) vs. sham injection 132/296 (44.6%); All combined doses pegaptanib vs sham injection: RR 0.77 (CI 0.65 to 0.92; p=0.004) | 54 weeks | NR | Withdrawals due to AEs: 1% in pegabtanib groups and 1% in sham injection groups Serious AEs: 19% in pegaptanib groups vs 15% in sham injection groups No systemic AEs; death rate 2% in all groups Endophthalmitis 0.16% pegaptanib Traumatic cataract 0.07% pegaptanib Retinal detachment 0.08% pegaptanib | Fair | 1186/1208 randomized patients included in analyses; 4 post-randomization exclusions
Regillo et al, 2008 ^143^ Randomized, double-masked, sham-controlled trial of ranibizumab for neovascular age-related macular degeneration: PIER study year 1 | To evaluate the efficacy and safety of ranibizumab | Double-blind RCT | Age≥50 years; primary or recurrent subfoveal CNV secondary to AMD, with the total CNV area (classic plus occult CNV) composing 50% of the total AMD lesion area; total AMD lesion size of 12 disk areas (DA); best-corrected VA of 20/40 to 20/320; minimally classic or occult with no classic CNV were eligible only if they met the criteria for presumed disease progression | Prior treatment with PDT; external-beam radiation therapy, transpupillary thermotherapy, or subfoveal laser photocoagulation (or juxtafoveal or extrafoveal laser photocoagulation one month before day zero); permanent structural damage to the central fovea; subretinal hemorrhage involving the fovea if 1 DA or 50% of the total lesion area; prior treatment with an antiangiogenic drug or if the nonstudy eye received PDT seven days before day zero | NR/NR/184 | Mean age ~78 years 60% female neovascular ARMD | US 43 sites setting NR | Genentech and Novartis Pharma AG | Change in visual acuity from baseline (ETDRS) | 0.3mg or 0.5mg ranibizumab 1×/month for 3 months followed by every 3 months sham injection | Mean change from baseline VA at 12 months: 0.3mg -1.6 letters vs 0.5mg -0.2 letters vs sham injection -16.3 letters Loss of >3 lines of of VA at 12 months: 0.3mg 10/60 (16.7%) vs 0.5mg 6/61 (9.8%) vs sham injection 32/63 (50.8%) Gain of ≥3 lines of VA at 12 months: 0.3mg 7/60 (11.7%) vs 0.5mg 8/61 (13.1%) vs sham injection 6/63 (9.5%) Patients with VA worse than 20/200 at 12 months: 0.3mg 14/60 (23.3%) vs 0.5mg 15/61(24.6%) v sham injection 33/63 (52.4%) No statistically significant difference between groups in NEI-VFQ 25 subscale score (data not reported) | 12 months | none reported; all patients accounted for | No cases of endophthalmitis, uveitis, retinal detachment or lens damage in any treatment group Ocular hemorrhage: 2/59 (3.4%) 0.3mg group vs 0/61 (0%) 0.5mg group vs 2/63 (3.2%) sham injection group Macular edema: 1/59 (1.7%) 0.3mg group vs 0/0 (0%) 0.5mg group vs 2/63 (3.2%) sham injection group Hypertension 4/59 (6.8%) 0.3mg group vs 6/61 (9.8%) 0.5mg group vs 5/63 (8.1%) sham injection group | Good
Rosenfeld et al, 2006 ^145^ MARINA Trial Ranibizumab for neovascular age-related macular degeneration Other publications: Boyer 2007 | To evaluate the effectiveness and safety of ranibizumab for the treatment of minimally classic or occult with no classic choroidal neovasculatization associated with ARMD | Pro-spective, double-blind RCT | Age ≥50 years; best corrected visual acuity 20/40 to 20/320 (Snellen equivalent determined with use of ETDRS chart); primary or recurrent choroidal neovascularization associated with ARMD, involving the foveal center; have a type of lesion that had been assessed with the use of fluorescein angiography and fundus photography as minimally classic or occult with no classic choroidal neovascularization; have a maximum lesion size of 12 optic-disk areas, with neovascularization composing ≥50% of the entire lesion; have presumed recent disease progression, as evidenced by observable blood, recent vision loss or a recent increase in a lesion's greatest linear diameter of >10%. | Prior treatment with verteporfin photodynamic therapy, external-beam radiation therapy, or transpupillary thermotherapy in the study eye; treatment with verteporfin photodynamic therapy in the nonstudy eye less than 7 days preceding day 0; previous participation in a clinical trial (for either eye) involving antiangiogenic drugs (pegaptanib, ranibizumab, anecortave acetate, protein kinase C inhibitors, etc.); previous intravitreal drug delivery (e.g., intravitreal corticosteroid injection or device implantation) in the study eye; previous subfoveal focal laser photocoagulation in the study eye; laser photocoagulation (juxtafoveal or extrafoveal) in the study eye within 1 month preceding day 0; history of vitrectomy surgery in the study eye; history of submacular surgery or other surgical intervention for AMD in the study eye; previous participation in any studies of investigational drugs within 1 month preceding day 0 (excluding vitamins and minerals) subretinal hemorrhage in the study eye that involves the fovea, if the size of the hemorrhage is either 50% or more of the total lesion area or 1 or more disc areas in size; subfoveal fibrosis or atrophy in the study eye; CNV in either eye due to other causes, such as ocular histoplasmosis, trauma, or pathologic myopia; retinal pigment epithelial tear involving the macula in the study eye; any concurrent intraocular condition in the study eye (e.g., cataract or diabetic retinopathy) that, in the opinion of the investigator, could either (a) require medical or surgical intervention during the 24-month study period to prevent or treat visual loss that might result from that condition, or (b) if allowed to progress untreated, could likely contribute to loss of at least 2 Snellen equivalent lines of best corrected visual acuity over the 24-month study period; active intraocular inflammation (grade trace or above) in the study eye; urgent vitreous hemorrhage in the study eye; history of rhegmatogenous retinal detachment or macular hole (Stage 3 or 4) in the study eye; history of idiopathic or autoimmune-associated uveitis in either eye; infectious conjunctivitis, keratitis, scleritis, or endophthalmitis in either eye; aphakia or absence of the posterior capsule in the study eye; spherical equivalent of the refractive error in the study eye demonstrating more than -8 diopters of myopia; intraocular surgery (including cataract surgery) in the study eye within 2 months preceding day 0; uncontrolled glaucoma in the study eye (defined as intraocular pressure of 30 mmHg or more despite treatment with antiglaucoma medications; history of glaucoma filtering surgery in the study eye; history of corneal transplant in the study eye; premenopausal women not using adequate contraception; history of other disease, metabolic dysfunction, physical examination finding, or clinical laboratory finding giving reasonable suspicion of a disease or condition that contraindicates the use of an investigational drug or that might affect interpretation of the results of the study or render the subject at high risk for treatment complications; current treatment for active systemic infection; history of allergy to fluorescein, not amenable to treatment with diphenhydramine;inability to obtain fundus photographs or fluorescein angiogram of sufficient quality to be analyzed and graded by the central reading center; inability to comply with study or follow-up procedures. | NR/NR/716 | Mean age 77 years (SD 8) 65% female ARMD | US 96 sites - clinical setting NR | Genentech and Novartis Pharma | Change in visual acuity measured by loss of fewer than 15 letters from baseline (ETDRS) | 0.3mg or 0.5mg ranibizumab 1x/month (range 23–37 days) for 2 years sham injection | Mean change in visual acuity at 12 months: ranibizumab 0.3mg 6.5 letters vs. ranibizumab 0.5mg 7.2 letters vs. placebo -10.4 letters; p<0.001 for both doses ranibizumab vs. placebo Mean change in visual acuity at 24 months: ranibizumab 0.3mg 5.4 letters vs. ranibizumab 0.5mg 6.6 letters vs. placebo -14.9 letters; p<0.001 for both doses ranibizumab vs. placebo Loss of >3 lines of VA at 12 months: ranibizumab 0.3 mg 13/238 (5.5%) vs ranibizumab 0.5mg 13/240 (5.4%) vs sham injection 90/238 (37.8%); All combined doses ranibizumab vs sham injection RR 0.19 (CI 0.12 to 0.28; p<0.0001) Loss of >3 lines of VA at 24 months: ranibizumab 0.3 mg 19/238 (8.0%) vs ranibizumab 0.5mg 24/240 (10.0%) vs sham injection 112/238 (47.1%); All combined doses ranibizumab vs sham injection RR 0.26 (CI 0.19 to 0.36; p<0.0001) | 2 years | 8/716 (1.1%) | Withdrawals due to AEs: 16/716 (2.2%) Serious AEs: ranibizumab 0.3mg 3/238 (1.3%) vs. ranibizumab 0.5mg 5/239 (2.0%) vs. placebo 2/236 (<1%) All-cause mortality: ranibizumab 0.3mg 5/238 (2.1%) vs. ranibizumab 0.5mg 6/239 (2.5%) vs. placebo 6/236 (2.5%) | Fair
Catarac
Chylack et al, 2002 ^109^ The Roche European American Cataract Trial (REACT): a randomized clinical trial to investigate the efficacy of an oral antioxidant micronutrient to slow progression of age-related cataract | To determine if a mixture of oral antioxidants would modify progression of cataract | Double-blind placebo-controlled trial of consecutively enrolled patients | Able to provide written informed consent; able to attend for all visits; ≥ 40 years old; at least one eye met the following ocular criteria: cataract extraction unlikely within two years, immature idiopathic ‘senile’ cataract present in one or both eyes, U.S. patients: presence of minimal cataract by Lens Opacities Classification System [LOCS II]14 criteria, U.K. patients: presence of cataract of minimal Oxford grade; logMAR acuity ≤0.5; ocular media clear enough to capture good images of the lens; remote risk of angle closure glaucoma; pupil dilatable to 6mm; oscillatory movement displacement threshold ≤50S; no visually significant fundus pathology; no clinical signs of glaucoma and intraocular pressure; no history of amblyopia, eye surgery, argon or YAG laser eye treatment, or major eye trauma; no history of iritis, retinal crystalline deposits, or optic nerve disease; no extended (daily for >3 months) use of ocular corticosteroid or glaucoma therapy; no participation in another clinical trial investigating an anticataract formulation within the last year. | Pregnancy; insulin dependent diabetes mellitus; severe renal failure or kidney stones; fat malabsorption syndrome; history of major intestinal surgery; chronic diarrhea; alcoholism; extended use of systemic corticosteroid treatment; use of anticoagulants; regular use of any vitamin supplement. | NR/445/315 | Mean age 66.2 years 59% female UK cohort older and had poorer nutritional status at baseline (p<0.005) | US and UK; 3 outpatient ophthalmology clinics | F. Hoffmann-LaRoche Ltd; Roche Vitamins | Primary outcome: cataract progression | Antioxidant multivitamin (250mg vitamin C + 200mg vitamin E + 6mg beta carotene) tid placebo | Multiple methods used to evaluate changes in lens opacities; following 3 years of treatment there was a marginally significant between group difference in cataract progression (p=0.048) based on the primary outcome measure only (% pixels opaque) and not for other measure of cataract progression (e.g. LOCS) | 3 years | 47% | NR | Fair | Only ‘completers’ included in 3-year analysis; authors acknowledge primary outcome measure of questionable clinical significance due to its ability to measure very small changes in lens opacities - modeling used to predict long-term effect on cataract progression
Foss et al, 2006 ^107^ Falls and health status in elderly women following second eye cataract surgery: a randomised controlled trial | To determine if second eye cataract surgery reduces the risk of falling and to measure associated health gain | RCT; immediate vs delayed treatment | Women age ≥70 years with a previous, successful cataract operation who had a second, operable cataract | Complex cataracts due to Fuch's corneal dystrophy, active intraocular inflammation, lens zonule dehiscence or lens instability; visual field defects; severe comorbid eye disease affecting visual acuity; memory problems preventing the completion of questionnaires or reliable recall of falls | 1000/313/239 | Mean age 79.5 years 100% female Cataract | UK; hospital ophthalmology clinic | Health Foundation Trent Regional Health Authority | Primary outcome: patient-recorded falls Secondary outcomes: change in health status | Cataract surgery no/delayed treatment | Proportion of patients with falls: 48/120 (40%) immediate surgery group vs 41/119 (34%) delayed treatment group; HR 1.06 (CI 0.69 to 1.61; p=0.80) Proportion of patients with second falls: 22/120 (18%) immediate surgery group vs 22/119 (18%) delayed treatment group; HR 0.85 (CI 0.49 to 1.56; p=0.61) Rate of falling per 1,000 patient days: 2.9 immediate treatment group vs 4.3 delayed treatment group; Rate ratio 0.68 (CI 0.39 to 1.19; p=0.18) | 12 months | 16/239 (7%) | NR | Good
Harwood et al, 2004 ^106^ Falls and health status in elderly women following first eye cataract surgery: a randomised controlled trial | To determine if first eye cataract surgery reduces the risk of falling and to measure associated health gain | RCT; immediate vs delayed treatment | Women age ≥70 years with cataract who were suitable for surgery and had not had previous ocular surgery | Cataracts not eligible for surgery by phacoemulsification due to Fuch's corneal dystrophy, active intraocular inflammation, lens zonule dehiscence or lens instability; refractive error in second eye of > +4.00 or ≤ -6.00 DS; visual field defects; severe comorbid eye disease affecting visual acuity; partially sighted as a result of cataract; memory problems preventing the completion of questionnaires or reliable recall of falls | 1600/482/306 | Mean age 78.5 years 100% female Cataract | UK; multiple ophthalmologic/optometric clinics | Trent Regional NHS Research and Development scheme PPP (Health) Foundation | Primary outcome: patient-recorded falls following cataract surgery Secondary outcomes: change in various QOL measures | Cataract surgery (phacoemulsification) no/delayed treatment | Proportion of patients with falls: 76/154 (49%) immediate surgery group vs 69/152 (45%) delayed treatment group; HR 0.95 (CI 0.69 to 1.35; p=0.77) Proportion of patients with second falls: 28/154 (18%) immediate surgery group vs 38/152 (25%) delayed treatment group; HR 0.60(CI 0.36 to 0.98; p=0.04) Rate of falling per 1,000 patient days: 1.0 immediate treatment group vs 1.52 delayed treatment group; Rate ratio 0.66 (CI 0.45 to 0.96; p=0.03) Fracture incidence: 4/154 (3%) immediate treatment group vs 12/152 (8%) delayed treatment group; Risk ratio 0.33 (CI 0.1 to 1.0; p=0.04) | 12 months | 13/306 (4%) | NR | Good
Uncorrected refractive error
Coleman et al, 2006 ^83^ Treatment of uncorrected refractive error improves vision-specific quality of life | To evaluate the benefits of eyeglasses and magnifiers in elderly patients with uncorrected refractive error | Prospective RCT | Age >65 years with habitual binocular visual acuity 20/32 or worse whose distance or near visual acuity could be improved by at least 2 lines of acuity; fixed residence for 3 months of study; speak and understand English; have a phone or other method of being contacted by research team; ambulatory with a cane or walker; MMSE score ≥23; capable of providing informed consent | NR | 1309/131/131 | Mean age 80.4 years (SD 8.2) 72% female 63% White; 18% Black; 8% Asian; 3% Hispanic; 8% Other. Mean baseline visual acuity 20/63 | US Community screening centers followed by home visit | UCLA Claude D. Pepper Older American Independence Center | Primary outcome: Change in National Eye Institute Visual Functioning Questionnaire Secondary outcomes: Change in visual acuity based on logMAR chart; Overall functioning based on the Rosow-Breslau function questionnaire | Intervention group: Received vision correction aids immediately (glasses, magnifier or both) Control group: Received a voucher and prescription to obtain vision correction aids at the conclusion of the trial (3 months later) | Mean change from baseline at 3 months, with glasses vs. without glasses National Eye Institute Visual Functioning Questionnaire: Composite score: 6.5 (SD 9.3) vs. -0.8 (SD 10.8); p<0.01 Selected individual components:; - General health: 4.2 (SD 18.0) vs. -0.4 (SD 17.4); p=.17; - General vision: 10.4 (SD 18.2) vs. -2.1 (SD 14.0); p<0.01; - Near vision: 7.6 (SD 19.1) vs. 0.4 (SD 17.4); p=0.04; - Distance vision: 3.3 (SD 23.2) vs. -6.3 (SD 22.7); p=0.03; - Social functioning: 4.5 (SD 21.0) vs. -0.9 (SD 19.6); p=0.17; Mental health: 11.2 (SD 25.3) vs. 0.4 (SD 24.2); p=0.02 Geriatric Depression Scale: -0.3 (SD 1.9) vs. -0.1 (SD 2.1); p=0.58 Rosow-Breslau functioning scale: 0.07 (SD 1.3) vs. -0.4 (SD 1.4); p=0.07 Distance visual acuity: 5.5 (SD 10.0) vs. 3.9 (10.4); p=0.41 Near visual acuity: 6.1 (SD 13.3) vs. 2.2 (SD 11.4); p=0.10 | 3 months | 20/131 (15%) | NR | Fair
Owsley et al, 2007 ^84^ Effect of refractive error correction on health-related quality of life and depression in older nursing home residents | To examine the effect of treating uncorrected refractive error through spectacle correction on vision-targeted health-related quality of life and depressive symptoms in nursing home residents | RCT immediate vs. delayed treatment | Able to answer simple questions about vision and daily activities; age ≥55 years; English speaker; Mini-Mental State Examination (MMSE) score ≥13; uncorrected refractive error in 1 or both eyes for near or far test distances as determined by routine eye exam w/optometrist within 1 month of study entry; correction of uncorrected refractive error had to improve visual acuity by at least 1 mile on a distance visual acuity chart for at least 1 eye according to optometrist's records | NR | NR/NR/151 | Mean age 78.7 years (SD 8.3) 76% female Diagnosis - Uncorrected refractive error; concomitant cataract (64%), ARMD (16%), diabetic retinopathy (6%), glaucoma (4%) | US; 17 nursing homes | Retirement Research Foundation, the EyeSight Foundation of Alabama, The Pearle Vision Foundation, NIH grant r21-EY14071, Research to Prevent Blindness Inc | Primary outcomes: QOL based on Nursing Home Vision-Targeted Health-Related Quality of Life (NHVQoL) Questionnaire and the VF-14; depressive symptoms based on Geriatric Depression Scale | Immediate (within 1 week) refractive error correction with glasses vs. delayed correction (glasses dispensed 2 months later) | Immediate vs. delayed correction at 2 months: NHVQoL subscale score - range 0–100; - General vision: 77.3 vs. 65.0; p<0.001; - Reading: 92.9 vs. 84.7; p<0.001; - Ocular symptoms: 81.4 vs. 78.3; p=0.23; - mobility: 91.5 vs. 90.0; p=0.24; - Psychological distress: 76.0 vs. 70.7; p=0.02; - Activities of daily living: 99.7 vs. 99.1; p=0.17; - Activities and hobbies: 98.0 vs. 94.0; p=0.04; - Adaptation and coping: 92.4 vs. 90.0; p=0.11; - Social interaction: 97.3 vs. 94.1; p=0.03; VF-14 total score - range 0–10095.7 vs. 83.1; p<0.001 SF-36 score - range 0–100; - Mental component summary 81.9 vs. 80.8; p=0.96; - Physical component summary 47.6 vs. 46.1; p=0.24; GDS score 3.6 vs. 4.9; p=0.003 | 2 months | 9/151 (6%) | NR | Fair | p-values adjusted based on baseline value of outcome and baseline mental status

Abbreviations: AE = adverse effect, AMD = age-related macular degeneration, ARMD = age-related macular degeneration, CI = confidence interval, CNV = choroidal neovascularisation, ETDRS = Early Treatment Diabetic Retinopathy Study, GDS = geriatric depression scale, LOCS = Lens Opacities Classification System, logMAR = logarithmic minimum angle of resolution, MI = myocardial infarction, MMSE = mini mental state examination, NHVQoL = nursing home vision-targeted health-related quality of life questionnaire, NR = not relevant, QOL = quality of life, RCT = randomized controlled study, RR = relative risk, SD = standard deviation.

Evidence Table C6. Quality Ratings of Treatment Randomized Controlled Trials

Study, Year | Random assignment | Allocation concealed | Groups similar at baseline | Eligibility criteria specified | Blinding: patients | Blinding: providers | Blinding: outcome assessors or data analysts | Intention-to-treat analysis | Reporting of attrition, contamination, etc | Differential loss to follow-up, overall high loss to follow-up, or incomplete follow-up | Funding source | External validity | Quality score
AREDS Research Group, 2001 ^114^ A randomized, placebo-controlled clinical trial of high-dose supplementation with vitamins C and E, beta carotene and zinc for age-related macular degeneration and vision loss: AREDS Report No. 8 | Randomized but method not described | Yes | Yes | Yes | Yes | Yes | Can't tell | Yes | Yes | No | National Eye Institute, National Institutes of Health, Bausch and Lomb Inc | Median age 56 yrs Mean BCVA at baseline better than 20/32 for all participants | Good
Coleman et al, 2006 ^83^ Treatment of uncorrected refractive error improves vision-specific quality of life | Randomized but method not described | Yes | Yes | Yes | NA | NA | Can't tell | No | Yes | Yes | UCLA Claude D. Pepper Older American Independence Center | Appears applicable to screening population; average visual acuity 20/63 | Fair
Cumming et al, 2007 ^69^ Improving vision to prevent falls in frail older people: a randomized trial | Randomized but method not described | Yes | Yes | Yes | NA | NA | Can't tell | Yes | Yes | No | National Health and Medical Research Council of Australia | Number screened and eligible not reported. Mean severity of visual acuity impairment not reported | Fair
Foss et al, 2006 ^107^ Falls and health status in elderly women following second eye cataract surgery: a randomised controlled trial | Yes | Yes | Yes | Yes | NA | NA | No | Yes | Yes | No | Health Foundation Trent Regional Health Authority | At baseline similar number of prior falls reported in both groups | Good
Harwood et al, 2005 ^106^ Falls and health status in elderly women following first eye cataract surgery: a randomised controlled trial | Yes | Yes | Yes | Yes | NA | NA | No | Yes | Yes | No | Trent Regional NHS Research and Development Scheme; PPP (Health) Foundation | At baseline similar number of prior falls reported in both groups | Good
Kaiser et al, 1995 ^123^ Visaline in the treatment of age-related macular degeneration: a pilot study | Randomized but method not described | Can't tell | Yes | Yes | Yes | Yes | Can't tell | Yes | No | Can't tell | NR | Mean age 72 yrs 65% female Mean far VA 0.57 | Fair
MPS Group 1982 ^128^ Argon laser photocoagulation for senile macular degeneration. Results of a randomized clinical trial | Yes | Can't tell | No | Yes | No | No | No | No | Yes | Yes | National Eye Institute, National Institutes of Health | BCVA 20/32 or better: 105/224 (47%) | Poor
MPS Group 1991a ^130^ Laser photocoagulation of subfoveal neovascular lesions in age-related macular degeneration | Randomized but method not described | Can't tell | Yes | Yes | No | No | No | No | Yes | Yes | National Eye Institute, National Institutes of Health | BCVA 20/20 or better: 106/373 (28%); 20/25-20/100: 190/373 (51%); 20/250 or worse: 76/373 (20%) | Poor
MPS Group 1991b ^131^ Laser photocoagulation of subfoveal recurrent neovascular lesions in age-related macular degeneration. Results of a randomized clinical trial | Randomized but method not described | Can't tell | No | Yes | No | No | No | No | Yes | Yes | National Eye Institute, National Institutes of Health | BCVA 20/20 or better: 70/206(34%); 20/25-20/100: 73/206 (35%); 20/250 or worse: 63/206 (31%) | Poor
MPS Group 1990 ^129^ Krypton laser photocoagulation for neovascular lesions of age-related macular degeneration. Results of a randomized clinical trial | Randomized but method not described | Can't tell | No | Yes | No | No | No | No | No | Yes | National Eye Institute, National Institutes of Health | BCVA 20/40 or better: 157/496 (32%) | Poor
Moorfields, 1982 ^132^ The Moorefields Macular Study Group Treatment of senile disciform macular degeneration: a single-blind randomised trial by argon laser photocoagulation | Randomized but method not described | Can't tell | Can't tell | Yes | Can't tell | Can't tell | Can't tell | No | Yes | No | National Eye Institute, National Institutes of Health, Medical Research Council | Inclusion criteria required age 50–80 yrs; no description of BCVA at baseline | Poor
Newsome, 1988 ^118^ Oral zinc in macular degeneration | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Utah State University; Mary Katherine Peterson Foundation | Mean age 67.9 yrs 65% female 32% VA >20/25 | Fair
Owsley et al, 2007 ^84^ Effect of refractive error correction on health-related quality of life and depression in older nursing home residents | Randomized but method not described | Can't tell | Yes | Yes | NA | NA | Can't tell | Yes | Yes | No | Retirement Research Foundation, the EyeSight Foundation of Alabama, The Pearle Vision Foundation, NIH grant r21-EY14071, Research to Prevent Blindness Inc | Number screened and eligible not reported. Mean refractive error +0.19 vs. -0.19 (spherical equivalents, SD) | Fair
Regillo et al, 2008 ^143^ Antiangiogenic therapy with anti-vascular endothelial growth factor modalities for neovascular age-related macular degeneration | Yes | NA | Yes | Yes | Yes | No | Yes | Yes | Yes | No | Genentech; Novartis Pharma AG | Mean baseline VA 20/63 to 20/80; most patients newly diagnosed with ARMD (87% within one year of diagnosis) | Good
Richer et al, 1996 ^120^ ARMD Study Group Multicenter ophthalmic and nutritional age-related macular degeneration study — part 2: antioxidant intervention and conclusion | Randomized but method not described | Can't tell | Yes | Yes | Yes | Yes | Yes | Can't tell | Yes | Yes | US Department of Veteran Affairs; Twin Laboratories; Stereo Optical; Eye Communications Inc; Illinois College of Optometry; Pacific University College of Optometry; Ezell Foundation | Mean age 72 yrs 7% female Mean far VA (LogMAR, right eyes) 0.26 | Fair
Richer et al, 2004 ^121^ Double-masked, placebo-controlled, randomized trial of lutein and antioxidant supplementation in the intervention of atrophic age-related macular degeneration: the Veterans LAST study (Lutein Antioxidant Supplementation Trial) | Yes | Yes | No | Yes | Yes | Yes | Yes | Can't tell | Yes | Yes | Department of Veterans Affairs | Mean age 73 yrs 4% female Mean VA (right eye, LogMAR) 0.377 | Fair
Rosenfeld et al, 2006 ^145^ Ranibizumab for neovascular age-related macular degeneration | Randomized but method not described | Can't tell | Yes | Yes | Yes | No | Yes | Yes | Yes | No | Genentech and Novartis | >85% had visual acuity >20/200 | Fair
Stur et al, 1996 ^122^ Oral zinc and the second eye in age-related macular degeneration | Randomized, but method not described | Can't tell | Yes | Yes | Yes | Yes | Can't tell | No | Yes | No | Austrian Foundation for the Propogation of Scientific Research | Mean age 71.5 yrs 57% female Mean VA (LogMAR) 0.0745 | Fair
TAP Study Group, 1999 ^135^ Photodynamic therapy of subfoveal choroidal neovascularization in age-related macular degeneration with verteporfin: one-year results of 2 randomized clinical trials—TAP report | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | No | QLT PhotoTherapeutics, CIBA Vision AG | Mean BCVA: 20/80-2 89% subfoveal lesion(s) | Good
VIM Study Group, 2005 ^137^ Verteporfin therapy of subfoveal minimally classic choroidal neovascularization in age-related macular degeneration (VIM): 2-year results of a randomized clinical trial | Randomized but method not described | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Novartis Pharma AG, QLT Inc | Mean BCVA: 20/80 92% subfoveal lesion(s) | Good
VIP Study Group, 2001 ^136^ Photodynamic therapy of subfoveal choroidal neovascularization in pathologic myopia with verteporfin. 1-year results of a randomized clinical trial—VIP report no. 1 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Novartis Ophthalmics AG, QLT Inc | Mean BVCA: 20/50+1 83.4% subfoveal lesion(s) | Good
VISION Clinical Trial Group, 2006 ^166^ Pegaptanib sodium for neovascular age-related macular degeneration: two-year safety results of the two prospective, multicenter, controlled clinical trials | Randomized but method not described | Can't tell | Yes | Yes | Yes | No | Yes | Yes | No | No | Eyetech Pharmaceuticals and Pfizer | Mean visual acuity 51 to 53 | Fair

Abbreviations: BCVA = best corrected visual acuity, MPS = Macular Photocoagulation Study Group, NA = not applicable, NR = not reported, SD = standard deviation.

Evidence Table C7. Treatment - Systematic Reviews

Study, Year, Title | Aims | Databases searched; Literature search dates; Other data sources | Eligibility criteria | Patients/trials | Characteristics of identified articles: study designs | Characteristics of identified articles: populations | Characteristics of identified articles: interventions | Main efficacy outcome | Main efficacy results | Harms results | Conclusion | Quality score
ARMD (Dry)
Evans et al, 2008 ^43^ Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration | To assess the effects of antioxidant vitamin or mineral supplementation, alone or in combination, on the progression of ARMD | CCRCT, MEDLINE, EMBASE, National Research Register through 2007, PubMed in process through 24 January 2006, AMED 1985-January 2006, SIGLE 1980-March 2005 | RCTs of antioxidant vitamins or mineral supplementation, alone or in combination, vs placebo or no treatment in ARMD patients | 9 trials (18 publications) Primary publications: Richer 1996 - AMDSG (n=71); Age-Related Eye Disease Study Research Group 2001 - AREDS (n=3640); Holz 1993 (n=58); Kaiser 1995 (n=20); Newsome 1988 (n=174); Stur 1996 (n=112); Garrett 1999 - VECAT study (n=1204); Richer 2004 - LAST study (n=90); Wang 2004 (n=400); total n=5769 | 9 RCTs | Mean age: 70 years 55% female Varying degree of ARMD by trial (mild to advanced, including AREDS, the largest trial) | 3 trials: zinc 200 mg QD vs placebo 2 trials: broad-spectrum antioxidant compound vs placebo 1 trial: vitamin E 500 mg QD vs placebo 1 trial: zinc 80 mg QD vs antioxidant combination vs zinc + antioxidants vs placebo 1 trial: lutein 10 mg QD v lutein + broad-spectrum antioxidant 1 trial: zinc oxide 80 mg QD, vitamin C, vitamin E vs placebo | Change in vision (Secondary outcome: disease progression) | All comparisons Any multivitamin or antioxidant vs placebo: Change in visual acuity - defined as a loss of 3 or more lines (15 or more letters) on a logMAR chart (AREDS, Newsome 1988, VECAT; I^2^=27.7%) Random effects model: pooled OR 0.83 (CI 0.63 to 1.09; p=0.18); Fixed effects model: pooled OR 0.81 (CI 0.67 to 0.98; p=0.03) Mean difference visual acuity (AMDSG, Kaiser 1995, Newsome 1988, Stur 1996, LAST; I^2^=0%): pooled SMD 0.02 (CI -0.21 to 0.26) ARMD progression as a dichotomous variable: (AREDS, Holz 1993, Stur 1996. VECAT; I^2^=64.2%) OR range: 0.50 to 2.31; no pooled analysis due to heterogeneity of studies ARMD progression as a continuous variable (AMDSG): mean difference -0.06 (CI -0.62 to 0.50) Individual comparisons Multivitamin supplements vs placebo (AREDS, Kaiser 1995, Richer 1996, Richer 2004) Change in visual acuity - defined as a loss of 3 or more lines (15 or more letters) on a logMAR chart (AREDS): OR 0.77 (CI 0.62 to 0.96) vs placebo Mean difference visual acuity (Kaiser 1995, AMDSG, LAST; I^2^=0%): pooled SMD 0.16 (CI -0.19 to 0.51) ARMD progression as a dichotomous variable (AREDS): adjusted OR 0.68 (CI 0.53 or 0.87) ARMD progression as a continuous variable (AMDSG): mean difference -0.06 (CI -0.62 to 0.50) Vitamin E vs placebo (VECAT) Change in visual acuity - defined as a loss of 3 or more lines (15 or more letters) on a logMAR chart: OR 1.05 (CI 0.70 to 1.57) ARMD progression: OR 0.11 (CI 0.80 to 1.55) Zinc vs placebo (AREDS, Holz 1993, Newsome 1988, Stur 1996) Change in visual acuity - defined as a loss of 3 or more lines (15 or more letters) on a logMAR chart (AREDS, Newsome 1988; I^2^=0%): OR 0.81 (CI 0.66 to 0.99) Mean difference visual acuity (Newsome 1988, Stur 1996; I^2^=56.6%): results somewhat inconsistent but no statistically significant difference found between treatment and control groups in both trials ARMD progression as a dichotomous variable (AREDS, Holz 1993, Stur 1996; I^2^=29.0%): pooled OR 0.73 (0.58–0.93) Lutein vs placebo (LAST): Mean difference visual acuity: 0.04 (-0.15 to 0.23) | None reported | Limited evidence, based primarily on AREDS, suggests a benefit in the use of antioxidant vitamins and minerals in slowing ARMD progression (risk reduction ~20–25%.) The AREDS population was relatively well-nourished at the trial's initiation and this may have had some effect on the trial results. Prolonged antioxidant use had been found to be harmful in some other populations (e.g. smokers) | Good
Evans et al, 2008 ^126^ Ginkgo biloba extract for age-related macular degeneration | To determine the effect of ginkgo biloba extract on the progression of AMD | CCRCT (Quarter 4, 2005), MEDLINE (1966-January 2006, week 3), EMBASE (1980-January 2006), SIGLE (1980-2005/03), AMED (1985-January 2006), NRR (2005, Issue 4); reference lists, Science Citation Index; expert recommendation | RCTs of ginkgo biloba vs control in AMD patients | 2 trials: Fies 2002 (n=99); Lebuisson 1986 (n=20); total n=119 pts | 2 RCTs: 160 mg QD gingko biloba vs placebo (1 trial); 240 mg QD gingko biloba v 60 mg QD gingko biloba (1 trial) | 1 trial: eye clinic outpatients <55 years w/ARMD, mean age 67 years, gender NR; 1 trial: eye clinic outpatients >59 years, mean age 76 years, 27% male | Gingko biloba extract EGb 761, doses 60–160 mg QD; placebo | Primary outcomes: number of patients with disease progression and/or new visual loss due to AMD; QOL | Gingko biloba 160 mg QD vs placebo (1 trial; n=20): Change in visual acuity: WMD 1.70 (CI 1.21 to 2.19) Clinical improvement: OR 36.00 (2.72 to 476.28) Gingko biloba 60 mg QD vs 240 mg QD (1 trial; n=99): Mean visual acuity: WMD 0.05 (CI -0.03 to 0.13) >0.2 improvement in visual acuity score: OR 2.29 (CI 0.90 to 5.80) | No serious AEs reported in either trial (headache, blood in stool and abdominal pain reported in 3/99 patients) | There is inadequate evidence from 2 small, short-term trials to draw conclusions regarding the effect of gingko biloba on ARMD progression. There may be harms associated with gingko biloba use, but they too have been inadequately reported | Good
ARMD (Wet)
Meads et al, 2003 ^133^ Clinical effectiveness and cost-utility of photodynamic therapy for met age-related macular degeneration: a systematic review and economic evaluation | To establish the clinical and cost-effectiveness of photodynamic therapy for neovascular AMD | Cochrane Library (2001, Issue 3), MEDLINE (1993-Aug 2001), EMBASE (1993-Aug 2001), Science Citation Index (1993-2001); health technology assessment web sites; internet sites of verteporfin manufacturers; reference lists; industry submissions | RCTS of photodynamic therapy vs no treatment or laser treatment in patients with wet ARMD | 2 trials: Treatment of Age-related Macular Degeneration with Photodynamic Therapy Study Group - TAP 1999 (n=609); Verteporfin in Photodynamic Therapy Study Group - VIP 2001 (n=2001); total n=2610 pts | 2 RCTs: verteporfin IV + laser vs placebo IV + laser | ARMD patients 2 trials: mean age 75 years; 98% white 1 trial: NR Baseline visual acuity in treated eye: TAP - 53 letters; VIP - 46 letters | IV verteporfin 6 mg/m2 + cold laser vs placebo + cold laser | Visual acuity changes | Results not pooled. TAP Loss of >15 letters (3 lines) at 24 months: 47.0% verteporfin vs 62.3% placebo; RR 0.75 (CI 0.65 to 0.88) Loss of >30 letters (6 lines) at 24 months: 18.2% verteporfin vs 30.0% placebo; RR 0.61 (CI 0.45 to 0.81) Proportion of pts with visual acuity of <34 letters at 24 months: 41.0% verteporfin vs 55.1% placebo; RR 0.75 (CI 0.63–0.88) VIP Loss of >15 letters (3 lines) at 24 months: 54.0% verteporfin vs 67% placebo; RR 0.81 (CI 0.68 to 0.96) Loss of >30 letters (6 lines) at 24 months: 30% verteporfin vs 47% placebo; RR 0.63 (CI 0.48 to 0.83) Proportion of pts with visual acuity of <34 letters at 24 months: this outcome not reported. | Results not pooled TAP mortality at 24 months: 3.2% verteporfin vs 3.9% placebo; RR 0.84 (0.35–1.99) VIP mortality at 24 months: 1.8% verteporfin vs 2.6% placebo; RR 0.68 (CI 0.15 to 2.97) | Photodynamic therapy is effective at preventing further visual loss due to AMD, although this conclusion is based largely on the results of the TAP trial. With the addition of a cost effectiveness analysis included in this review, the authors concluded that there is a need for further research on this topic. | Good
Vedula et al, 2008 ^142^ Antiangiogenic therapy with anti-vascular endothelial growth factor modalities for neovascular age-related macular degeneration | To investigate the effects of anti-vascular endothelial growth factor (anti-VEGF) modalities for treating endovascular ARMD | CCRCT, MEDLINE, EMBASE, LILACs through February 2008; hand search of Association for Research in Vision & Ophthalmology meeting abstracts | RCTs of anti-VEGF modalities in ARMD | 5 trials (15 publications) Primary publications: Brown 2006 - ANCHOR Trial (n=423); Macugen 2007 - EOP 1003 Trial (n=578); Leys 2007 - EOP 1004 Trial (n=612); Heier 2006 - FOCUS Trial (n=162); Rosenfeld 2006 - MARINA Trial (n=716) | RCTs - 2 trials: pegaptanib 0.3, 1.0 or 3.0mg vs sham injection 1 trial: ranibizumab 0.3 or 0.5mg + sham verteporfin PDT therapy vs sham ranibizumab + active verteporfin PDT therapy 1 trial: 0.3 or 0.5mg ranibizumab vs sham injection 1 trial: 0.5mg ranibizumab + verteprofin PDT vs verteporfin PDT only | Mean age range 73–78 years 46–69% female Diagnosis of ARMD | Pegaptanib 0.3, 1.0 or 3.0mg Ranibizumab 0.3 or 0.5mg Verteporfin PDT sham injection/sham PDT | Visual acuity after at least 1 year follow up | Change in visual acuity (% of patients losing ≥3 lines of acuity at 1 year) Pegaptanib (all doses) vs sham: RR 0.71 (CI 0.60 to 0.84); NSD for 3.0mg dose vs sham; NNT 6.67 0.3mg dose, 6.25 1.0mg dose, 14.28 3.0mg dose Ranibizumab (both doses) vs sham: RR 0.14 (CI 0.08 to 0.25); NNT 3.13 (both doses) Blindness Pegaptanib RR 0.69 (CI 0.59 to 0.82) Ranibizumab RR 0.28 (CI 0.21 to 0.37) Quality of life - Mean change in NEI-VFQ scores at 2 years follow-up ANCHOR Trial: 5.9 ranibizumab 0.3mg vs 8.1 ranibizumab 0.5mg vs 2.2 verteprofin MARINA Trial: 4.8 ranibizumab 0.3mg vs 4.5 0.5mg ranibizumab vs -6.4 sham injection | Ranibizumab: similar rates of serious AEs including mortality Unpublished data from SAILOR Trial reported by the drug's manufacturer showed significantly higher stroke risk w 0.5mg dose relative to 0.3mg dose(p=0.02; no sham control in this trial) Pegaptanib: Serious ocular AEs (endophthalmitis, retinal detachment, traumatic cataract) in tx groups, none in sham group | Both interventions effective a reducing visual acuity loss and progression to blindness with improved QoL outcomes | Good
Virgili et al, 2008 ^45^ Laser photocoagulation for age-related macular degeneration | To examine the effect of laser photocoagulation on neovascular (wet) ARMD | CCRCT, MEDLINE, EMBASE, LILACS, National Research Register (NRR), ZETOC through March 2007 | RCTs of laser photocoagulation for neovascular ARMD | 15 trials (34 publications) Primary publications: Arnold 1997; Canadian Ophthalmology Study Group 1993 (n=55); Bressler 1996 (n=100); Canadian Ophthalmology Study Group 1993 (n=191); Cardillo 1993 (n=23); Coscas 1983 (n=60); Coscas 1991 (n=160); Duch Mestres 1993 (n-41); Moorfields 1982 (n=128); Macular Photocoagulation Study Group - MPS Argon Extra 1982 (n=224); Macular Photocoagulation Study Group - MPS Krypton Juxta 1990 (n=496); Macular Photocoagulation Study Group - MPS Subf. New 1991 (n=371); Macular Photocoagulation Study Group - MPS Subf. Recurrent 1991 (n=206); Bressler 2000 & Submacular Surgery Trials Research Group 2000 - SST 2000 (n=70); Versteeg-Tijmes 1982 (n=13, excluding 13 non-ARMD eyes); Yassur 1982 (n=96) | RCTSs - various laser treatments vs no or sham treatment | Mean age: NR All participants had diagnosis of ARMD, although this was defined in only 5 studies; CNV location: subfoveal (7 studies); extrafoveal and/or juxtafoveal (8 studies) | 12 studies: Photocoagulation vs no treatment 1 study: photocoagulation vs surgery 1 study: argon vs krypton laser wavelength 1 study: argon vs dye red laser wavelength | Changes in visual acuity and contrast sensitivity (Secondary outcomes: reading ability, performance in vision-related tasks, QOL) | Direct photocoagulation vs no treatment Visual acuity at 3 months: NNH 20 (CI 13 to 100) Reading ability at 3 years: NNT 6 (CI 3 to 33); at 5 years: NNT 7 (CI 4 to 33) Perifoveal photocoagulation of subfoveal CNV Visual acuity, loss of 6 lines or more at 2 years*: NNT 3 (CI 2 to 8) *only timepoint with SS difference b/t treatment and control, although photocoagulation was favored for other timepoints Grid photocoagulation of subfoveal CNV Visual acuity, loss of 2 or more lines: RR 1.83 (CI 1.10 to 3.05); NNT 5 (CI 3 to 20) Photocoagulation vs surgery No SS difference between treatments, although surgery was favored for visual acuity and QOL outcomes Argon vs krypton lasers No difference between argon and krypton at 2 years in visual acuity changes | None reported | Photocoagulation is effective for certain types of ARMD (extrafoveal CNV). For juxta-or sub- foveal CNV patients, the benefit of laser photocoagulation is less clear, | Good
Wormald et al, 2008 ^134^ Photodynamic therapy for neovascular age-related macular degeneration | To examine the effects of photodynamic therapy in the treatment of ARMD | CCRCT, MEDLINE EMBASE through March 2007; Science Citation Index (no date specified); expert recommendation | RCTs of photodynamic therapy (vs another treatment, placebo or no treatment) in ARMD patients | 3 trials (7 publications) Primary publications: Treatment of Age-related Macular Degeneration with Photodynamic Therapy Study Group - TAP 1999 (n=609); Visudyne in minimally classic choroidal neovascularisation study - VIM 2005 (n=117); Verteporfin in Photodynamic Therapy Study Group - VIP 2001 (n=2001); total n=1065 pts | 3 RCTs: verteporfin IV + laser vs placebo IV + laser | ARMD patients 2 trials: mean age 75 years; 98% white 1 trial: NR | IV verteporfin (2 trials: 6 mg/m2; 1 trial dose NR) + cold laser vs placebo + cold laser | Prevention of visual loss, based on visual acuity | Loss of >3 lines of visual acuity at 24 months: pooled RR (2 trials: TAP, VIP) 0.78 (CI 0.7–0.87); risk ratio reduction 0.22 (CI 0.13 to 0.30); NNT: 7 (population: patients with subfoveal choroidal neovascularization with baseline visual acuity 20/40-20/200) Loss of >6 lines of visual acuity at 24 months: pooled RR (2 trials: TAP, VIM) 0.60 (CI 0.49–0.73); risk ratio reduction 0.40 (CI 0.27–0.51); NNT: 7 (population: patients with subfoveal choroidal neovascularization with baseline visual acuity 20/40-20/200) Mean number of lines of vision lost at 24 months (1 trial: TAP): 2.7 lines verteporfin vs 1.2 control; mean difference 1.2 (p<0.001) No QOL outcomes reported | Acute severe visual acuity decrease (within 13 days of tx): Absolute risk difference 0.01 (CI 0.01 to 0.03); NNH 30 (range 30–100) | Photodynamic therapy is effective in preventing further visual loss due to AMD although the effect size is unclear. | Good
Cataracts
Powe et al, 1994 ^91^ Synthesis of the literature on visual acuity and complications following cataract extraction with intraocular lens implantation | To define the effectiveness and risks of cataract surgery | MEDLINE 1975-April 1991; reference lists | Original studies published between 1975 and April, 1991 with primary data on standard extracapsular extraction or phacoemulsification with posterior chamber IOL implantation or published between 1980 and April 1991 on intracapsular cataract extraction with flexible anterior chamber IOL implantation; visual acuity outcomes or complications were reported; English language | 83 single-arm observational studies and 7 cohort studies Median n=231 (17 to 22,791) | 90 non-RCTs | Mean age: 71 years 58% female (reported in 23 studies) | 22 studies: phacoemulsification; 58 studies: extracapsular extraction; 1 study: intracapsular extraction; 18 studies: mixed phacoemulsification and extracapsular extraction | Proportion of eyes with 20/40 or better visual acuity post-surgery | Pooled % of eyes with 20/40 acuity or better: 95.5% (CI 95.1% to 95.9%) in pts with no ocular comorbidities and 87% (CI 89.3% to 90.2%) for all eyes | Pooled rates - % (CI):Endophalmitis 0.13 (0.09 to 0.17) Bullous keratopathy 0.3 (0.2 to 0.4) Malposition/dislocation of IOL 1.1 (0.9 to 1.2) Clinical cystoid macular edema 1.4 (1.2 to 1.6)Angi-ographic cystoid macula edema 3.5 (2.9 to 4.0) Retinal detachment 0.7 (0.6 to 0.8) Posterior capsular opaci-fication 19.7 (19.1 to 20.3) | Cataract surgery yields excellent visual acuity and is relatively safe regardless of method of surgical extraction | Good
Schaumberg et al, 1998 ^163^ A systematic overview of the incidence of posterior capsule opaci-fication | To obtain an estimate of the incidence of posterior capsule opaci-fication (PCO) and to explore factors that may influence its development | MEDLINE 1979-1996; reference lists | Studies of PCO published between 1979 and 1996 reporting total sample size, length of follow-up and postoperative rate of PCO; English language | 49 studies (design NR); total n=NR | 49 studies | NR | 27 studies: extracapsular extraction; 9 studies: phacoemulsification; 13 studies: mixed extracapsular extraction and phacoemulsification | Safety outcome: estimate of PCO occurrence 1, 3 and 5 years post-surgery (safety study, no efficacy outcomes) | NR | Pooled rate, incidence of PCO: 1 year: 11.8% (9.3%–14.3%) 3 years: 20.7% (16.6%–24.9%) 5 years: 28.4% (18.4%–38.4%) | Visually significant PC0 develops in more than 25% of patients undergoing extracapsular extraction or phacoemulsification with IOL within 5 years of surgery | Fair
Taban et al, 2005 ^164^ Acute endophthalmitis following cataract surgery | To determine reported incidence of acute endophthalmitis following cataract extraction and to explore possible contributing factors | Cochrane (database not specified); MEDLINE 1963-March 2003; reference lists; textbook hand search; conference proceedings and abstracts | Studies published in English of humans; primary or secondary cataract surgery with or without IOL; included post-surgery endophthalmitis outcomes | 215 studies (design NR); total n=NR | 215 studies | NR | NR | Incidence of acute endophthalmitis (safety study, no efficacy outcomes) | NR | Pooled rate, incidence of endophthalmitis: 0.128% Rate 1963-1999: 0.109% Rate 2000-2003: 0.265% (RR 2.44. CI 2.27 to 2.61) | Incidence of endophthalmitis associated with cataract extraction has increased over the last decade and may be linked to the increasing use of sutureless clear corneal incisions | Fair
Uncorrected refractive error
Murray et al, 2005 ^85^ A systematic review of the safety and efficacy of elective photorefractive surgery for the correction of refractive error | To systematically review the evidence for safety and efficacy of PRK, LASEK and LASIK for the correction of myopia, hyperopia and astigmatism | MEDLINE, MEDLINE Extra, EMBASE, BIOSIS, Science Citation Index, Cochrane Controlled Trials Register, National Research Register Clinical Trials, Current Controlled Trials, FDA Premarket Approval (PMA) Database Web of Science Proceedings, Conference Papers Index, Zetoc, Association for Research in Vision and Ophthalmology (ARVO) Abstracts Database, American Society of Cataract and Refractive Surgery-American Society of Ophthalmic Administrators (ASCRS-ASOA) Abstracts Database; 2000-2005 | Studies published from 2000 onward; prospective studies with at least 300 eyes; retrospective case series with at least 500 eyes; RCTs comparing LASIK and PRK, LASIK and LASEK, and PRK and LASEK | LASIK: 4 trials, 64 case series (73 publications); LASEK: 14 RCTs (16 publications), 26 case series (40 publications); PRK: 9 RCTs, 40 case series | 27 RCTs; 130 case series | Adults undergoing photorefractive surgery for correction of myopia, hyperopia or astigmatism | Studies of primary treatment with any type of excimer laser used to perform PRK, LASEK, and LASIK for refractive correction of myopia, hyperopia or astigmatism | Achievement of the intended visual outcome, uncorrected visual acuity, stability of visual result and need for further refractive surgery Safety outcomes: incidence of serious complications and unintended consequence | Uncorrected visual acuity of 20/20 or better in myopia: PRK 70%, LASEK 62%, LASIK 64% 20/40 or better: PRK 92%, LASEK 92% and LASIK 94% Highly myopic eyes achieved High myopia at baseline, 20/20: PRK14% and LASIK 44% compared with Low myopia at baseline: PRK 76% and LASIK 81% Correction of myopia/myopic astigmatism, median across all 3 treatments: 68% to 75% of eyes achieving within 0.5 D of their intended correction; 86% to 92% of eyes achieved within 1.0 D. Correction of hyperopia: 61% of eyes achieved within 0.5 D of intended correction after PRK and LASIK; 79% and 88% for PRK and LASIK respectively within 1.0 D. | Ectasia (5 LASIK studies): median rate 0.2% (range 0% to 0.87%) Loss of ≥2 lines of BSCVA in myopia: PRK 0.5%, LASEK 0% and LASIK 0.6% Loss of ≥2 lines of BSCVA in hyperopia: PRK 7.0%, LASIK 3.5% | The safety and efficacy of photorefractive surgery should be considered against the alternative methods of correction; adverse events occur rarely from a statistical standpoint. | Good
Virgili et al, 2008 ^39^ Reading aids for adults with low vision | To assess the effects of reading aids for adults with low vision | CCRCT (Cochrane Central Register of Controlled Trials), MEDLINE, EMBASE, SIGLE, LILACS (Latin American and Caribbean Health Science Literature Database) and IndMed through July 2006; Science Citation Index; hand search British Journal of Visual Impairment 1983-1999 and Journal of Visual Impairment and Blindness 1976-1991 | RCTs or quasi-RCTs comparing any device to aid in low vision correction to another | 9 trials: Culham 2004 (n=20); Eperjesi 2004 (n=12); Goodrich 2001 (n=22); Kleweno 2001 (n=13); Ortiz 1999 (n=10); Peterson 2003 (n=70); Smith 2005 (n=243); Spitzberg 1995 (n=39); Stelmack 1991 (n=37) | Within-subject design (8) and one parallel group RCT | Patients with low vision due to a variety of causes, including ARMD | Magnifiers, CCTV (stand-mounted and hand-held); prism spectacles | Increase in reading speed | Reading speed: prism spectacles were no better than conventional spectacles in the single study comparing them; for other interventions, there was no difference in reading speed among the treatments although this could have been due to problematic design and reporting among the included studies | None reported | No evidence supports any particular low vision reading aid over another; the studies included in the SR were of questionable quality and potential biased | Good

Abbreviations: AREDS = age-related eye disease study, ARMD = age-related macular degeneration, CI = confidence interval, CNV = choroidal neovascularisation, IOL = intraocular lenses, LASIK = laser assisted in situ keratomileusis, LASEK = laser assisted sub-epithelial keratomileusis, NEI-VFQ = national eye institute visual functioning questionnaire, NNH = number needed to harm, NR = not reported, PCO = posterior capsule opacification, PDT = photodynamic therapy, PRK = photorefractive keratectomy, RCT = randomized controlled trials, RR = relative risk, SR = systematic review, VECAT =vitamin E, cataract and age-related maculopathy study, VEGF = vascular endothelial growth factor.

Evidence Table C8. Quality Ratings of Treatment Systematic Reviews

Study, Year | Search dates | Search methods reported | Comprehensive search | Inclusion criteria reported | Selection bias avoided | Validity criteria reported | Validity assessed appropriately | Methods used to combine studies reported | Findings combined appropriately | Conclusions supported by data | Quality score
Evans et al, 2008 ^43^ Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration | Up to August 2007 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Evans et al, 2008 ^126^ Ginkgo biloba extract for age-related macular degeneration | Up to January 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Meads et al, 2003 ^133^ Clinical effectiveness and cost-utility of photodynamic therapy for met age-related macular degeneration: a systematic review and economic evaluation | Up to August 2001 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Murray et al, 2005 ^85^ A systematic review of the safety and efficacy of elective photorefractive surgery for the correction of refractive error | Up to 2006 | Yes | Yes | Yes | Can't tell | Yes | Yes | Yes | Yes | Yes | Good
Powe et al, 1994 ^91^ Synthesis of the literature on visual acuity and complications following cataract extraction with intraocular lens implantation | Up to April 1991 | Yes | Yes | Yes | Can't tell | Yes | Yes | Yes | Yes | Yes | Good
Schaumberg et al, 1998 ^163^ A systematic overview of the incidence of posterior capsule opacification | Up to 1996 | Partial | Can't tell | Yes | Can't tell | No | No | Yes | Yes | Yes | Fair
Taban et al, 2005 ^164^ Acute endophthalmitis following cataract surgery | Up to March 2007 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Fair
Vedula et al, 2008 ^142^ Antiangiogenic therapy with anti-vascular endothelial growth factor modalities for neovascular age-related macular degeneration | Up to February 2008 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Virgili et al, 2008 ^45^ Laser photocoagulation for age-related macular degeneration | Up to March 2007 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Virgili et al, 2008 ^39^ Reading aids for adults with low vision | Up to July 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Wormald et al, 2008 ^134^ Photodynamic therapy for neovascular age-related macular degeneration | Up to March 2007 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good