# Appendix B. Detailed Methods

## Appendix B1. Vision Search Strategies

### Diagnostic Accuracy Searches

Database: Ovid MEDLINE(R)

1 exp Vision/
2 exp Vision Disorders/
3 exp Mass Screening/
4 exp Geriatric Assessment/
5 1 or 2
6 3 and 5
7 limit 6 to “all aged (65 and over)”
8 4 and 5
9 7 or 8
10 screen$.mp.
11 exp Vision Tests/
12 10 and 11
13 limit 12 to “all aged (65 and over)”
14 exp Refractive Errors/
15 (presbyop$ or myop$ or astigmati$ or hyperop$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
16 14 or 15
17 exp Macular Degeneration/
18 (degenerat$ adj3 macula$).mp.
19 armd.mp.
20 or/17-19
21 exp Cataract/
22 cataract.mp.
23 21 or 22
24 16 or 20 or 23
25 24 and (3 or 4 or 12)
26 limit 25 to “all aged (65 and over)”
27 7 or 13 or 26
28 limit 27 to english language
29 limit 27 to abstracts
30 28 or 29
31 exp “Sensitivity and Specificity”/
32 5 or 11 or 24
33 31 and 32
34 limit 33 to “all aged (65 and over)”
35 limit 34 to english language
36 limit 34 to abstracts
37 35 or 36
38 37 not 30
39 from 38 keep 1-579

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 exp Vision/
2 exp Vision Disorders/
3 exp Mass Screening/
4 screen$.mp.
5 exp Refractive Errors/
6 (presbyop$ or myop$ or astigmati$ or hyperop$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7 exp Macular Degeneration/
8 (degenerat$ adj3 macula$).mp.
9 armd.mp.
10 exp Cataract/
11 cataract.mp.
12 (1 or 2) and (3 or 4)
13 or/5-11
14 and (3 or 4)
15 12 or 14
16 sensitivity.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
17 specificity.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
18 accura$.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
19 (16 and 17) or 18
20 15 and 19
21 (child$ or pediatri$ or infant$ or neonat$).ti.
22 20 not 21
23 from 22 keep 1-44

Database: EBM Reviews - Cochrane Database of Systematic Reviews

1 cataract$.ab.
2 macular degeneration$.ab.
3 refractive error$.ab.
4 (presbyop$ or astigmati$ or myop$ or hyperop$).ab.
5 (vision or visual).ab.
6 or/1-4
7 screen$.mp. [mp=title, abstract, full text, keywords, caption text]
8 accura$.mp. [mp=title, abstract, full text, keywords, caption text]
9 sensitivity.mp. [mp=title, abstract, full text, keywords, caption text]
10 specificity.mp. [mp=title, abstract, full text, keywords, caption text]
11 (Cochrane Eyes and Vision Group).mp. [mp=title, abstract, full text, keywords, caption text]
12 5 and 6
13 7 and 12
14 or/8-10
15 13 and 14
16 11 and 15
17 (child$ or pediatri$ or infant$ or neonat$).ti.
18 16 not 17
19 (glaucoma or diabet$).ti.
20 18 not 19
21 from 20 keep 1-14

### Screening Searches

Database: Ovid MEDLINE(R)

1 exp Vision/
2 exp Vision Disorders/
3 exp Mass Screening/
4 exp Geriatric Assessment/
5 1 or 2
6 3 and 5
7 limit 6 to “all aged (65 and over)”
8 4 and 5
9 7 or 8
10 screen$.mp.
11 exp Vision Tests/
12 10 and 11
13 limit 12 to “all aged (65 and over)”
14 exp Refractive Errors/
15 (presbyop$ or myop$ or astigmati$ or hyperop$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]
16 14 or 15
17 exp Macular Degeneration/
18 (degenerat$ adj3 macula$).mp.
19 armd.mp.
20 or/17-19
21 exp Cataract/
22 cataract.mp.
23 21 or 22
24 16 or 20 or 23
25 24 and (3 or 4 or 12)
26 limit 25 to “all aged (65 and over)”
27 7 or 13 or 26
28 limit 27 to english language
29 limit 27 to abstracts
30 28 or 29
31 from 30 keep 1-498

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 ((vision or visual) adj5 screen$).mp.
2 (presbyop$ or myop$ or astigmati$ or hyperop$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3 (macula$ adj3 degenerat$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4 armd.mp.
5 cataract$.mp.
6 screen$.mp.
7 or/2-5
8 6 and 7
9 1 or 8
10 (elder$ or old or aged).mp.
11 9 and 10
12 (child$ or pediatri$ or infant or neonat$).mp.
13 11 not 12
14 from 13 keep 1-95

Database: EBM Reviews - Cochrane Database of Systematic Reviews

1 ((vision or visual) adj5 screen$).mp.
2 (presbyop$ or myop$ or astigmati$ or hyperop$).mp. [mp=title, abstract, full text, keywords, caption text]
3 (macula$ adj3 degenerat$).mp. [mp=title, abstract, full text, keywords, caption text]
4 armd.mp.
5 cataract$.mp.
6 screen$.mp.
7 or/2-5
8 6 and 7
9 1 or 8
10 (elder$ or old or aged).mp.
11 9 and 10
12 (child$ or pediatri$ or infant or neonat$).mp.
13 11 not 12
14 from 13 keep 1-28

### Treatment Searches

Database: Ovid MEDLINE(R)

1 exp Vision Disorders/nu, pc, dh, dt, rt, rh, su, th [Nursing, Prevention & Control, Diet Therapy, Drug Therapy, Radiotherapy, Rehabilitation, Surgery, Therapy]
2 exp Cataract/nu, dh, pc, dt, rt, rh, th [Nursing, Diet Therapy, Prevention & Control, Drug Therapy, Radiotherapy, Rehabilitation, Therapy]
3 exp Macular Degeneration/nu, pc, dh, dt, rt, rh, su, th [Nursing, Prevention & Control, Diet Therapy, Drug Therapy, Radiotherapy, Rehabilitation, Surgery, Therapy]
4 exp Refractive Errors/nu, pc, dt, rt, rh, th [Nursing, Prevention & Control, Drug Therapy, Radiotherapy, Rehabilitation, Therapy]
5 Presbyopia/pc, dt, rt, rh, su, th [Prevention & Control, Drug Therapy, Radiotherapy, Rehabilitation, Surgery, Therapy]
6 or/1-5
7 exp Vital Statistics/
8 exp “Quality of Life”/
9 6 and (7 or 8)
10 exp Time Factors/
11 exp Prognosis/
12 10 and 11
13 6 and 12
14 9 or 13
15 limit 14 to “all aged (65 and over)”
16 limit 15 to english language
17 limit 15 to abstracts
18 16 or 17
19 from 18 keep 1-365

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 exp Vision/
2 exp Vision Disorders/
3 exp Refractive Errors/
4 (presbyop$ or myop$ or astigmati$ or hyperop$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5 exp Macular Degeneration/
6 (degenerat$ adj3 macula$).mp.
7 armd.mp.
8 exp Cataract/
9 cataract.mp.
10 1 or 2
11 or/3-9
12 10 and 11
13 treatment$.ab.
14 12 and 13
15 (child$ or pediatri$ or infant$ or neonat$).ti.
16 14 not 15
17 (glaucoma or diabet$).ti.
18 16 not 17
19 (geriatri$ or aged or elderly or old).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
20 18 and 19
21 from 20 keep 1-306

Database: EBM Reviews - Cochrane Database of Systematic Reviews

1 cataract$.ab.
2 macular degeneration$.ab.
3 refractive error$.ab.
4 (presbyop$ or astigmati$ or myop$ or hyperop$).ab.
5 or/1-4
6 (Cochrane Eyes and Vision Group).mp. [mp=title, abstract, full text, keywords, caption text]
7 5 and 6
8 (child$ or pediatri$ or infant or neonat$).ab.
9 7 not 8
10 (glaucoma or diabet$).ti.
11 9 not 10
12 from 11 keep 1-22

## Appendix B2. Inclusion and Exclusion Criteria

### All Key Questions

#### Populations

[underlined: Include] : Asymptomatic adults ages 65 years and older (if insufficient data for adults 65 years and older will include studies enrolling adults in general) with vision impairment (visual acuity worse than 20/40 but better than 20/200), uncorrected refractive errors (due to myopia, hyperopia, astigmatism, or presbyopia), age-related macular degeneration (ARMD), or cataracts

[underlined: Exclude] : Persons with known vision impairment, cataracts, ARMD, diabetes, or glaucoma

#### Languages

[underlined: Include] : English language

### Key Questions 1 & 2

#### Interventions

[underlined: Include] : Vision screening performed in primary care or eye specialty settings, including multi-component screening with a distinct vision screening component

[underlined: Exclude] : Community-based or in-home interventions

#### Study designs

[underlined: Include] : Randomized controlled trials and controlled observational studies

#### Outcomes

[underlined: Include] : Visual acuity; quality of life, functional capacity (including ability to drive and driving outcomes), other measures of morbidity; mortality

[underlined: Exclude] : Falls, reading speed and other tests of vision function

### Key Question 3

#### Interventions

[underlined: Include] : Screening questions or diagnostic tests used for vision screening in primary care settings (e.g., Snellen eye chart, other visual acuity charts, physical examination, fundoscopic examination performed by a primary care clinician)

[underlined: Exclude] : Diagnostic tests used for vision screening in eye specialty settings (including fundoscopic examination performed by an eye professional and specialized diagnostic testing)

#### Study designs

[underlined: Include] : Studies evaluating diagnostic accuracy of a screening question or diagnostic test compared to a reference standard

#### Outcomes

[underlined: Include] : Sensitivity, specificity, positive and negative predictive values, areas under the receiver operating curve, other measures of diagnostic test accuracy

### Key Questions 4 & 5

#### Interventions

[underlined: Include] : Corrective lenses (eyeglasses and contact lenses), reading aids, photorefractive surgery (LASIK, LASEK, PRK), vitamins and antioxidants, laser therapy, photodynamic therapy, vascular endothelin growth factor inhibitors

#### Study designs

[underlined: Include] : Randomized controlled trials, controlled observational studies if insufficient evidence from randomized trials

#### Outcomes

[underlined: Include] : Visual acuity; quality of life, functional capacity (including ability to drive and driving outcomes), other measures of morbidity; mortality

[underlined: Exclude] : Reading speed and other tests of vision function

## Appendix B4. Excluded Studies

### Contextual Only

Arias L, Garcia-Arumi J, Ramon JM, et al. Photodynamic therapy with intravitreal triamcinolone in predominantly classic choroidal neovascularization: one-year results of a randomized study. Ophthalmology. 2006;113(12):2243-2250. [pmid: 16996600].
Bergman B, Nilsson-Ehle H, Sjostrand J. Ocular changes, risk markers for eye disorders and effects of cataract surgery in elderly people: a study of an urban Swedish population followed from 70 to 97 years of age. Acta Ophthalmol Scand. 2004;82(2):166-174. [pmid: 15043535].
Brannan S, Dewar C, Sen J, et al. A prospective study of the rate of falls before and after cataract surgery. Br J Ophthalmol. 2003;87(5):560-562. [pmid: 12714392].
Brenner M, Curbow B, Javitt J, et al. Vision change and quality of life in the elderly; response to cataract surgery and treatment of other chronic ocular conditions. Arch Opthalmol. 1993;111:680-685.
Bressler NM, Bressler SB, Childs AL, et al. Surgery for hemorrhagic choroidal neovascular lesions of age-related macular degeneration: ophthalmic findings: SST report no. 13. Ophthalmology. 2004;111(11):1993-2006. [pmid: 15522364].
Canadian Task Force guideline. Canadian Task Force on Preventive Health Care. Prepared by Dr. Christopher Patterson. Screening for visual impairment in the elderly. 1994.: Available at: http://www.ctfphc.org/Tables_printable/Ch78tab.htm; Accessed: May 2008.
Childs AL, Bressler NM, Bass EB, et al. Surgery for hemorrhagic choroidal neovascular lesions of age-related macular degeneration: quality-of-life findings: SST report no. 14. Ophthalmology. 2004;111(11):2007-2014. [pmid: 15522365].
Christen WG, Glynn RJ, Chew EY, et al. Vitamin E and age-related cataract in a randomized trial of women. Ophthalmology. 2008;115(5):822-829. e821. [pmid: 18067963].
Cabello A, Maraini G. Clinical Trial of Nutritional Supplement Study Group, et al. A randomized, double-masked, placebo-controlled clinical trial of multivitamin supplementation for age-related lens opacities. Clinical trial of nutritional supplements and age-related cataract report no. 3. Ophthalmology. 2008;115(4):599-607. [pmid: 18387406].
CTNS Study Group. The Italian-American Clinical Trial of Nutritional Supplements and Age-Related Cataract (CTNS): design implications. CTNS report no. 1. Control Clin Trials. 2003;24:815-829. [pmid: 14662284].
Day L, Fildes B, Gordon I, et al. Randomised factorial trial of falls prevention among older people living in their own homes. BMJ. 2002;325(7356):128. [pmid: 12130606].
Findl O, Buehl W, Bauer P, et al. Interventions for preventing posterior capsule opacification. Cochrane Database Syst Rev. 2008;1.
Geltzer A, Turalba A, Vedula SS. Surgical implantation of steroids with antiangiogenic characteristics for treating neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
Gohel PS, Mandava N, Olson JL, et al. Age-related macular degeneration: an update on treatment. Am J Med. 2008;121(4):279-281. [pmid: 18374683].
Holladay JT. Visual acuity measurements. J Cataract Refract Surg. 2004;30(2):287-290. [pmid: 15030802].
Jung S, Coleman A, Weintraub NT. Vision screening in the elderly. J Am Med Dir Assoc. 2007;8(6):355-362. [pmid: 17619034].
Kaiser PK. Verteporfin therapy of subfoveal choroidal neovascularization in age-related macular degeneration: 5-year results of two randomized clinical trials with open-label extension. TAP Report No. 8. Graefe's Arch Clin Exp Ophthalmology. 2006;244:1132-1142.
Klein BE, Klein R, Kathryn LP, et al. Prevalence of Age-related Lens Opacities in a Population. Ophthalmology. 1992;99(4):546-552. [pmid: 1584573].
Klein R, Klein BEK, Lee KE, et al. Changes in Visual Acuity in a Population Over a 15-year Period: The Beaver Dam Eye Study. Am J Ophthalmol. 2006;142(4):539-549. e532. [pmid: 17011842].
Luke M, Ziemssen F, Bartz-Schmidt KU, et al. Quality of life in a prospective, randomised pilot-trial of photodynamic therapy versus full macular translocation in treatment of neovascular age-related macular degeneration—a report of 1 year results. Graefes Arch Clin Exp Ophthalmol. 2007;245(12):1831-1836. [pmid: 17347809].
Lundstrom M, Stenevi U, Thorburn W. Cataract surgery in the very elderly. J Cataract Refract Surg. 2000;26(3):408-414. [pmid: 10713238].
Mary ET. Where Is the Vision for Fall Prevention?. J Am Geriatr Soc. 2001;49(5):676-677. [pmid: 11380766].
Meads C, Hyde C. Photodynamic therapy with verteporfin is effective, but how big is its effect? Results of a systematic review. Br J Ophthalmol. 2004;88(2):212-217. [pmid: 14736777].
Miskala PH, Bass EB, Bressler NM, et al. Surgery for subfoveal choroidal neovascularization in age-related macular degeneration: quality-of-life findings: SST report no. 12. Ophthalmology. 2004;111(11):1981-1992. [pmid: 15522363].
Monestam E, Wachmeister L. Impact of cataract surgery on the visual ability of the very old. Am J Ophthalmol. 2004;137(1):145-155. [pmid: 14700658].
Quillen DA. Common Causes of Vision Loss in Elderly Patients. Am Fam Physician. 1999;60(1):99. [pmid: 10414631].
Reddy U, Krzystolik M. Antiangiogenic therapy with interferon alfa for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
Sivagnanavel V, Evans JR, Ockrim Z, et al. Radiotherapy for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
Taylor HR, Vu HT, McCarty CA, et al. The need for routine eye examinations. Invest Ophthalmol Vis Sci. 2004;45(8):2539-2542. [pmid: 15277474].
Thiagarajan M, Evans JR, Smeeth L, et al. Cause-specific visual impairment and mortality: results from a population-based study of older people in the United Kingdom. Arch Ophthalmol. 2005;123(10):1397-1403. [pmid: 16219731].
Westcott MC, Tuft SJ, Minassian DC. Effect of age on visual outcome following cataract extraction. Br J Ophthalmol. 2000;84:1380-1382. [pmid: 11090477].

### In a Systematic Review, not directly used

Bernth-Petersen P. Outcome of cataract surgery. A prospective, observational study. Acta Ophthalmol. 1982;60:235-242. [pmid: 7136534].
Blumenkranz MS, Bressler NM, Bressler SB, et al. Verteporfin therapy for subfoveal choroidal neovascularization in age-related macular degeneration: three-year results of an open-label extension of 2 randomized clinical trials—TAP Report no. 5. Arch Ophthalmol. 2002;120(10):1307-1314. [pmid: 12365909].
Boyer DS, Antoszyk AN, Awh CC, et al. Subgroup analysis of the MARINA study of ranibizumab in neovascular age-related macular degeneration. Ophthalmology. 2007;114(2):246-252. [pmid: 17270674].
Bressler NM, Arnold J, Benchaboune M, et al. Verteporfin therapy of subfoveal choroidal neovascularization in patients with age-related macular degeneration: additional information regarding baseline lesion composition's impact on vision outcomes-TAP report No. 3. Arch Ophthalmol. 2002;120(11):1443-1454. [pmid: 12427056].
Complications of Age-Related Macular Degeneration Prevention Trial Research G. Laser treatment in patients with bilateral large drusen: the complications of age-related macular degeneration prevention trial. Ophthalmology. 2006;113(11):1974-1986. [pmid: 17074563].
Desai P, Minassian DC, Reidy A. National cataract surgery survey 1997-1998: a report of the results of the clinical outcomes. Br J Ophthalmol. 1999;83:1336-1340. [pmid: 10574810].
Engler C, Sander B, Villumsen J, et al. Interferon alfa-2a modifies the course of subfoveal and juxtafoveal choroidal neovascularisation. Br J Ophthalmol. 1994;78(10):749-753. [pmid: 7528534].
Flaxel CJ, Friedrichsen EJ, Smith JO, et al. Proton beam irradiation of subfoveal choroidal neovascularisation in age-related macular degeneration. Eye. 2000;14(Pt 2):155-164. [pmid: 10845009].
Gillies MC, Simpson JM, Billson FA, et al. Safety of an intravitreal injection of triamcinolone: results from a randomized clinical trial. Arch Ophthalmol. 2004;122(3):336-340. [pmid: 15006845].
Gillies MC, Simpson JM, Luo W, et al. A randomized clinical trial of a single dose of intravitreal triamcinolone acetonide for neovascular age-related macular degeneration: one-year results. Arch Ophthalmol. 2003;121(5):667-673. [pmid: 12742844].
Gonzales CR. VEGF Inhibition Study in Ocular Neovascularization Clinical Trial Group. Enhanced efficacy associated with early treatment of neovascular age-related macular degeneration with pegaptanib sodium: an exploratory analysis. Retina (Philadelphia, Pa.). 2005;25(7):815-827.
Hart PM, Chakravarthy U, Mackenzie G, et al. Visual outcomes in the subfoveal radiotherapy study: a randomized controlled trial of teletherapy for age-related macular degeneration. Arch Ophthalmol. 2002;120(8):1029-1038. [pmid: 12149056].
Hosal BM, Tekeli O, Gursel E. Eyelid malpositions after cataract surgery. Eur J Ophthalmol. 1998;8(1):12-15. [pmid: 9590589].
Jonas JB, Degenring RF, Kreissig I, et al. Exudative age-related macular degeneration treated by intravitreal triamcinolone acetonide. A prospective comparative nonrandomized study. Eye (London, England). 2005;19(2):163-170.
Lin DY, Manche EE. Two-year results of conductive keratoplasty for the correction of low to moderate hyperopia. J Cataract Refract Surg. 2003;29(12):2339-2350. [pmid: 14709295].
Marcus DM, Peskin E, Maguire M, et al. The age-related macular degeneration radiotherapy trial (AMDRT): one year results from a pilot study. Am J Ophthalmol. 2004;138(5):818-828. [pmid: 15531318].
McDonald MB, Hersh PS, Manche EE, et al. Conductive keratoplasty for the correction of low to moderate hyperopia: U.S. Clinical trial 1-year results on 355 eyes. Ophthalmology. 2002;109(11):1978-1989. [pmid: 12414402].
McGwin G Jr, Scilley K, Brown J, et al. Impact of cataract surgery on self-reported visual difficulties: comparison with a no-surgery reference group. J Cataract Refract Surg. 2003;29(5):941-948. [pmid: 12781280].
Naoumidi T, Kounis G, Astyrakakis N, et al. Two-year follow-up of conductive keratoplasty for the treatment of hyperopic astigmatism. J Cataract Refract Surg. 2006;32(5):732-741. [pmid: 16765788].
Norregaard JC, Thoning H, Bernth-Petersen P, et al. Risk of endophthalmitis after cataract extraction: results from the International Cataract Surgery Outcomes study. Br J Ophthalmol. 1997;81:102-106. [pmid: 9059242].
Pallikaris IG, Naoumidi TL, Astyrakakis NI. Long-term results of conductive keratoplasty for low to moderate hyperopia. J Cataract Refract Surg. 2005;31(8):1520-1529. [pmid: 16129286].
Pham TQ, Wang JJ, Maloof A, et al. Cataract surgery in patients with age-related maculopathy: preoperative diagnosis and postoperative visual acuity. Clin Experiment Ophthalmol. 2005;33(4):360-363. [pmid: 16033346].
RAD Study. A prospective, randomized, double-masked trial on radiation therapy for neovascular age-related macular degeneration (RAD Study).
Radiation Therapy for Age-related Macular Degeneration. Ophthalmology. 1999;106(12):2239-2247.
Schein OD, Steinberg EPC, SD, Tielsch JM, et al. Predictors of outcome in patients who underwent cataract surgery. Ophthalmology. 1995;102:817-823. [pmid: 7777281].
Stahl J. Conductive keratoplasty for presbyopia: 3-year results. J Refract Surg. 2007;23(9):905-910. [pmid: 18041244].
Stevenson MR, Hart PM, Chakravarthy U, et al. Visual functioning and quality of life in the SubFoveal Radiotherapy Study (SFRADS): SFRADS report 2. The Br J Ophthalmol. 2005;89(8):1045-1051. [pmid: 16024863].
Taylor HR, Tikellis G, Robman LD, et al. Vitamin E supplementation and macular degeneration: randomised controlled trial. BMJ. 2002;325(7354):11. [pmid: 12098721].
Valmaggia C, Ries G, Ballinari P. Radiotherapy for subfoveal choroidal neovascularization in age-related macular degeneration: a randomized clinical trial. Am J Ophthalmol. 2002;133(4):521-529. [pmid: 11931786].
Zambarakji HJ, Lane AM, Ezra E, et al. Proton beam irradiation for neovascular age-related macular degeneration. Ophthalmology. 2006;113(11):2012-2019. [pmid: 16935343].
Garrett SK, McNeil JJ, Silagy C, et al. Methodology of the VECAT study: vitamin E intervention in cataract and age-related maculopathy. Ophthalmic Epidemiol. 1999;6(3):195-208. [pmid: 10487974].
Holz F, Wolfensberger T, Piguet B, et al. Oral zinc-therapy in age-related macular degeneration: a double-blind study (abstract). German J Ophthalmol. 1993;2:391.
Wang H, Li RX, Wang MF. Effects of zinc and antioxidant on visual function of patients with age-related macular degeneration. Zhongguo Linchuant Kangfu. 2004;8:1290-1291.
Apte R, Modi M. Macugen AMD Study Group, et al. Pegaptanib 1-year systemic safety results from a safety-pharmacokinetic trial in patients with neovascular age-related macular degeneration. Ophthalmology. 2007;114(9):1702-1712. [pmid: 17509689].
Coscas G, Soubrane G, Ramahefasolo C, et al. Perifoveal laser treatment for subfoveal choroidal new vessels in age-related macular degeneration: Results of a randomized clinical trial. Arch Ophthalmol. 1991;109(9):1258-1265. [pmid: 1718253].
Arnold J, Algan M, Soubrane G, et al. Indirect scatter laser photocoagulation to subfoveal choroidal neovascularization in age-related macular degeneration. Graefes Arch Clin Exp Ophthalmol. 1997;235(4):208-216. [pmid: 9143888].
Bressler NM, Maguire MG, Murphy PL, et al. Macular scatter (‘grid’) laser treatment of poorly demarcated subfoveal choroidal neovascularization in age-related macular degeneration. Results of a randomized pilot trial. Arch Ophthalmol. 1996;114(12):1456-1464. [pmid: 8953976].
Canadian Ophthalmology Study Group. Argon green vs krypton red laser photocoagulation of extrafoveal choroidal neovascular lesions. One-year results in age-related macular degeneration. Arch Ophthalmol. 1993;111(2):181-185. [pmid: 7679269].
Cardillo P, Ghiglione D, Allegri P. Grid laser treatment of occult choroidal neovascularization in age related macular degeneration. Int Ophthalmol. 1993;17(2):77-83. [pmid: 7691775].
Coscas G, Soubrane G. Argon laser photocoagulation of macular subretinal neovascularization: Indications, methods, and results in 60 cases. Journal Francais d'Ophthalmologie. 1983;7(2):99-105.
Culham L, Chabra A, Rubin G. Clinical performance of electronic, head-mounted, low-vision devices. Ophthalmic Physiol Opt. 2004;24(4):281-290. [pmid: 15228505].
Duch Mestres F, Vilaplana D, Civit J, et al. Static perimetry evaluation of argon green and dye red laser treatment for choroidal nevovascular membranes. Lasers and Light in Ophthalmology. 1993;6(1):27-32.
Eperjesi F, Fowler C, Evans B. The effects of coloured light filter overlays on reading rates in age-related macular degeneration. Acta Ophthalmol Scand. 2004;82(6):695-700. [pmid: 15606466].
Goodrich G, Kirby J. A comparison of patient reading performance and preference: optical devices, handheld CCTV (Innoventions Magni-Cam), or stand-mounted CCTV (Optelec Clearview or TSI Genie). Optometry. 2001;72(8):519-528. [pmid: 11519714].
Kleweno C, Seibel E, Viirre E, et al. The virtual retinal display as a low-vision computer interface: A pilot study. J Rehabil Res Dev. 2001;38(4):431-432. [pmid: 11563496].
Ortiz A, Chung S, Legge G, et al. Reading with a headmounted videomagnifier. Optometry and Vision Science. 1999;76(11):755-763. [pmid: 10566860].
Peterson R, Wolffsohn J, Rubinstein M, et al. Benefits of electronic vision enhancement systems (EVES) for the visually impaired. Am J Ophthalmol. 2003;136(6).
Smith HJ, Dickinson CM, Cacho I, et al. A randomized controlled trial to determine the effectiveness of prism spectacles for patients with age-related macular degeneration. Arch Ophthalmol. 2005;123(8):1042-1050. [pmid: 16087836].
Spitzberg L, Goodrich G. New ergonomic stand magnifiers. J Am Optom Assoc. 1995;66(1):25-30. [pmid: 7884138].
Stelmack J, Reda D, Ahlers S, et al. Reading performance of geriatric patients post exudativemaculopathy. J Am Optom Assoc. 1991;62(1):53-57. [pmid: 1813493].
Bressler NM, Bressler SB. Submacular Surgery Trials Pilot Study, et al. Submacular surgery trials randomized pilot trial of laser photocoagulation versus surgery for recurrent choroidal neovascularization secondary to age-related macular degeneration: I. Ophthalmic outcomes submacular surgery trials pilot study report number 1. Am J Ophthalmol. 2000;130(4):387-407. [pmid: 11024412].
Versteeg-Tijmes NT, de Jong PTF, Bos PJ, et al. Argon laser treatment of pigment epithelial detachments and of subretinal neovascular membranes in Junius-Kuhnt's senile disciform macular degeneration. A prospective, randomized study. Graefe's Arch Clin Exp Ophthalmology. 1982;218(5):271-274.
Yassur Y, Axer-Siegel R, Cohen S, et al. Treatment of neovascular senile maculopathy at the foveal capillary free zone with red krypton laser. Retina (Philadelphia, Pa.). 1982;2(3):127-133.

### Wrong Intervention

Boyer DS, Beer PM. ADD-V Study Group, et al. Effect of adjunctive diclofenac with verteporfin therapy to treat choroidal neovascularization due to age-related macular degeneration: phase II study. Retina (Philadelphia, Pa.). 2007;27(6):693-700.
Agurto-Rivera R, Diaz-Rubio J, Torres-Bernal L, et al. (2005). Intravitreal triamcinolone with transpupillary therapy for subfoveal choroidal neovascularization in age related macular degeneration. A randomized controlled pilot study [ISRCTN74123635]. BMC Ophthalmol. Vol 5(27).
Arden GB, Wolf JE. Colour vision testing as an aid to diagnosis and management of age related maculopathy. Br J Ophthalmol. 2004;88(9):1180-5. [pmid: 15317712].
Brody BL, Roch-Levecq AC, Thomas RG, et al. Self-management of age-related macular degeneration at the 6-month follow-up: a randomized controlled trial. Arch Ophthalmol. 2005;123(1):46-53. [pmid: 15642811].
Brunner R, Widder RA, Walter P, et al. Influence of membrane differential filtration on the natural course of age-related macular degeneration: a randomized trial. Retina (Philadelphia, Pa.). 2000;20(5):483-91.
Brunner S, Krebs I, Stolba U, et al. (2005). Cataract Surgery in Nonexudative Age-Related Macular Degeneration - First Results of a Prospective, Randomized, Multicenter Trial (ECAM-1). Invest Ophthalmol Vis Sci. Vol. 46(195).
Chan WK, Heng WJ, Tseng P, et al. Photorefractive keratectomy for myopia of 6 to 12 diopters. J Refract Surg (Thorofare, N.J). 1995;11(3 Suppl):S286-92.
Chan WM, Lai TY, Wong AL, et al. Combined photodynamic therapy and intravitreal triamcinolone injection for the treatment of subfoveal choroidal neovascularisation in age related macular degeneration: a comparative study. Br J Ophthalmol. 2006;90(3):337-41. [pmid: 16488958].
Cox C, Krueger R. Monovision with Laser Vision correction. Ophthlmol Clin N Am. 2006;19:71-75.
Dahlin-Ivanoff S, Sonn U, Svensson E. A health education program for elderly persons with visual impairments and perceived security in the performance of daily occupations: a randomized study. Am J Occup Ther. 2002;56(3):322-30. [pmid: 12058521].
D'Amico DJ, Goldberg MF, Hudson H, et al. Anecortave acetate as monotherapy for treatment of subfoveal neovascularization in age-related macular degeneration: twelve-month clinical outcomes. Ophthalmology. 2003;110(12):2372-83. [pmid: 14644721].
D'Amico DJ, Goldberg MF, Hudson H, et al. Anecortave acetate as monotherapy for the treatment of subfoveal lesions in patients with exudative age-related macular degeneration (AMD): interim (month 6) analysis of clinical safety and efficacy. Retina (Philadelphia, Pa.). 2003;23(1):14-23.
Eklund K, Sonn U, Dahlin-Ivanoff S. Long-term evaluation of a health education programme for elderly persons with visual impairment. Disabil Rehabil. 2004;26(7):401-9. [pmid: 15204476].
Espindle D, Crawford B, Maxwell A, et al. Quality-of-life improvements in cataract patients with bilateral blue light-filtering intraocular lenses: clinical trial. J Cataract Refract Surg. 2005;31(10):1952-9. [pmid: 16338566].
Fedorowicz Z, Lawrence D and Gutierrez P (2008). Day care versus in-patient surgery for age-related cataract. Cochrane Database Syst Rev. 1.
Feher J, Papale A, Mannino G, et al. Mitotropic compounds for the treatment of age-related macular degeneration. The metabolic approach and a pilot study. Int J Ophthalmol. 2003;217(5):351-7.
Fine SL. Early detection of extrafoveal neovascular membranes by daily central field evaluation. Opthalmology. 1985;92:603-609.
Garamendi E, Pesudovs K, Elliott DB. Changes in quality of life after laser in situ keratomileusis for myopia. J Cataract Refract Surg. 2005;31(8):1537-43. [pmid: 16129288].
Gelisken F, Voelker M, Schwabe R, et al. Full macular translocation versus photodynamic therapy with verteporfin in the treatment of neovascular age-related macular degeneration: 1-year results of a prospective, controlled, randomised pilot trial (FMT-PDT). Graefes Arch Clin Exp Ophthalmol. 2007;245(8):1085-95. [pmid: 17219106].
Goldstein M, Loewenstein A, Barak A, et al. Results of a multicenter clinical trial to evaluate the preferential hyperacuity perimeter for detection of age-related macular degeneration. Retina. 2005;25(3):296-303. [pmid: 15805906].
Haase KW, Bryant EE. Development of a scale designed to measure functional distance vision loss using an interview technique. Porc Am Stat Assoc. 1973;SS:274-279.
Hodge WG, Barnes D, Schachter H, et al. (2005). Effects of Omega-3 fatty acids on eye health. Agency for Healthcare Research and Quality - U.S. Department of Health and Human Services.
Jain S, Arora I, Azar DT. Success of Monovision in Presbyopes: Review of the Literature and Potential Applications to Refractive Surgery. Surv Ophthalmol. 1996;40(6):491-499. [pmid: 8724641].
Jain S, Hamada S, Membrey WL, et al. Screening for age-related macular degeneration using nonstereo digital fundus photographs. Eye. 2006;20(4):471-5. [pmid: 15895024].
Kim JE, Shah KB, Han DP, et al. Transpupillary thermotherapy with indocyanine green dye enhancement for the treatment of occult subfoveal choroidal neovascularization in age-related macular degeneration. Ophthalmic Surg Lasers Imaging. 2006;37(4):272-7. [pmid: 16898386].
Koch DD, Kohnen T, McDonnell PJ, et al. Hyperopia correction by noncontact holmium: YAG laser thermal keratoplasty. United States phase IIA clinical study with a 1-year follow-up. Ophthalmology. 1996;103(10):1525-35. [pmid: 8874423].
Kohnen T, Koch DD, McDonnell PJ, et al. Noncontact holmium: YAG laser thermal keratoplasty to correct hyperopia: 18-month follow-up. Ophthalmologica Int J Ophthalmol. 1997;211(5):274-82.
McDonald MB, Durrie D, Asbell P, et al. Treatment of presbyopia with conductive keratoplasty. Cornea. 2004;23(7):661-668. [pmid: 15448490].
Nazemi PP, Fink W, Lim JI, et al. Scotomas of age-related macular degeneration detected and characterized by means of a novel three-dimensional computer-automated visual field test. Retina. 2005;25(4):446-53. [pmid: 15933591].
Owsley C, McGwin G Jr, Phillips JM, et al. Impact of an educational program on the safety of high-risk, visually impaired, older drivers. Am J Prev Med. 2004;6(3):222-9. [pmid: 15026102].
Reeves BC, Harper RA, Russell WB. Enhanced low vision rehabilitation for people with age related macular degeneration: a randomised controlled trial. Br J Ophthalmol. 2004;88(11):1443-9. [pmid: 15489491].
Siatkowski RM, Lam BL, Anderson DR, et al. Automated suprathreshold static perimetry screening for detecting neuro-ophthalmologic disease. Ophthalmology. 1996;03(6):907-17. [pmid: 8643246].
Slakter JS, Bochow TW, D'Amico DJ, et al. Anecortave acetate (15 milligrams) versus photodynamic therapy for treatment of subfoveal neovascularization in age-related macular degeneration. Ophthalmology. 2006;13(1):3-13. [pmid: 16368146].
Sloan FA, Picone G, Brown DS, et al. Longitudinal Analysis of the Relationship Between Regular Eye Examinations and Changes in Visual and Functional Status. J Am Geriatr Soc. 2005;53(11):1867-1874. [pmid: 16274366].
Smeeth, L and Iliffe, S (2008). Community screening for visual impairment in the elderly. Cochrane Database Syst Rev. 1.
Stelmack JA, Tang XC, Reda DJ, et al. Outcomes of the Veterans Affairs Low Vision Intervention Trial (LOVIT). Arch Ophthalmol. 2008;26(5):608-617. [pmid: 18474769].
Submacular Surgery Trials (SST) Study Group. Submacular surgery trials randomized pilot trial of laser photocoagulation versus surgery for recurrent choroidal neovascularization secondary to age-related macular degeneration: II. Quality of life outcomes submacular surgery trials pilot study report number 2. Am J Ophthalmol. 2000;130(4):408-18. [pmid: 11024413].
Tikellis G, Robman LD, Harper A, et al. Methods for detecting age-related maculopathy: a comparison between photographic and clinical assessment. Clin Experiment Ophthalmol. 2000;8(5):367-72. [pmid: 11097285].
Topouzis F, Coleman AL, Yu F, et al. Sensitivity and specificity of the 76-suprathreshold visual field test to detect eyes with visual field defect by Humphrey threshold testing in a population-based setting: the Thessaloniki eye study. Am J Ophthalmol. 2004;137(3):420-5. [pmid: 15013863].

### Wrong Outcome

Anstey KJ, Lord SR, Hennessy M, et al. The effect of cataract surgery on neuropsychological test performance: a randomized controlled trial. J Int Neuropsychol Soc. 2006;12(5):632-9. [pmid: 16961944].
Asbell PA, Maloney RK, Davidorf J, et al. Conductive keratoplasty for the correction of hyperopia. Trans Am Ophthalmol Soc. 2001;Vol 99:79-84. [pmid: 11797323].
Batchelder TJ, Fireman B, Friedman GD, et al. The value of routine dilated pupil screening examination. Arch Ophthalmol. 1997;115(9):1179-84. [pmid: 9298061].
Broman AT, Munoz B, Rodriguez J, et al. The impact of visual impairment and eye disease on vision-related quality of life in a Mexican-American population: proyecto VER. Invest Ophthalmol Vis Sci. 2002;43(11):3393-8. [pmid: 12407148].
Frennesson C, Nilsson SE. Prophylactic laser treatment in early age related maculopathy reduced the incidence of exudative complications. Br J Ophthalmol. 1998;82(10):1169-74. [pmid: 9924306].
Frennesson CI. Prophylactic laser treatment in early age-related maculopathy: an 8-year follow-up in a randomized pilot study shows a reduced incidence of exudative complications. Acta Ophthalmol Scand. 2003;81(5):449-54. [pmid: 14510790].
Gustavsson C, Agardh E. Transpupillary thermotherapy for occult subfoveal choroidal neovascularization: a 1-year, prospective randomized pilot study. Acta Ophthalmol Scand. 2005;83(2):148-53. [pmid: 15799724].
Haegerstrom-Portnoy G, Brabyn J, Schneck ME, et al. The SKILL Card. Invest Ophthalmol Vis Sci. 1997;38(1):207-18. [pmid: 9008645].
Hodge W, Horsley T, Albiani D, et al. The consequesces of waiting for cataract surgery: a systematic review. CMAJ. 2007;176(9):1285-1290. [pmid: 17452662].
Hofeldt AJ, Weiss MJ. Illuminated near card assessment of potential acuity in eyes with cataract. Ophthalmology. 1998;105(8):1531-6. [pmid: 9709769].
Johnson L, Buckley JG, Scally AJ, et al. Multifocal spectacles increase variability in toe clearance and risk of tripping in the elderly. Invest Ophthalmol Vis Sci. 2007;48(4):1466-71. [pmid: 17389472].
Keane EM, O'Connor M, Coakley D, et al. Eye screening in the elderly. Ir Med J. 1997;90(4):141-2. [pmid: 9267091].
Lazic R, Gabric N. Verteporfin therapy and intravitreal bevacizumab combined and alone in choroidal neovascularization due to age-related macular degeneration. Ophthalmology. 2007;114(6):1179-85. [pmid: 17544776].
Lois N, Owens SL, Coco R, et al. Fundus autofluorescence in patients with age-related macular degeneration and high risk of visual loss. Am J Ophthalmol. 2002;133(3):341-9. [pmid: 11860971].
Maberley DA, Isbister C, Mackenzie P, et al. An evaluation of photographic screening for neovascular age-related macular degeneration. Eye. 2005;19(6):611-6. [pmid: 15184945].
Gilson MM, Bressler NM. NAPP Trial Research Group, et al. Periocular triamcinolone and photodynamic therapy for subfoveal choroidal neovascularization in age-related macular degeneration. Ophthalmology. 2007;114(9):1713-21. [pmid: 17822977].
Nio YK, Jansonius NM, Wijdh RHJ, et al. Effect of methods of myopia correction on visual acuity, contrast sensitivity, and depth of focus. J Cataract Refract Surg. 2003;29(11):2082-95. [pmid: 14670416].
Nottle HR, McCarty CA, Hassell JB, et al. Detection of vision impairment in people admitted to aged care assessment centres. Clin Experiment Ophthalmol. 2000;28(3):162-4. [pmid: 10981787].
Owens SL, Bunce C, Brannon AJ, et al. Prophylactic laser treatment hastens choroidal neovascularization in unilateral age-related maculopathy: final results of the drusen laser study. Am J Ophthalmol. 2006;141(2):276-81. [pmid: 16458680].
Papadaki T, Tsilimbaris M, Thermos K, et al. The role of lanreotide in the treatment of choroidal neovascularization secondary to age-related macular degeneration: a pilot clinical trial. Retina. 2003;23(6):800-7. [pmid: 14707831].
Parisi V, Tedeschi M, Gallinaro G, et al. Carotenoids and antioxidants in age-related maculopathy italian study: multifocal electroretinogram modifications after 1 year. Ophthalmology. 2008;115(2):324-333. e2. [pmid: 17716735].
Pesudovs K, Patel B, Bradbury JA, et al. Reading speed test for potential central vision measurement. Clin Experiment Ophthalmol. 2002;30(3):183-6. [pmid: 12010211].
Quigley HA, Park CK, Tracey PA, et al. Community screening for eye disease by laypersons: the Hoffberger program. Am J Ophthalmol. 2002;133(3):386-92. [pmid: 11860976].
Remky A, Weber A, Arend O, et al. Topical dorzolamide increases pericentral visual function in age-related maculopathy: pilot study findings with short-wavelength automated perimetry. Acta Ophthalmol Scand. 2005;83(2):154-60. [pmid: 15799725].
Robbie SJ, Muhtaseb M, Qureshi K, et al. Intraoperative complications of cataract surgery in the very old. Br J Ophthalmol. 2006;90:1516-1518. [pmid: 16899530].
Rosser DA, Laidlaw DA, Murdoch IE. The development of a “reduced logMAR” visual acuity chart for use in routine clinical practice. Br J Ophthalmol. 2001;85(4):432-6. [pmid: 11264133].
Salz JJ, Stevens CA. LADAR Vision LASIK Hyperopia Study Group. LASIK correction of spherical hyperopia, hyperopic astigmatism, and mixed astigmatism with the LADARVision excimer laser system. Ophthalmology. 2002;109(9):1647-56. [pmid: 12208711].
Wylegala EA, Pilat J, Teper SJ, et al. Monitoring of photodynamic therapy results in age-related macular degeneration by means of preferential hyperacuity perimeter. Eur J Ophthalmol. 2007;17(5):768-75. [pmid: 17932853].

### Wrong Population

Amsler M. Earliest symptoms of diseases of the macular. Br J Ophthalmol. 1953;37:521-537. [pmid: 13081950].
Augustin AJ, Offermann I, Lutz J, et al. Comparison of the original Amsler grid with the modified Amsler grid: result for patients with age-related macular degeneration. Retina. 2005;25(4):443-5. [pmid: 15933590].
Binder S, Krebs I, Hilgers RD, et al. Outcome of transplantation of autologous retinal pigment epithelium in age-related macular degeneration: a prospective trial. Invest Ophthalmol Vis Sci. 2004;45(11):4151-60. [pmid: 15505069].
Brancato R, Pece A, Radrizzani E. Photocoagulation scar expansion after laser therapy for choroidal nerovascularization in degenreative myopia. Retina. 1990;25(4):239-243. [pmid: 1708513].
Chen CY, Keeffe JE, Garoufalis P, et al. Vision-related quality of life comparison for emmetropes, myopes after refractive surgery, and myopes wearing spectacles or contact lenses. J Refract Surg. 2007;23(8):752-9. [pmid: 17985794].
Chong EWT, Wong TY, Kreis AJ, et al. Dietary antioxidants and primary prevention of age related macular degeneration: systematic review and meta-analysis. BMJ. 2007;335(7623):755. [pmid: 17923720].
Christen W, Glynn R, Sperduto R, et al. Age-related cataract in a randomized trial of beta-carotene in women. Ophthalmic Epidemiol. 2004;11(5):401-12. [pmid: 15590586].
Christen WG, Manson JE, Glynn RJ, et al. Beta carotene supplementation and age-related maculopathy in a randomized trial of US physicians. Arch Ophthalmol. 2007;125(3):333-9. [pmid: 17353403].
Christen WG, Manson JE, Glynn RJ, et al. A randomized trial of beta carotene and age-related cataract in US physicians. Arch Ophthalmol. 2003;121(3):372-8. [pmid: 12617708].
Garamendi E, Pesudovs K, Elliott D. Changes in quality of life after laser in situ keratomileusis for myopia. J Cataract Refract Surg. 2005;31:1537-1543. [pmid: 16129288].
Gouthaman M, Raman RP, Kadambi A, et al. A customised portable LogMAR chart with adjustable chart illumination for use as a mass screening device in the rural population. J Postgrad Med. 2005;51(2):112-4. [pmid: 16006702].
Haan MN, Klein R, Klein BE, et al. Hormone therapy and age-related macular degeneration: the Women's Health Initiative Sight Exam Study. Arch Ophthalmol. 2006;124(7):988-92. [pmid: 16832022].
Johansen A, White S, Waraisch P. Screening for visual impairment in older people: validation of the Cardiff Acuity Test. Arch Gerontol Geriatr. 2003;36(3):289-93. [pmid: 12849084].
Lee J, Lee J, Park K, et al. Assessing the value of laser in situ keratomileusis by patient-reported outcomes using quality of life assessment. J Refract Surg. 2005;21(1):59-71. [pmid: 15724686].
Liu DT, Li CL, Lee VY. Screening for visual impairment in elderly patients with hip fracture: validating a simple bedside test. Eye. 2006;20(12):1429-30. [pmid: 16485012].
Loewenstein A, Malach R, Goldstein M, et al. Replacing the Amsler grid: a new method for monitoring patients with age-related macular degeneration. Ophthalmology. 2003;110(5):966-70. [pmid: 12750099].
Loewenstein J, Palmberg P, Connett J. Effectiveness of pinhole method for visual screening. Arch Opthalmol. 1985;103(2):222-223.
Loewenstein JI, Palmberg PF, Connett JE, et al. Effectiveness of a pinhole method for visual acuity screening. Arch Ophthamol. 1985;103:222-223.
Long, V, Chen, S and Hatt, S (2008). Surgical interventions for bilateral congenital cataract. Cochrane Database Syst Rev. 1.
McNeil JJ, Robman L, Tikellis G, et al. Vitamin E supplementation and cataract: randomized controlled trial. Ophthalmology. 2004;111(1):75-84. [pmid: 14711717].
Melki SA, Safar A, Martin J, et al. Potential acuity pinhole: a simple method to measure potential visual acuity in patients with cataracts, comparison to potential acuity meter. Ophthalmology. 1999;106(7):1262-7. [pmid: 10406603].
Myint K, Armbrecht AM, Mon S, et al. Transpupillary thermotherapy for the treatment of occult CNV in age-related macular degeneration: a prospective randomized controlled pilot study. Acta Ophthalmol Scand. 2006;84(3):328-32. [pmid: 16704693].
Pesudovs K, Garamendi E, Elliott DB. A quality of life comparison of people wearing spectacles or contact lenses or having undergone refractive surgery. J Refract Surg. 2006;22(1):19-27. [pmid: 16447932].
Riaz Y, Mehta JS, Wormald R, et al. (2008). Surgical interventions for age-related cataract. Cochrane Database Syst Rev. 1.
Squirrell DM, Kenny J, Mawer N, et al. Screening for visual impairment in elderly patients with hip fracture: validating a simple bedside test. Eye. 2005;19(1):55-9. [pmid: 15184957].
Stone DH, Shannon DJ. Screening for impaired visual acuity in middle age in general practice. BMJ. 1978;2(6141):859-861. [pmid: 709095].
Tamura H, Tsukamoto H, Mukai S, et al. Improvement in cognitive impairment after cataract surgery in elderly patients. J Cataract Refract Surg. 2004;30(3):598-602. [pmid: 15050255].
van Leeuwen R, Boekhoorn S, Vingerling JR, et al. Dietary intake of antioxidants and risk of age-related macular degeneration. JAMA. 2005;294(24):3101-7. [pmid: 16380590].
van Splunder J, Stilma JS, Bernsen RM, et al. Refractive errors and visual impairment in 900 adults with intellectual disabilities in the Netherlands. Acta Ophthalmol Scand. 2003;81(2):123-9. [pmid: 12752049].
Varma R, Ying-Lai M, Francis BA, et al. Prevalence of open-angle glaucoma and ocular hypertension in Latinos: The Los Angeles Latino Eye Study. Ophthalmology. 2004;111(8):1439-1448. [pmid: 15288969].
VIP and Verteporfin in Photodynamic Therapy Study Group. Verteporfin therapy of subfoveal choroidal neovascularization in pathologic myopia 2-year results of a randomized clinical trial - VIP report No.3. Ophthalmology. 2003;110(4):667-673. [pmid: 12689884].
Virgili G and Menchini F (2008). Laser photocoagulation for choroidal neovascularisation in pathologic myopia. Cochrane Database Syst Rev. 1.
Wun YT, Lam CC, Shum WK. Impaired vision in the elderly: a preventable condition. Fam Pract. 1997;14(4):289-92. [pmid: 9283848].
Zaidi FH, Cheong-Leen R, Gair EJ, et al. The Amsler chart is of doubtful value in retinal screening for early laser therapy of subretinal membranes. The West London Survey. Eye. 2004;18(5):503-8. [pmid: 15131682].

### Wrong Study Design or Publication Type

Amsler M. Quantitative and qualitative vision. J Ophthalmalogical Societies UK. 1949;69:397-410.
Birch DG, Toler SM, Swanson WH, et al. A double-blind placebo-controlled evaluation of the acute effects of sildenafil citrate (Viagra) on visual function in subjects with early-stage age-related macular degeneration. Am J Ophthalmol. 2002;133(5):665-672. [pmid: 11992864].
Carones F, Brancato R, Morico A, et al. Photorefractive keratectomy for hyperopia using an erodible disc and axicon lens: 2-year results. J Refract Surg (Thorofare, N.J.). 1998;14(5):504-511.
Costa RA, Williams GA, For the Two-fold Illumination Scheme for Photodynamic Therapy Study G. Twofold illumination photodynamic therapy scheme for subfoveal choroidal neovascularization in pathologic myopia: results from a randomized pilot study. Retina (Philadelphia, Pa.). 2006;26(7):757-764.
Hays RD, Mangione CM, Ellwein L, et al. Psychometric properties of the National Eye Institute-Refractive Error Quality of Life instrument. Ophthalmology. 2003;110(12):2292-2301. [pmid: 14644710].
Heier JS, Antoszyk AN, Pavan PR, et al. Ranibizumab for treatment of neovascular age-related macular degeneration: a phase I/II multicenter, controlled, multidose study. Ophthalmology. 2006;113(4):633-642. [pmid: 16483659].
Heier JS, Boyer DS, Ciulla TA, et al. Ranibizumab combined with verteporfin photodynamic therapy in neovascular age-related macular degeneration: year 1 results of the FOCUS Study. Arch Ophthalmol. 2006;124(11):1532-1542. [pmid: 17101999].
Hirsch R, Schwartz B. Increased mortality among elderly patients undergoing cataract extraction. Arch Opthalmol. 1983;101(7):1034-1037.
Klein BEK, Moss SE, Klein R, et al. Associations of visual function with physical outcomes and limitations 5 years later in an older population: The Beaver Dam eye study. Ophthalmology. 2003;110(4):644-650. [pmid: 12689880].
McEwan R, Davison N. Screening elderly people in primary care: a randomized controlled trial. Br J Gen Pract. 1990;40(332):94-97. [pmid: 2112022].
McKean-Cowdin R, Varma R, Wu J, et al. Severity of Visual Field Loss and Health-related Quality of Life. Am J Ophthalmol. 2007;143(6):1013-1023. [pmid: 17399676].
Michels S, Wachtlin J, Gamulescu MA, et al. Comparison of early retreatment with the standard regimen in verteporfin therapy of neovascular age-related macular degeneration. Ophthalmology. 2005;112(12):2070-2075. [pmid: 16225928].
O.C.T.E.T. Subjective assessment of the effect of cataract surgery and a review of long term aims. Oxford Cataract Treatment and Evaluation Team (O.C.T.E.T.). Eye. 1987;1(Pt 2):247-253. [pmid: 2888691].
Owsley C, Stalvey B, Wells J, et al. Older drivers and cataract. Driving habits and crash risk. J Gerontol A Biol Sci Med Sci. 1999;54:M203-211. [pmid: 10219012].
Rosenfeld PJ, Heier JS, Hantsbarger G, et al. Tolerability and efficacy of multiple escalating doses of ranibizumab (Lucentis) for neovascular age-related macular degeneration. Ophthalmology. 2006;113(4):632. e631.
Rosenfeld PJ, Schwartz SD, Blumenkranz MS, et al. Maximum tolerated dose of a humanized anti-vascular endothelial growth factor antibody fragment for treating neovascular age-related macular degeneration. Ophthalmology. 2005;112(6):1048-1053. [pmid: 15885778].
Shortt AJ, Bunce C, Allan BD, et al. Evidence for superior efficacy and safety of LASIK over photorefractive keratectomy for correction of myopia. Ophthalmology. 2006;113(11):1897-1908. [pmid: 17074559].
Spalton D. Posterior capsular opacification after cataract surgery. Eye (London, England). 1999;13(Pt 36):489-492.
Talamo JH, Siebert K, Wagoner MD, et al. Multicenter study of photorefractive keratectomy for myopia of 6.00 to 8.00 diopters. VISX Moderate Myopia Study Group. J Refract Surg (Thorofare, N.J.). 1995;11(4):238-247.
Thompson J, Sparrow JM, Gibson J, et al. Cataract and survival in an elderly non-diabetic population. Arch Opthalmol. 1993;111(5):675-679.
Cangemi FE. TOZAL Study: an open case control study of an oral antioxidant and omega-3 supplement for dry AMD. BMC Ophthalmol. Vol. 2007;7(3).
Bartlett H, Eperjesi F. Age-related macular degeneration and nutritional supplementation: a review of randomised controlled trials. Ophthalmic Physiol Opt. 2003;23(5):383-399. [pmid: 12950886].
Bartlett H, Eperjesi F. Possible contraindications and adverse reactions associated with the use of ocular nutritional supplements. Ophthalmic Physiol Opt. 2005;25(3):179-194. [pmid: 15854063].
Borodoker N, Spaide RF, Maranan L, et al. Verteporfin infusion-associated pain. Am J Ophthalmol. 2002;133(2):211-214. [pmid: 11812424].
Coleman H, Chew E. Nutritional supplementation in age-related macular degeneration. Curr Opin Ophthalmol. 2007;18(3):220-223. [pmid: 17435429].
Du TT, Fan VC, Asbell PA. Conductive keratoplasty. Curr Opin Ophthalmol. 2007;18(4):334-337. [pmid: 17568211].
Evans B. Monovision: a review. Ophthalmic Physiol Opt. 2007;27(5):417-439. [pmid: 17718882].
Gillespie LD, Robertson MC, Gillespie WJ, et al. Interventions for preventing falls in older people living in the community. Cochrane Database Syst Rev. 2008(2).
Jackson WB, Casson E, Hodge WG, et al. Laser vision correction for low hyperopia. An 18-month assessment of safety and efficacy. Ophthalmology. 1998;105(9):1727-1738. [pmid: 9754184].
McDonald MB, Davidorf J, Maloney RK, et al. Conductive keratoplasty for the correction of low to moderate hyperopia: 1-year results on the first 54 eyes. Ophthalmology. 2002;109(4):637-649. [pmid: 11927418].
Mills E, Heels-Ansdell D, Kelly S, et al. A randomized trial of Pegaptanib sodium for age-related macular degeneration used an innovative design to explore disease-modifying effects. J Clin Epidemiol. 2007;60(5):456-460. [pmid: 17419956].
Rosenthal BP. Ophthalmology. Screening and treatment of age-related and pathologic vision changes. Geriatrics. 2001;56(12):27-31. [pmid: 11766560].
Sakimoto T, Rosenblatt M, Azar DT. Laser eye surgery for refractive errors. Lancet. 2006;367:1432-1447. [pmid: 16650653].
Schein OD, McNally JJ, Katz J, et al. The incidence of microbial keratitis among wearers of a 30-day silicone hydrogel extended-wear contact lens. Ophthalmology. 2005;112(12):2172-2179. [pmid: 16325711].
Schmidt-Erfurth U, Richard G, Augustin AJ, et al. Guideance for the treatment of neovascular age-related macular degeneration. Acta Ophthalmol Scand. 2007;85:486-494. [pmid: 17655610].
Smeeth L. Assessing the likely effectiveness of screening older people for impaired vision in primary care. Fam Pract. 1998;15(Suppl 1):S24-29. [pmid: 9613464].
Smeeth L. Community screening for visual impairment in older people. J Am Geriatr Soc. 2001;49(5):673-675. [pmid: 11380765].
Smeeth L, Iliffe S. Effectiveness of screening older people for impaired vision in community setting: systematic review of evidence from randomised controlled trials. BMJ. 1998;316(7132):660-663. [pmid: 9522788].
Smeeth L, Iliffe S. Community Screening for Visual Impairment in Older People. Community Screening for Visual Impairment in the Elderly. J Am Geriatr Soc. 2001;49(5):673-675. [pmid: 11380765].
Suchecki J, Donshik PC, Ehlers WH. Contact lens complications. Ophthalmol Clin North Am. 2003;16:471-484. [pmid: 14564768].
Takeda A, Colquitt J, Clegg A, et al. Pegaptanib and ranibizumab for neovascular age-related macular degeneration: a systematic review. Br J Ophthalmol. 2007;91:1177-1182. [pmid: 17475698].
TAP & VIP study groups. Acute severe visual acuity decrease after photodynamic therapy with verteporfin: case reports from randomized clinical trials - TAP and VIP Report No. 3. Am J Ophthalmol. 2004;137:683-696. [pmid: 15059708].
The Eye Diseases Prevalence Research Group. The prevalence of refractive errors among adults in the United States, Western Europe, and Australia. Arch Ophthalmol. 2004;122(4):495-505. [pmid: 15078666].
Wong TY. Effect of increasing age on cataract surgery outcomes in very elderly patients. BMJ. 2001;322(7294):1104-1106. [pmid: 11337443].

### Non-English Language

Fies P, Dienel A. Ginkgo extract in impaired vision—treatment with special extract EGb 761 of impaired vision due to dry senile macular degeneration. Wiener medizinische Wochenschrift. 2002;152:423-6. [pmid: 12244891].
Lebuisson DA, Leroy L, Rigal G. Treatment of senile macular degeneration with Ginkgo biloba extract. A preliminary double-blind drug vs. placebo study. Presse medicale. 1986;15:1556-8.

## Appendix B5. U.S. Preventive Services Task Force Quality Rating Criteria for Rcts and Observational Studies*

### Diagnostic Accuracy Studies

#### Criteria

- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate results in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test

#### Definition of ratings based on above criteria

- Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease.
- Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
- Poor: Has important limitation such as: uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size of very narrow selected spectrum of patients.

### Randomized Controlled Trials (RCTs) and Cohort Studies

#### Criteria

- Initial assembly of comparable groups: RCTs—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

#### Definition of ratings based on above criteria

- Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention to confounders in analysis.
- Fair: Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for.
- Poor: Studies will be graded “poor” if any of the following major limitations exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention.

### Case Control Studies

#### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variable

#### Definition of ratings based on criteria above

- Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.
- Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.
- Poor: Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

*Reference:

Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001:20(3S); 21–35.

## Appendix B6. Quality Rating Criteria For Systematic Reviews*

Overall quality rating for each systematic review is based on the below questions. Ratings are summarized as: Good, Fair, or Poor:

- Search dates reported? Yes or No
- Search methods reported? Yes or No
- Comprehensive search? Yes or No
- Inclusion criteria reported? Yes or No
- Selection bias avoided? Yes or No
- Validity criteria reported? Yes or No
- Validity assessed appropriately? Yes or No
- Methods used to combine studies reported? Yes or No
- Findings combined appropriately? Yes or No
- Conclusions supported by data? Yes or No

### Definitions of ratings based on above criteria

- [underlined: Good]: Meet all criteria: Reports comprehensive and reproducible search methods and results; reports pre-defined criteria to select studies and reports reasons for excluding potentially relevant studies; adequately evaluates quality of included studies and incorporates assessments of quality when synthesizing data; reports methods for synthesizing data and uses appropriate methods to combine data qualitatively or quantitatively; conclusions supported by the evidence reviewed.
- [underlined: Fair]: Studies will be graded fair if they fail to meet one or more of the above criteria, but the limitations are not judged as being major.
- [underlined: Poor]: Studies will be graded poor if they have a major limitation in one or more of the above criteria.

*Created from the following publications:

Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001:20(3S); 21–35.

National Institute for Health and Clinical Excellence. The Guidelines Manual. London: Institute for Health and Clinical Excellence; 2006.

Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44:1271–8.

## Appendix B7. Expert Reviewers Of The Draft Report

Rebecca Armour, MD

Assistant Professor, Ophthalmology, Casey Eye Institute, Oregon Health and Science University

Mark B Horton, OD, MD

Phoenix Indian Medical Center, Phoenix Arizona

Linda Kinsinger, MD

North Carolina Memorial Hospital, Chapel Hill, North Carolina

Gerald McGwin Jr, PhD

Professor of Epidemiology, University of Alabama at Birmingham

Liam Smeeth, MD

Professor of Clinical Epidemiology, University of London

Gianni Virgili, MD

Associate Professor of Ophthalmology, Department of Ophthalmology, University of Florence, Italy