# Appendix A. Abbreviations

Abbreviation | Meaning
ADVS | Activities of Daily Vision Scale, used to assess the impact of cataract surgery
AE | Adverse Event
AREDS | Age-related Eye Disease Study
ARMD, AMD | Age-related Macular Degeneration
BCVA | Best-Corrected Visual Acuity
BSCVA | Best Spectacle-Corrected Visual Acuity
CCT | Center for Clinical Trials
CES-D | Center for Epidemiologic Studies Depression Scale
CI | Confidence Interval
CNV | Choroidal Neovascularisation
CRVO | Central Retinal Vein Occlusion
CSS | Cataract Symptom Score
D | Diopters
DORS | Diagnostic Odds Ratio
ETDRS | Early Treatment Diabetic Retinopathy Study
FDA | Food and Drug Administration
GDS | Geriatric Depression Scale
IOL | Intraocular Lenses
KQ | Key Question
LASEK | Laser Assisted Sub-Epithelial Keratomileusis
LASIK | Laser Assisted in Situ Keratomileusis
LOCS | Lens Opacities Classification System
logMAR | Logarithmic Minimum Angle of Resolution
MI | Myocardial infarction
MMSE | Mini-Mental State Examination
NA | Not Applicable
NEI-VFQ | National Eye Institute Visual Functioning Questionnaire
NHANES | National Health and Nutrition Examination Survey
NHVQoL | Nursing Home Vision-Targeted Health-Related Quality of Life Questionnaire
NLR | Negative Likelihood Ratio
NNH | Number-Needed-to-Harm
NNT | Number-Needed-to-Treat
NR | Not Relevant
OR | Odds Ratio
PCO | Posterior Capsule Opacification
PCT | Placebo Controlled Trial
PDT | Photodynamic Therapy
PLR | Positive Likelihood Ratio
PRK | Photorefractive Keratectomy
QoL | Quality of Life
RCT | Randomized Controlled Trial
RR | Relative Risk
SD | Standard Deviation
SF-36 | Medical Outcomes Study - Short Form Health Survey 36
TAP | Treatment of Age-Related Macular Degeneration With Photodynamic Therapy
UCVA | Uncorrected Visual Acuity
US | United States
USPSTF | United States Preventive Services Task Force
VECAT | Vitamin E, Cataract and Age-Related Maculopathy Study
VEGF | Vascular Endothelial Growth Factor
VF-14 | Health survey questionnaire designed for ophthalmology. “VF” stands for Visual Function, and “14” refers to the 14 questions in the main section of the questionnaire.
VIM | Visudyne in Minimally Classic Choroidal Neovascularisation Trial
VIP | Verteporfin in Photodynamic Therapy