# References

1 The Eye Diseases Prevalence Research Group. Causes and prevalence of visual impairment among adults in the United States. Arch Ophthalmol. 2004;122:477-485. [pmid: 15078664].
2 U.S. Preventive Services Task Force. Chapter 33. Screening for Visual Impairment. Guide to Clinical Preventive Services. Second ed. Rockville, MD: Agency for Healthcare Research and Quality, 1996. Available at: http://www.ahrq.gov/clinic/2ndcps/visual.pdf. Assessed: May 2008.
3 Munoz B, West SK, Rubin GS, et al. Causes of blindness and visual impairment in a population of older Americans: The Salisbury Eye Evaluation Study. Arch Ophthalmol. 2000;118(6):819-825. [pmid: 10865321].
4 Vitale S, Cotch MF, Sperduto RD. Prevalence of visual impairment in the United States. JAMA. 2006;295:2158-2163. [pmid: 16684986].
5 Norris SL, Kansagara D, Bougatsos C, et al. Screening for Type 2 Diabetes Mellitus: Update of 2003 Systematic Evidence Review for the US Preventive Services Task Force. Evidence Synthesis No. 61. Rockville, MD: Agency for Healthcare Research and Quality, 2008. Available at: http://www.ahrq.gov/clinic/uspstf08/type2/type2es.pdf. Assessed June 25, 2008.
6 Fleming C, Whitlock E, Beil T, et al. Primary Care Screening for Ocular Hypertension and Primary Open-Angle Glaucoma: Evidence Synthesis. Evidence Synthesis No. 34. Rockville, MD: Agency for Healthcare Research and Quality, March 2005: Available at: http://www.ahrq.gov/clinic/uspstf05/glaucoma/glaucsyn.pdf. Accessed: May 2008.
7 Lee DJ, Gomez-Marin O, Lam BL, et al. Trends in visual acuity impairment in U.S. adults. Arch Ophthalmol. 2004;122:506-509. [pmid: 15078667].
8 Owsley C, McGwin G, Scilley K, et al. The visual status of older persons residing in nursing homes. Arch Ophthalmol. 2007;125(7):925-930. [pmid: 17620572].
9 Tielsch JM, Javitt JC, Coleman A, et al. The prevalence of blindness and visual impairment among nursing home residents in Baltimore. N Engl J Med. 1995;332:1205-1209. [pmid: 7700315].
10 Haymes SA, Johnston AW, Heyes AD. Relationship between vision impairment and ability to perform activities of daily living. Ophthalmic Physiol Opt. 2002;22(2):79-91. [pmid: 12014491].
11 Klein BEK, Moss SE, Klein R, et al. Associations of visual function with physical outcomes and limitations 5 years later in an older population: The Beaver Dam Eye Study. Ophthalmology. 2003;110(4):644-650. [pmid: 12689880].
12 Rubin G, Roche KB, Prasada-Rao P, et al. Visual Impairment and disability in older adults. Optom Vis Sci. 1994;71:750-760. [pmid: 7898882].
13 West SK, Munoz B, Rubin GS, et al. Function and visual impairment in a population-based study of older adults. The SEE project. Salisbury Eye Evaluation. Invest Ophthalmol Vis Sci. 1997;38(1):72-82. [pmid: 9008632].
14 Ivers RQ, Cumming RG, Mitchell P, et al. Visual impairment and falls in older adults: the Blue Mountains Eye Study. J Am Geriatr Soc. 1998;46:58-64. [pmid: 9434666].
15 Lord SR, Dayhew J. Visual risk factors for falls in older people. J Am Geriatr Soc. 2001;49(5):508-515. [pmid: 11380741].
16 McGwin G Jr, Chapman V, Owsley C. Visual risk factors for driving difficulty among older drivers. Accid Anal Prev. 2000;32(6):735-744. [pmid: 10994600].
17 Owsley C, Stalvey B, Wells J, et al. Older drivers and cataract: driving habits and crash risk. J Gerontol A Biol Sci Med Sci. 1999;54:M203-M211. [pmid: 10219012].
18 Sims RV, Owsley C, Allman RM, et al. A preliminary assessment of the medical and functional factors associated with vehicle crashes by older adults. J Am Geratr Soc. 1998;46:556-561.
19 Cugati S, Cumming RG, Smith W, et al. Visual impairment, age-related macular degeneration, cataract, and long-term mortality. Arch Ophthalmol. 2007;125:917-924. [pmid: 17620571].
20 Knudtson MC, Klein BEK, Klein R. Age-related eye disease, visual impairment, and survival. The Beaver Dam Eye Study. Arch Ophthalmol. 2006;124:243-249. [pmid: 16476894].
21 Lee DJ, Gomez-Marin O, Lam BL, et al. Visual acuity impairment and mortality in U.S. adults. Arch Ophthalmol. 2002;120:1544-1550. [pmid: 12427070].
22 McCarty CA, Nanjan MB, Taylor HR. Vision impairment predicts 5 year mortality. Br J Ophthalmol. 2001;85:322-326. [pmid: 11222339].
23 McGwin G Jr, Owsley C, Gauthreaux S. The association between cataract and mortality among older adults. Ophthalmic Epidemiol. 2003;10(2):107-119. [pmid: 12660859].
24 Wang JJ, Mitchell P, Simpson JM, et al. Visual impairment, age-related cataract, and mortality. Arch Opthalmol. 2001;119:1186-1190.
25 West SK, Munoz B, Istre J, et al. Mixed lens opacities and subsequent mortality. Arch Ophthalmol. 2000;118:393-397. [pmid: 10721963].
26 Borger PH, van Leeuwen R, Hulsman CAA, et al. Is there a direct association between age-related eye disease and mortality?. Ophthalmology. 2003;110:1292-1296. [pmid: 12867381].
27 Thiagarajan M, Evans JR, Smeeth L, et al. Cause-specific visual impairment and mortality: results from a population-based study of older people in the United Kingdom. Arch Ophthalmol. 2005;123(10):1397-1403. [pmid: 16219731].
28 The Eye Diseases Prevalence Research Group. The prevalence of refractive errors among adults in the United States, Western Europe, and Australia. Arch Ophthalmol. 2004;122(4):495-505. [pmid: 15078666].
29 The Eye Diseases Prevalence Research Group. Prevalence of cataract and pseudophakia/aphakia among adults in the United States. Arch Ophthalmol. 2004;122:487-494. [pmid: 15078665].
30 The Eye Diseases Prevalence Research Group. Prevalence of age-related macular degeneration in the United States. Arch Ophthalmol. 2004;122:564-572. [pmid: 15078675].
31 Hyman L. Myopic and hyperopic refractive error in adults: an overview. Ophthalmic Epidemiol. 2007;14(4):192-197. [pmid: 17896297].
32 Asbell PA, Dualan I, Mindel J, et al. Age-related cataract. Lancet. 2005;365:599-609. [pmid: 15708105].
33 de Jong PTVM. Age-related macular degeneration. N Engl J Med. 2006;355:1474-1485. [pmid: 17021323].
34 Congdon NG. Prevention strategies for age related cataract. Br J Ophthalmol. 2001;85:516-520. [pmid: 11316704].
35 West SK, Valmadrid CT. Epidemiology of risk factors for age-related cataracts. Surv Ophthalmol. 1995;39:323-334. [pmid: 7725232].
36 Sommer A, Tielsch JM, Katz J, et al. Racial differences in the cause-specific prevalence of blindness in East Baltimore. N Engl J Med. 1991;325:1412-1417. [pmid: 1922252].
37 Smith W, Assink J, Klein R, et al. Risk factors for age-related macular degeneration. Pooled findings from three continents. Ophthalmology. 2001;108:697-704. [pmid: 11297486].
38 Canadian Task Force guideline. Canadian Task Force on Preventive Health Care. Screening for visual problems among elderly patients. 1995 Update: Available at: http://www.ctfphc.org/Tables_printable/Visual_tab.htm; Accessed: May 2008.
39 Virgili G, Acosta R. Reading aids for adults with low vision. Cochrane Database Syst Rev. 2008;1.
40 Riaz Y, Mehta JS, Wormald R, et al. Surgical interventions for age-related cataract. Cochrane Database Syst Rev. 2008;1.
41 Christen W, Glynn R, Sperduto R, et al. Age-related cataract in a randomized trial of beta-carotene in women. Ophthalmic Epidemiol. 2004;11(5):401-412. [pmid: 15590586].
42 Christen WG, Manson JE, Glynn RJ, et al. A randomized trial of beta carotene and age-related cataract in US physicians. Arch Ophthalmol. 2003;121(3):372-378. [pmid: 12617708].
43 Evans JR. Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration. Cochrane Database Syst Rev. 2008(1).
44 McNeil JJ, Robman L, Tikellis G, et al. Vitamin E supplementation and cataract: randomized controlled trial. Ophthalmology. 2004;111(1):75-84. [pmid: 14711717].
45 Virgili G, Bini A. Laser photocoagulation for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
46 Gohel PS, Mandava N, Olson JL, et al. Age-related macular degeneration: an update on treatment. Am J Med. 2008;121(4):279-281. [pmid: 18374683].
47 Iu L, Kwok A. An update of treatment options for neovascular age-related macular degeneration. Hong Kong Med. 2007;13(6):460-470.
48 Geltzer A, Turalba A, Vedula SS. Surgical implantation of steroids with antiangiogenic characteristics for treating neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
49 Reddy U, Krzystolik M. Antiangiogenic therapy with interferon alfa for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
50 Sivagnanavel V, Evans JR, Ockrim Z, et al. Radiotherapy for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
51 Loewenstein JI, Palmberg PF, Connett JE, et al. Effectiveness of a pinhole method for visual acuity screening. Arch Ophthamol. 1985;103:222-223.
52 Melki SA, Safar A, Martin J, et al. Potential acuity pinhole: a simple method to measure potential visual acuity in patients with cataracts, comparison to potential acuity meter. Ophthalmology. 1999;106(7):1262-1267. [pmid: 10406603].
53 Amsler M. Earliest symptoms of diseases of the macular. Br J Ophthalmol. 1953;37:521-537. [pmid: 13081950].
54 Fine AM. Earliest symptoms caused by neovascular membranes in the macular. Arch Opthalmol. 1986;104:513-514.
55 Fine SL. Early detection of extrafoveal neovascular membranes by daily central field evaluation. Ophthalmology. 1985;92:603-609. [pmid: 2409502].
56 Haase KW, Bryant EE. Development of a scale designed to measure functional distance vision loss using an interview technique. Porc Am Stat Assoc. 1973(SS):274–279.
57 Zheng X, Saaddine JB, Lee PP, et al. Eye care in the United States. Do we deliver to high-risk people who can benefit most from it?. Arch Opthalmol. 2007;125:411-418.
58 American Academy of Family Physicians. Recommended Clinical Preventive Services for Adult Men, April 2006. Available at: http://www.aafp.org/online/etc/medialib/aafp_org/documents/clinical/CPS/Men_Age_Chart.Par.0001.File.tmp/agechart_men.pdf. Accessed: May 2008.
59 American Academy of Family Physicians. Recommended Clinical Preventive Services for Adult Women, March 2007. Available at: http://www.aafp.org/online/etc/medialib/aafp_org/documents/clinical/CPS/Women_Age_Chart.Par.0001.File.tmp/agechart_women.pdf. Accessed: May 2008.
60 American Academy of Ophthalmology. Preferred Pattern Guidelines. Comprehensive adult medical eye evaluation. San Francisco, CA: American Academy of Ophthalmology, 2005. Available at: http://www.aao.org/education/guidelines/ppp/upload/Comprehensive_Adult_Medical_Eye_Evaluation-2.pdf. Accessed: May 2008.
61 American Optometric Association Consensus Panel on Comprehensive Adult Eye and Vision Examination. Practice Guideline. Comprehensive Adult Eye and Vision Examination. Reference Guide for Clinicians. Second Edition, 2005. Available at: http://www.aoa.org/documents/CPG-1.pdf. Accessed: May 2008.
62 Whitlock EP, Lin JS, Chou R, et al. Using existing systematic reviews in complex systematic reviews. Ann Intern med. 2008;148:776-782. [pmid: 18490690].
63 Harris RP, Helfand M, Woolf SH, et al. Current methods of the third US Preventive Services Task Force. Am J PrevMed. 2001;20(3S):21-35.
64 Campbell MK, Elbourne DR, Altman DG, et al. CONSORT statement: extension to cluster randomised trials. BMJ. 2004;328:702-708. [pmid: 15031246].
65 Jaeschke R, Guyatt GH, Sackett DL. Users' guides to the medical literature. III. How to use an article about a diagnostic test. B. What are the results and will they help me in caring for my patients? The Evidence-Based Medicine Working Group. JAMA. 1994;271:703-707. [pmid: 8309035].
66 Eekhof J, De Bock G, Schaapveld K, et al. Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. 2000;17(4):329-333. [pmid: 10934182].
67 Moore AA, Siu A, Partridge JM, et al. A randomized trial of office-based screening for common problems in older persons. Am J Med. 1997;102(4):371-378. [pmid: 9217619].
68 Smeeth L, Fletcher AE, Hanciles S, et al. Screening older people for impaired vision in primary care: cluster randomised trial. BMJ. 2003;327(7422):1027. [pmid: 14593039].
69 Cumming RG, Ivers R, Clemson L, et al. Improving vision to prevent falls in frail older people: a randomized trial. J Am Geriatr Soc. 2007;55(2):175-181. [pmid: 17302652].
70 Sloan FA, Picone G, Brown DS, et al. Longitudinal Analysis of the Relationship Between Regular Eye Examinations and Changes in Visual and Functional Status. J Am Geriatr Soc. 2005;53(11):1867-1874. [pmid: 16274366].
71 Taylor HR, Vu HT, McCarty CA, et al. The need for routine eye examinations. Invest Ophthalmol Vis Sci. 2004;45(8):2539-2542. [pmid: 15277474].
72 Smeeth L, Iliffe S. Community screening for visual impairment in the elderly. Cochrane Database Syst Rev. 2008;1.
73 Stone DH, Shannon DJ. Screening for impaired visual acuity in middle age in general practice. BMJ. 1978;2(6141):859-861. [pmid: 709095].
74 Ariyasu RG, Lee PP, Linton KP, et al. Sensitivity, specificity, and predictive values of screening tests for eye conditions in a clinic-based population. Ophthalmology. 1996;103(11):1751-1760. [pmid: 8942866].
75 Eekhof JA, De Bock GH, Schaapveld K, et al. Screening for hearing and visual loss among elderly with questionnaires and tests: which method is the most convincing for action?. Scand J Prim Health Care. 2000;18(4):203-207. [pmid: 11205087].
76 Hiller R, Krueger DE. Validity of a survey question as a measure of visual acuity impairment. Am J Public Health. 1983;73:93-96. [pmid: 6848004].
77 Ivers RQ, Optom B, Macaskill P, et al. Sensitivity and specificity of tests to detect eye disease in an older population. Ophthalmology. 2001;108(5):968-975. [pmid: 11320029].
78 McMurdo M, Baines P. The detection of visual disability in the elderly. Health Bulletin. 1988;46(6):327-329. [pmid: 3240947].
79 Teh RC, Lim WS. Utility of a patient-response screening question for visual impairment. J Am Geriatr Soc. 2006;54(2):370-372. [pmid: 16460398].
80 Wang F, Tielsch JM, Ford DE, et al. Evaluation of screening schemes for eye disease in a primary care setting. Ophthalmic Epidemiol. 1998;5(2):69-82. [pmid: 9672907].
81 Woods RL, Tregear SJ, Mitchell RA. Screening for ophthalmic disease in older subjects using visual acuity and contrast sensitivity. Ophthalmology. 1998;105(12):2318-2326. [pmid: 9855166].
82 Pollack AL, Brodie SE. Diagnostic yield of the routine dilated fundus examination. Ophthalmology. 1998;105(2):382-386. [pmid: 9479303].
83 Coleman AL, Yu F, Keeler E, et al. Treatment of uncorrected refractive error improves vision-specific quality of life. J Am Geriatr Soc. 2006;54(6):883-890. [pmid: 16776781].
84 Owsley C, McGwin G Jr, Scilley K, et al. Effect of refractive error correction on health-related quality of life and depression in older nursing home residents. Arch Ophthalmol. 2007;125(11):1471-1477. [pmid: 17998508].
85 Murray A, Jones L, Milne A, et al. A systematic review of the safety and efficacy of elective photorefractive surgery for the correction of refractive error. Health Services Research Unit: Department of Health Services, Research School of Health and Related Research; 2005.
86 McDonnell PJ, Mangione C, Lee P, et al. Responsiveness of the National Eye Institute Refractive Error Quality of Life instrument to surgical correction of refractive error. Ophthalmology. 2003;110(12):2302-2309. [pmid: 14644711].
87 Schein OD, Vitale S, Cassard SD, et al. Patient outcomes of refractive surgery. The refractive status and vision profile. J Cataract Refract Surg. 2001;27(5):665-673. [pmid: 11377893].
88 Tahzib N, Bootsma S, Eggink A, et al. Functional outcomes and patient satisfaction after laser in situ keratomileusis for correction of myopia. J Cataract Refract Surg. 2005;31:1943-1951. [pmid: 16338565].
89 Smith HJ, Dickinson CM, Cacho I, et al. A randomized controlled trial to determine the effectiveness of prism spectacles for patients with age-related macular degeneration. Arch Ophthalmol. 2005;123(8):1042-1050. [pmid: 16087836].
90 Scott IU, Smiddy WE, Schiffman J, et al. Quality of life of low-vision patients and the impact of low-vision services. Am J Ophthalmol. 1999;128(1):54-62. [pmid: 10482094].
91 Powe N, Schein O, Gieser S, et al. Synthesis of the literature on visual acuity and complications following cataract extraction with intraocular lens implantation. Arch Opthalmol. 1994;112(2):239-252.
92 Powe N, Tielsch J, Schein O, et al. Rigor of research methods in studies of the effectiveness and safety of cataract extraction with intraocular lens implantation. Arch Opthalmol. 1994;112:228-238.
93 Desai P, Minassian D, Reidy A. National cataract surgery survey 1997-1998: a report of the results of the clinical outcomes. Br J Ophthalmol. 1999;83:1336-1340. [pmid: 10574810].
94 Schein O, Steinberg E, Tielsch J, et al. Predictors of outcome in patients who underwent cataract surgery. Ophthalmology. 1995;102:817-823. [pmid: 7777281].
95 Westcott M, Tuft S, Minassian D. Effect of age on visual outcome following cataract extraction. Br J Ophthalmol. 2000;84:1380-1382. [pmid: 11090477].
96 Lundstrom M, Stenevi U, Thorburn W. Cataract surgery in the very elderly. J Cataract Refract Surg. 2000;26(3):408-414. [pmid: 10713238].
97 Owsley C, McGwin G Jr, Scilley K, et al. Impact of cataract surgery on health-related quality of life in nursing home residents. Br J Ophthalmol. 2007;91(10):1359-1363. [pmid: 17522143].
98 Steinberg E, Tielsch J, Schein O, et al. National study of cataract surgery outcomes: variation in 4-month postoperative outcomes as reflected in multiple outcome measures. Ophthalmology. 1994;101:1131-1140. [pmid: 8008355].
99 Mangione C, Phillips R, MG L, et al. Improved visual function and attenuation of declines in health-related quality of life after cataract extraction. Arch Opthalmol. 1994;112:1419-1425.
100 Brenner M, Curbow B, Javitt J, et al. Vision change and quality of life in the elderly; response to cataract surgery and treatment of other chronic ocular conditions. Arch Opthalmol. 1993;111:680-685.
101 Applegate W, Miller S, Elam J, et al. Impact of cataract surgery with lens implantation on vision and physical function in elderly patients. JAMA. 1987;257:1064-1066. [pmid: 3806895].
102 Bernth-Petersen P. Outcome of cataract surgery. A prospective, observational study. Acta Ophthalmol. 1982;60:235-242. [pmid: 7136534].
103 Bergman B, Nilsson-Ehle H, Sjostrand J. Ocular changes, risk markers for eye disorders and effects of cataract surgery in elderly people: a study of an urban Swedish population followed from 70 to 97 years of age. Acta Ophthalmol Scand. 2004;82(2):166-174. [pmid: 15043535].
104 Monestam E, Wachmeister L. Impact of cataract surgery on the visual ability of the very old. Am J Ophthalmol. 2004;137(1):145-155. [pmid: 14700658].
105 McGwin G Jr, Li J, McNeal S, et al. The impact of cataract surgery on depression among older adults. Ophthalmic Epidemiol. 2003;10(5):303-313. [pmid: 14566631].
106 Harwood RH, Foss AJE, Osborn F, et al. Falls and health status in elderly women following first eye cataract surgery: a randomised controlled trial. Br J Ophthalmol. 2005;89(1):53-59. [pmid: 15615747].
107 Foss A, Harwood R, Osborn F, et al. Falls and health status in elderly women following second eye cataract surgery: a randomised controlled trial. Age Ageing. 2006;35(1):66-71. [pmid: 16364936].
108 Owsley C, McGwin G Jr, Sloane M, et al. Impact of Cataract Surgery on Motor Vehicle Crash Involvement by Older Adults. JAMA. 2002;288(7):841-849. [pmid: 12186601].
109 Chylack L Jr, Brown N, Bron A, et al. The Roche European American Cataract Trial (REACT): a randomized clinical trial to investigate the efficacy of an oral antioxidant micronutrient mixture to slow progression of age-related cataract. Ophthalmic Epidemiol. 2002;9(1):49-80. [pmid: 11815895].
110 Chiu CJ, Taylor A. Nutritional antioxidants and age-related cataract and maculopathy. Exp Eye Res. 2007;84(2):229-245. [pmid: 16879819].
111 Christen W, Glynn R, Chew E, et al. Vitamin E and age-related cataract in a randomized trial of women. Ophthalmology. 2008;115(5):822-829. e821. [pmid: 18067963].
112 Cabello A, Maraini G. Clinical Trial of Nutritional Supplement Study Group, et al. A randomized, double-masked, placebo-controlled clinical trial of multivitamin supplementation for age-related lens opacities. Clinical trial of nutritional supplements and age-related cataract report no. 3. Ophthalmology. 2008;115(4):599-607. [pmid: 18387406].
113 AREDS, Age-Related Eye Disease Study Research Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E and beta carotene for age-related cataract and vision loss: AREDS report no. 9. Arch Ophthalmol. 2001;119(10):1439-1452. [pmid: 11594943].
114 AREDS, Age-Related Eye Disease Study Research Group. A randomized, placebo-controlled, clinical trial of high-dose supplementation with vitamins C and E, beta carotene, and zinc for age-related macular degeneration and vision loss: AREDS report no. 8. Arch Ophthalmol. 2001;119(10):1417-1436. [pmid: 11594942].
115 Garrett S, McNeil J, Silagy C, et al. Methodology of the VECAT study: vitamin E intervention in cataract and age-related maculopathy. Ophthalmic Epidemiol. 1999;6(3):195-208. [pmid: 10487974].
116 Holz F, Wolfensberger T, Piguet B, et al. Oral zinc-therapy in age-related macular degeneration: a double-blind study (abstract). Ger J of Ophthalmol. 1993;2:391.
117 Wang H, Li RX, Wang MF. Effects of zinc and antioxidant on visual function of patients with age-related macular degeneration. Zhongguo Linchuant Kangfu. 2004;8:1290-1291.
118 Newsome D, Swartz M, Leone N, et al. Oral zinc in macular degeneration. Arch Ophthalmol. 1988;106(2):192-198. [pmid: 3277606].
119 Richer S. Multicenter ophthalmic and nutritional age-related macular degeneration study-part 1: design, subjects and procedures. J Am Optom Assoc. 1996;67:12-29. [pmid: 8825016].
120 Richer S. Multicenter ophthalmic and nutritional age-related macular degeneration study — part 2: antioxidant intervention and conclusion. J Am Optom Assoc. 1996;67(1):30-49. [pmid: 8825017].
121 Richer S, Stiles W, Statkute L, et al. Double-masked, placebo-controlled, randomized trial of lutein and antioxidant supplementation in the intervention of atrophic age-related macular degeneration: the Veterans LAST study (Lutein Antioxidant Supplementation Trial). Optometry. 2004;75(4):216-230. [pmid: 15117055].
122 Stur M, Tittl M, Reitner A, et al. Oral zinc and the second eye in age-related macular degeneration. Invest Ophthalmol Vis Sci. 1996;37(7):1225-1235. [pmid: 8641826].
123 Kaiser H, Flammer J, Stumpfig D, et al. Visaline in the treatment of age-related macular degeneration: a pilot study. Ophthalmologica. 1995;209(6):302-305. [pmid: 8751336].
124 Feher J, Kovacs B, Kovacs I, et al. Improvement of visual functions and fundus alterations in early age-related macular degeneration treated with a combination of acetyl-L-carnitine, n-3 fatty acids, and coenzyme Q10. Ophthalmologica. 2005;219(3):154-166. [pmid: 15947501].
125 Trumbo PR, Ellwood KC. Lutein and zeaxanthin intakes and risk of age-related macular degeneration and cataracts: an evaluation using the Food and Drug Administration's evidence-based review system for health claims. Am J Clin Nutr. 2006;84(5):971-974. [pmid: 17093145].
126 Evans JR. Ginkgo Biloba extract for age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
127 Pulido JS, Winters JL, Boyer D. Preliminary analysis of the final multicenter investigation of rheopheresis for age related macular degeneration trial (MIRA-1) results. Trans Am Ophthalmol Soc. 2006;104:221-231. [pmid: 17471343].
128 Macular Photocoagulation Study Group. Argon laser photocoagulation for senile macular degeneration. Results of a randomized clinical trial. Arch Ophthalmol. 1982;100(6):912-918. [pmid: 7046707].
129 Macular Photocoagulation Study Group. Krypton laser photocoagulation for neovascular lesions of age-related macular degeneration. Results of a randomized clinical trial. Arch Ophthalmol. 1990;108(6):816-824. [pmid: 1693496].
130 Macular Photocoagulation Study Group. Laser photocoagulation of subfoveal neovascular lesions in age-related macular degeneration. Results of a randomized clinical trial. Arch Ophthalmol. 1991;109(9):1220-1231. [pmid: 1718250].
131 Macular Photocoagulation Study Group. Laser photocoagulation of subfoveal recurrent neovascular lesions in age-related macular degeneration. Results of a randomized clinical trial. Arch Ophthalmol. 1991;109(9):1232-1241. [pmid: 1718251].
132 Moorfields, The Moorfields Macular Study Group. Treatment of senile disciform macular degeneration: a single-blind randomised trial by argon laser photocoagulation. Br J Ophthalmol. 1982;66(12):745-753. [pmid: 6184070].
133 Meads C, Salas C, Roberts T, et al. Clinical effectiveness and cost-utility of photodynamic therapy for wet age-related macular degeneration: a systematic review and economic evaluation. Health Technol Assess. 2003;7(9).
134 Wormald R, Evans J, Smeeth L, et al. Photodynamic therapy for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008;1.
135 Treatment of age-related macular degeneration with photodynamic therapy (TAP) Study Group. Photodynamic therapy of subfoveal choroidal neovascularization in age-related macular degeneration with verteporfin: one-year results of 2 randomized clinical trials—TAP report. Arch Ophthalmol. 1999;117(10):1329-1345. [pmid: 10532441].
136 Verteporfin in Photodynamic Therapy Study Group. Photodynamic therapy of subfoveal choroidal neovascularization in pathologic myopia with verteporfin. 1-year results of a randomized clinical trial—VIP report no. 1. Ophthalmology. 2001;108(5):841-852. [pmid: 11320011].
137 Azab M, Boyer DS, Bressler NM, et al. Verteporfin therapy of subfoveal minimally classic choroidal neovascularization in age-related macular degeneration (VIM): 2-year results of a randomized clinical trial. Arch Ophthalmol. 2005;123(4):448-457. [pmid: 15824216].
138 Blumenkranz MS, Bressler NM, Bressler SB, et al. Verteporfin therapy for subfoveal choroidal neovascularization in age-related macular degeneration: three-year results of an open-label extension of 2 randomized clinical trials—TAP Report no. 5. Arch Ophthalmol. 2002;120(10):1307-1314. [pmid: 12365909].
139 Kaiser PK. Verteporfin therapy of subfoveal choroidal neovascularization in age-related macular degeneration: 5-year results of two randomized clinical trials with open-label extension. TAP Report No. 8. Graefe's Arch Clin Exp Ophthalmology. 2006;244:1132-1142.
140 Armbrecht AM, Aspinall P, Dhillon B. A prospective study of visual function and quality of life following PDT in patients with wet age related macular degeneration. Br J Ophthalmology. 2004;88:1270-1273.
141 Hewitt AW, Jeganathan VS, Kidd JE, et al. Influence of photodynamic therapy for age related macular degeneration upon subjective vision related quality of life. Graefes Arch Clin Exp Ophthalmol. 2006;244(8):972-977. [pmid: 16411103].
142 Vedula SS, Krzystolik MG. Antiangiogenic therapy with anti-vascular endothelial growth factor modalities for neovascular age-related macular degeneration. Cochrane Database Syst Rev. 2008(2).
143 Regillo CD, Brown DM, Abraham P, et al. Randomized, double-masked, sham-controlled trial of ranibizumab for neovascular age-related macular degeneration: PIER Study year 1. Am J Ophthalmol. 2008;145(2):239-248. [pmid: 18222192].
144 Gragoudas ES, Adamis AP, Cunningham ET, et al. Pegaptanib for neovascular age-related macular degeneration. N Engl J Med. 2004;351(27):2805-2816. [pmid: 15625332].
145 Rosenfeld PJ, Brown DM, Heier JS, et al. Ranibizumab for neovascular age-related macular degeneration. N Engl J Med. 2006;355(14):1419-1431. [pmid: 17021318].
146 Chang TS, Bressler NM, Fine JT, et al. Improved vision-related function after ranibizumab treatment of neovascular age-related macular degeneration: results of a randomized clinical trial. Arch Ophthalmol. 2007;125(11):1460-1469. [pmid: 17998507].
147 Leys A, Zlateva G, Shah S, et al. Quality of life in patients with age-related macular degeneration: results from the VISION study. Eye. 2007:1–7.
148 Brown DM, Kaiser PK, Michels M, et al. Ranibizumab versus verteporfin for neovascular age-related macular degeneration. N Engl J Med. 2006;355(14):1432-1444. [pmid: 17021319].
149 Antoszyk AN, Tuomi L, Chung CY, et al. Ranibizumab combined with verteporfin photodynamic therapy in neovascular age-related macular degeneration (FOCUS): year 2 results. Am J Ophthalmol. 2008;145(5):862-874. [pmid: 18321465].
150 Arias L, Garcia-Arumi J, Ramon JM, et al. Photodynamic therapy with intravitreal triamcinolone in predominantly classic choroidal neovascularization: one-year results of a randomized study. Ophthalmology. 2006;113(12):2243-2250. [pmid: 16996600].
151 Heier JS, Boyer DS, Ciulla TA, et al. Ranibizumab combined with verteporfin photodynamic therapy in neovascular age-related macular degeneration: year 1 results of the FOCUS Study. Arch Ophthalmol. 2006;124(11):1532-1542. [pmid: 17101999].
152 Gelisken F, Voelker M, Schwabe R, et al. Full macular translocation versus photodynamic therapy with verteporfin in the treatment of neovascular age-related macular degeneration: 1-year results of a prospective, controlled, randomised pilot trial (FMT-PDT). Graefes Arch Clin Exp Ophthalmol. 2007;245(8):1085-1095. [pmid: 17219106].
153 Luke M, Ziemssen F, Bartz-Schmidt KU, et al. Quality of life in a prospective, randomised pilot-trial of photodynamic therapy versus full macular translocation in treatment of neovascular age-related macular degeneration—a report of 1 year results. Graefes Arch Clin Exp Ophthalmol. 2007;245(12):1831-1836. [pmid: 17347809].
154 Miskala PH, Bass EB, Bressler NM, et al. Surgery for subfoveal choroidal neovascularization in age-related macular degeneration: quality-of-life findings: SST report no. 12. Ophthalmology. 2004;111(11):1981-1992. [pmid: 15522363].
155 Lord SR, Dayhew J, Howland A. Multifocal glasses impair edge-contrast sensitivity and depth perception and increase the risk of falls in older people. J Am Geriatr Soc. 2002;50(11):1760-1766. [pmid: 12410892].
156 Suchecki JK, Ehlers WH, Donshik PC. A comparison of contact lens-related complications in various daily wear modalities. Clao J. 2000;26(4):204-213. [pmid: 11071345].
157 Keay L, Stapleton F, Schein O, et al. Epidemiology of contact lens-related inflammation and microbial keratitis: a 20-year perspective. Eye Contact Lens. 2007;33(6 Pt 2):346-353. [pmid: 17975418].
158 Cheng KH, Leung SL, Hoekman HW, et al. Incidence of contact-lens-associated microbial keratitis and its related morbidity. Lancet. 1999;354(9174):181-185. [pmid: 10421298].
159 Nilsson SE, Montan PG. The annualized incidence of contact lens induced keratitis in Sweden and its relation to lens type and wear schedule: results of a 3-month prospective study. Clao J. 1994;20(4):225-230. [pmid: 7820916].
160 Schein OD, McNally JJ, Katz J, et al. The incidence of microbial keratitis among wearers of a 30-day silicone hydrogel extended-wear contact lens. Ophthalmology. 2005;112(12):2172-2179. [pmid: 16325711].
161 Chalmers RL, McNally JJ, Schein OD, et al. Risk factors for corneal infiltrates with continuous wear of contact lenses. Optom Vis Sci. 2007;84(7):573-579. [pmid: 17632304].
162 Findl O, Buehl W, Bauer P, et al. Interventions for preventing posterior capsule opacification. Cochrane Database Syst Rev. 2008;1.
163 Schaumberg DA, Dana MR, Christen WG, et al. A systematic overview of the incidence of posterior capsular opacification. Ophthalmology. 1998;105:1213-1221. [pmid: 9663224].
164 Taban M, Behrens A, Newcomb RL, et al. Acute endophthalmitis following cataract surgery. Arch Ophthalmol. 2005;123:613-620. [pmid: 15883279].
165 Johnson AR, Munoz A, Gottlieb JL, et al. High dose zinc increases hospital admissions due to genitourinary complications. J Urol. 2007;177(2):639-643. [pmid: 17222649].
166 VISION Clinical Trial Group. Pegaptanib sodium for neovascular age-related macular degeneration: two-year safety results of the two prospective, multicenter, controlled clinical trials. Ophthalmology. 2006;113(6):992-1001. e1006. [pmid: 16647134].
167 The HOPE HOPE-TOO Trial Investigators. Effects of long-term vitamin E supplementation on cardiovascular events and cancer: a randomized controlled trial. JAMA. 2005;293:1338-1347. [pmid: 15769967].
168 Omenn GS, Goodman GE, Thornquist MD, et al. Effects of a combination of beta carotene and vitamin A on lung cancer and cardiovascular disease. N Engl J Med. 1996;334:1150-1155. [pmid: 8602180].
169 The Alpha-Tocopherol Beta Carotene Cancer Prevention Study Group. The effect of vitamin E and beta carotene on the incidence of lung cancer and other cancers in male smokers. N Engl J Med. 1994;330:1029-1035. [pmid: 8127329].