# Discussion

Results of this evidence synthesis organized by KQ are summarized in Table 12.

Table 12 Summary Of Evidence

Number of studies: Overall quality rating | Limitations | Consistency | Primary care applicability | Summary of findings
KQ1 Overall effect of screening on final outcomes
4 RCTs: Fair quality | Vision screening assessed as part of a multicomponent intervention in most studies; methodological shortcomings in trials; fairly small numbers of trials | Consistent | High | Three cluster RCT's found no difference between vision screening and usual care, no vision screening, or delayed screening on vision and other clinical outcomes. One RCT found vision screening by an optometrist in frail elderly persons associated with an increased risk of falls (RR 1.57, 95% CI 1.20 to 2.05) and a trend towards increased risk of fractures (RR 1.74, 95% C I 0.97 to 3.11).
KQ2 Harms of screening
1 RCT: Fair quality | Not applicable | Not applicable | Not applicable | See KQ 1 for evidence on falls.
KQ3 Accuracy of screening
8 studies of diagnostic accuracy: Fair quality | Methodological shortcoming in trials; no studies assessing accuracy or utility of Amsler grid, fundoscopic examination, or pinhole testing in primary care settings | Consistent | Moderate (some studies conducted in mixed populations of younger and older adults or in non-primary care settings) | Four studies found that screening questions are not accurate for identifying persons with vision impairment compared to the Snellen chart. Four studies found that visual acuity testing is not accurate for identifying the presence of vision conditions compared to a detailed ophthalmologic examination. One study four that the Amsler grid is not accurate for identifying the presence of vision conditions compared to a detailed ophthalmologic examination. One very small (n=50) study found non-ophthalmologists are as accurate as ophthalmologists for identifying presence of cataracts.
KQ4 Treatment
Age-related macular degeneration (DRY)
7 RCTs: Fair quality | Conclusions are heavily influenced by results of one large trial | Some inconsistency | High | A large randomized trial found a multivitamin and zinc combination effective for slowing progression of ARMD (adjusted OR 0.68, 99% CI 0.49 to 0.93), though the difference in the likelihood of losing 15 or more letters of visual acuity was not statistically significant (adjusted OR 0.77, 95% CI 0.58 to 1.03).
Age-related macular degeneration (WET)
11 RCTs: Fair - good quality | Relatively small numbers of trials | Consistent | High | Laser photocoagulation: RR 0.67 for 6+ lines visual acuity loss; 95% CI 0.53 to 0.83, 5 RCTs (poor quality, but consistent). Photodynamic therapy: RR 0.22 for 3+ lines visual acuity loss, 95% CI 0.13 to 0.30, 3 RCTs (fair to good quality). Vascular endothelin growth factor inhibitors: RR 0.71, 95% CI 0.61 to 0.84, 2 RCTs for pegaptanib and RR 0.21, 95% CI 0.16–0.27, 2 RCTs for ranibizumab for 3+ lines visual acuity loss (fair to good quality).
Cataracts
3 RCTs, plus numerous observational studies: Fair quality | Two trials compared immediate to delayed cataract surgery for effects on falls; most observational studies have methodological shortcomings | Consistent | High | Numerous observational studies found that over 90% of patients achieve visual acuity 20/40 or better following cataract extraction and intraocular lens implantation. Three observational studies found cataract surgery associated with improved vision-related function. One trial found immediate first-eye cataract surgery associated with a decreased rate of second (but not first) fall compared to delayed surgery, resulting in a lower overall rate of falls (rate ratio 0.66, 95% CI 0.40 to 0.96, p=0.03), but a second trial found no effect of second-eye cataract surgery on falls.
Uncorrected refractive error
2 RCTs, 2 systematic reviews, plus numerous observational studies: Fair - good quality | Few trials comparing treatments for uncorrected refractive error versus placebo or no therapy | Consistent | High | In 1 large population-based study, 60% of older adults with vision impairment can achieve visual acuity 20/40 or better with refractive correction. Two RCTs found use of corrective lenses associated with improvements in vision-related function, but effects on overall function inconsistent. Numerous observational studies show that over 85% of patients achieve visual acuity 20/40 or better following photorefractive surgery for myopia or hyperopia.
KQ5 Harms of treatment
Age-related macular degeneration (DRY)
3 RCTs, 1 systematic review: Fair quality | Data on harms poorly reported | Consistent | High | The large AREDS trial found zinc associated with significantly increased risk of hospitalization for genitourinary causes compared to non-use of zinc (11.1% versus 7.6%; p=0.0003) and antioxidants associated with increased risk of yellow skin compared to non-use of antioxidants (8.3% vs. 6.0%, p=0.008).
Age-related macular degeneration (WET)
5 RCTs, 2 systematic reviews: Fair to good quality | Some data on harms are not yet published, data on long-term effects of photodynamic therapy and vascular endothelin growth factor inhibitors is limited | Consistent | High | Laser photocoagulation: Visual acuity loss ≥6 lines compared to observation 3 months after treatment (absolute rate 16.6%; relative risk 1.41 [95% CI 1.08 to 1.82], 5 trials). Photodynamic therapy: Increased risk of acute severe visual acuity loss (20 letter loss within 7 days of treatment) compared to placebo (2% vs. 0.2%, relative risk 0.02, 95% CI 0.01 to 0.03) and increased risk of infusion-related back pain compared to placebo (3.4% vs. 0.3%, relative risk 6.50, 95% CI 1.52 to 27.78). Vascular endothelin growth factor inhibitors: more cases of endophthalmitis and uveitis compared to placebo, but small numbers of events. No increase in risk of systemic hypertension or arterial thromboembolic events.
Cataracts
3 systematic reviews of observational studies: Fair quality | No data on harms from placebo-controlled trials | Some inconsistency in reported rates | High | Systematic reviews of numerous observational studies of cataract surgery found a pooled rate of posterior capsule opacification of 28% after 5 years, and a pooled rate of 0.13% for endophthalmitis.
Uncorrected refractive error
1 systematic review, 4 observational studies: Poor-fair quality | Little data on harms for corrective lenses; many observational studies did not report rates of harms associated with photorefractive surgery | Consistent | High | One small prospective study found multifocal lenses associated with a higher risk of falls in older adults compared to unifocal lenses (OR 2.09, 95% CI 1.06 to 4.92). Three studies found incidence of infectious keratitis ranges from 0.3 to 3.6 cases per 10,000 contact lens wearers; one study found incidence to be higher in persons over 50 years old. Corneal ectasia rates range from 0% to 0.87% in five studies of LASIK, keratitis rates range from 0% to 3.4% in 6 studies of LASIK and 4 studies of LASEK.

Abbreviations: AREDS = age-related eye disease study, CI = confidence interval, KQ = key question, LASEK = laser assisted sub-epithelial keratomileusis, LASIK = laser assisted in situ keratomileusis, RCT = randomized controlled study, RR = relative risk, SR = systematic review.

Impaired visual acuity is common in older adults, and effective treatments are available for common causes of impaired visual acuity. Nonetheless, direct evidence found that vision screening in asymptomatic older adults in primary care settings was not effective for improving visual acuity or other clinical outcomes. Additional studies are needed to determine why trials of vision screening have shown no benefit. For any vision screening program to be effective, optimal screening approaches and intervals need to be defined, and older adults with impaired visual acuity effectively linked to appropriate follow-up care.

Compared to the 1996 USPSTF evidence synthesis, ^2^ there is now more direct evidence on vision screening in older adults. Three fair- to good-quality cluster randomized trials that enrolled over 4700 patients found vision screening in older adults as part of a multi-component screening intervention in primary care settings to be no more effective than no vision screening, delayed screening, or usual care. ^66^ – ^68^ A fourth trial found optometrist screening associated with an increased risk of falls in frail elderly. ^69^ Although one prospective cohort study found more eye examinations over a 5-year period associated with superior visual and functional outcomes, its applicability to vision screening in primary care settings is unclear because reasons for the eye examinations and eye examination settings were not described. ^70^ There remains no evidence to evaluate optimal screening intervals in older adults.

Despite the lack of direct evidence to support vision screening, there is strong evidence on effectiveness of treatments for common causes of impaired visual acuity. As concluded by the 1996 USPSTF review, a very high proportion of patients experience favorable vision-related outcomes following treatment for impaired visual acuity due to refractive error and cataracts. ^2^ Over half of older adults with impaired visual acuity could achieve vision better than 20/40 with refractive correction, ^4^ which can be done noninvasively in most cases with corrective lenses. Correction of refractive error is also associated with improvement in vision-related quality of life. ^83,^ ^84^ In patients with cataracts, a large body of observational studies indicates that surgical extraction and intraocular lens implantation results in visual acuity of 20/40 or better in over 90% of patients, and is associated with improvements in vision-related quality of life. ^91^ For dry ARMD, there is evidence that antioxidant vitamins and minerals are effective for slowing progression of disease, ^43^ though conclusions are largely based on a single large trial (AREDS). ^114^ Antioxidants included in the AREDS formulation have been found to be associated with congestive heart failure (vitamin E ^167^ ) and lung cancer in smokers (beta-carotene ^168,^ ^169^ ) when prescribed for prevention of cancer or cardiovascular disease, though these harms were not observed in AREDS. For wet ARMD, VEGF inhibitors and PDT with verteporfin appear to be effective treatment options with a relatively low incidence of serious harms. ^134,^ ^142^ An important advantage of these treatments is that they are associated with less retinal scarring compared to laser photocoagulation, which is a particularly important consideration for patients with subfoveal (central) neovascularization.

Evidence on accuracy of screening tests for impaired visual acuity (or conditions associated with impaired visual acuity) is difficult to interpret. Although the Snellen remains the most widely used tool to measure visual acuity in primary care settings, no clinically relevant reference standard exists to determine its diagnostic accuracy, in part because the Snellen is often considered the standard for assessing visual acuity in clinical practice. Although some studies found Snellen testing inaccurate compared to a detailed ophthalmologic examination, the conditions identified on examination were not necessarily associated with impaired visual acuity. It is now known whether identification of ARMD or cataracts prior to the development of impaired visual acuity is associated with improved clinical outcomes compared to identification of these conditions after the development of early impaired visual acuity. As in the 1996 USPSTF evidence review, ^2^ evidence is consistent that no screening question is comparable in accuracy to tests of visual acuity. ^73,^ ^75,^ ^76,^ ^79,^ ^80^ There remains insufficient evidence to assess the accuracy or utility of pinhole testing, the Amsler grid, visual acuity tests other than the Snellen, physical examination, or fundoscopic examination.

## Limitations

Our evidence review has some potential limitations. First, we included relevant systematic reviews, and the reliability of systematic reviews depends on how well they are designed and conducted. We therefore only included systematic reviews meeting a quality threshold based on pre-defined criteria. ^62^ In addition, we verified data abstraction of the systematic reviews by independently abstracting and rating the quality of trials comparing an intervention to placebo, sham treatment, or no treatment. Second, we excluded non-English language studies, which could introduce language bias. However, we identified no relevant non-English language studies in literature searches or when searching reference lists. Third, when randomized trials were available, they were too few in number to perform assessments for publication bias. Finally, we did not attempt to construct outcomes tables, because the direct trials of screening found no benefits.

## Emerging Issues

A number of trials comparing different individual treatments and combination therapies for wet ARMD are currently in progress. ^142^ In October 2006, the National Eye Institute announced recruitment for the AREDS-2 trial, which will evaluate the benefits and harms of an antioxidant combination with reduced zinc and/or beta-carotene (http://areds-2.com/).

## Future Research

We identified several important gaps in the evidence on screening for impaired visual acuity in older adults. There is no direct evidence showing that vision screening in older adults is effective for improving visual outcomes or other clinical outcomes. Well-designed studies are needed to identify optimal methods for vision screening, define appropriate screening intervals, and develop effective strategies for linking older adults with vision impairment to appropriate care. Studies are needed on diagnostic accuracy and utility of fundoscopic examination, pinhole testing, the Amsler grid, and non-Snellen visual acuity charts in primary care settings for supplementing or replacing the Snellen visual eye chart. More studies are needed on potential harms (particularly long-term harms) of VEGF inhibitors and PDT for wet ARMD. Evidence on effectiveness of antioxidants and vitamins for dry ARMD is largely dependent on a single large trial reporting a post-hoc subgroup analysis, ^113^ and would be strengthened by similar findings from other, well-designed trials that are also designed to adequately evaluate potential harms such as congestive heart failure and lung cancer risk. More studies are needed to understand the potential association between correction of refractive errors and risk of falls, ^69^ and, if an association is present, to identify methods for falls prevention.

## Conclusions

Impaired visual acuity is common in older adults. There remains no direct evidence that vision screening in older adults in primary care settings is effective for improving visual acuity or other clinical outcomes, though evidence is limited to a relatively small number of trials in which vision screening was typically conducted as part of a multi-component assessment. ^66^ – ^68^ On the other hand, effective treatments are available for common causes of impaired visual acuity, and vision impairment can be identified non-invasively using the Snellen chart, though its diagnostic accuracy is difficult to estimate. Additional studies are needed to determine why direct studies of screening have been unable to demonstrate benefits despite the availability of effective treatments, to clarify the risk of potential unintended harms from screening (such as increased risk of falls), ^69^ and to define optimal intervals of screening. For any vision screening program to be effective, patients with impaired visual acuity must be linked to appropriate eye care and follow-up.