# Results

## Key Question 1. Does vision screening in asymptomatic older adults result in improved morbidity or mortality or improved quality of life?

### Summary

Three fair-quality cluster randomized trials (N=4,728) found vision screening in older adults as part of a multi-component screening intervention in primary care settings to be no more effective than no vision screening, delayed screening, or usual care for improving vision or functional outcomes. One fair-quality randomized trial (N=309) found vision screening by an optometrist in frail older adults associated with an increased risk of falls (rate ratio 1.57, 95% confidence interval [CI] 1.20 to 2.05) and a trend towards increased risk of fractures (rate ratio 1.74, 95% CI 0.97 to 3.11) compared to usual care. One prospective cohort study found an increased number of eye examinations over a five-year period associated with decreased risk of becoming unable to read newsprint and new functional limitations, but results do not appear to be directly applicable to vision screening in primary care settings. No study evaluates optimal vision screening intervals.

## Evidence

There is no direct evidence from randomized trials that screening for impaired visual acuity in asymptomatic older adults is associated with improved visual outcomes, function, or other clinical outcomes. Three fair- or fair-to-good quality cluster randomized trials (N=4,728) evaluated vision screening as part of a multi-component screening intervention (Table 3, Appendices C1 and C2). ^66^ – ^68^ Methodological shortcomings in all trials include lack of intention-to-treat analysis and unclear blinding status of outcomes assessors. Only one trial ^68^ applied a cluster correlation correction when analyzing results. ^64^ The screening intervention varied in the three trials: one trial compared visual acuity testing (Glasgow acuity chart followed by pinhole testing for persons with visual acuity worse than 6/18) to targeted screening; ^68^ one compared immediate vision screening to delayed vision screening (screening methods not described well, but appeared to include Snellen acuity chart, test of ability to read newspaper letters at 25 cm, and assessment of difficulty in recognizing a face at 4 m or reading a newspaper); ^66^ and the third compared use of a screening question followed by visual acuity testing if positive to usual care. ^67^ None of the trials found vision screening associated with improvements (or lower likelihood of deterioration) in vision, likelihood of vision disorders, or functional impairment related to vision at 6 months to up to 5 years after the intervention (Table 3).

Table 3 Randomized Controlled Trials of Vision Screening in Older Adults

Study, Year, Title | Screening intervention | Study design | Setting | Patient population | Results | Loss to follow-up | Quality score
Cumming et al, 2007 ^69^ Improving vision to prevent falls in frail older people | Visual acuity assessed with Early Treatment Diabetic Retinopathy Study Chart at 2.4 m; contrast sensitivity with the CSV-1000E Chart 1 at 2.4 m; visual fields with Humphrey automated visual field unit; Perkins applanation tonometer; intraocular pressure with slit lamp exam and direct ophthalmoscopy | Randomized controlled trial | Community based - patients received in-home care and/or at study clinic | 70 years or older n=616 Australia | Vision screening vs. no vision screening Falls: Rate ratio 1.57 (95% CI 1.20 to 2.05; p=0.001) Fractures: Relative risk 1.74 (95% CI 0.97 to 3.11) | 84/616 (14%) | Fair
Eekhof et al, 2000 ^66^ Effects of screening for disorders among the elderly: an intervention study in general practice | Assessment of difficulty in recognizing a face at 4 meters and/or reading normal letters in a newspaper, and/or impaired vision with both by Snellen eye chart or not being able to read normal newspaper letters at 25 cm distance | Cluster randomized controlled trial | Primary care clinic | 75 years or older n=1121 The Netherlands | Immediate versus delayed vision screening Visual disorder in 2nd year: 51% vs. 47% (p=0.68) | 16% (93/576) patients who underwent immediate screening did not participate in second year; otherwise unclear | Fair
Moore et al, 1997 ^67^ A randomized trial of office-based screening for common problems in older persons | Vision screening: Question to assess difficulty performing everyday activities, followed by Snellen eye chart if positive | Cluster randomized controlled trial | Primary care clinic | 70 years or older n=261 United States | Vision screening versus usual care Improvement in vision at 6 months: 20% (20/99) vs. 24% (31/131), p=0.45 | 12% (31/261) at 6 months | Fair
Smeeth et al, 2003 ^68^ Screening older people for impaired vision in primary care: a cluster randomized trial | Detailed health assessment by a trained nurse, including Glasgow eye chart and pinhole testing if visual acuity less than 6/18 in either eye (targeted screening only consisted of a brief health assessment) | Cluster randomized controlled trial | Primary care clinic | 75 years or older n=3249 United Kingdom | Universal vs. targeted vision screening: Visual acuity less than 6/18 in either eye at median 3.9 years: RR 1.07 (95% CI 0.84 to 1.36, p=0.58) National Eye Institute visual function questionnaire at median 3.9 years (mean score, 0 to 100 scale): 86.0 vs. 85.6 (p=0.69) | (1807/3249) did not complete outcome assessment (1465 deaths) | Good-Fair

Abbreviations: CI = confidence interval, RR = relative risk

In the highest quality (rated fair-to-good) trial, universal vision screening identified about 10 times as many patients with impaired visual acuity and correctable impairment in visual acuity compared to targeted screening, yet found no difference in the rate of visual acuity worse than 20/60 after 3 to 5 years of follow-up. ^68^ Reasons for the negative findings are not entirely clear. However, only half of the patients advised to see an eye care provider after vision screening actually received new glasses. In addition, short-term improvements in vision may have been missed because outcomes were assessed after a median of 3.9 years, though no difference in visual outcomes was seen in a subgroup with shorter time to assessment (1.6 to 3 years). Other reasons for lack of benefit in the screening trials may include high loss to follow-up (in part related to advanced age and mortality in enrollees), similar frequency of vision disorder detection and treatment in the screening and control groups in one trial, ^67^ and low uptake of recommended interventions in one trial. ^66^

One fair-quality trial found that vision screening by an optometrist in frail older adults (N=309) did not reduce risk of falls and fractures compared to usual care. ^69^ Screening included visual acuity testing using the Early Treatment Diabetic Retinopathy Study Chart, contrast sensitivity testing, visual field testing, assessment of intraocular pressure, slit lamp examination, and direct ophthalmoscopy. Screening led to new eyeglasses or referral for further treatment in about half (146/309; 47%) of the study's participants. After one year of follow-up, vision screening was associated with an increased risk of falls (rate ratio 1.57, 95% CI 1.20 to 2.05, p=0.01) and a trend towards increased risk of fractures (rate ratio 1.74, 95% CI 0.97 to 3.11, p=0.06) compared to usual care. Possible explanations for these results could be the need for a prolonged period of readjustment in frail older adults after receiving new eyeglasses, or increased activity or other behaviors following treatment for vision impairment that could place subjects at increased risk for falls.

One fair-quality prospective cohort study of Medicare beneficiaries aged 65 years or older found an association between the number of eye examinations over a 5 year period and the probability of experiencing vision decline and functional limitations. ^70^ However, the study did not meet inclusion criteria as its applicability to screening is unclear and may be limited. The study did not distinguish between eye examinations for the purpose of screening versus monitoring of known eye diseases or systemic conditions associated with eye diseases, or describe whether screening was performed in primary care settings or in eye clinics. Among persons enrolled in the study that developed blindness or low vision or became unable to read newsprint, approximately one-quarter carried diagnoses of diabetes or glaucoma. The study also did not compare results of subjects who underwent at least one eye examination versus those who underwent no eye examinations. Methodological limitations of the study include high loss to follow-up, unclear reporting of attrition, and failure to report baseline characteristics stratified by the number of eye examinations, making it difficult to assess comparability between groups or likelihood for residual confounding. The study found each additional year with an eye examination associated with a 12% decrease in the probability of becoming unable to read newsprint (p=0.03), a 5% decrease in the probability of an increased number of activities of daily living limitations (p=0.003), and 13% decrease in the probability of an increased number of instrumental activities of daily living limitations (p=0.002). The association between each additional year of eye examinations and decreased probability of onset of low vision or blindness was not statistically significant (0.9% decrease, p=0.06).

No study directly evaluated effects of screening for impaired visual acuity in asymptomatic older adults at different intervals. One cohort study found that following a normal baseline eye examination, the likelihood of experiencing no significant visual field or visual acuity loss after 5 years was 97% in persons aged 60 to 69 years old, and 93% in persons aged 70 to 79 years old. ^71^

We excluded a systematic review of community screening for impaired visual acuity in older adults because five of the six included trials evaluated multi-component screening interventions performed in the home (the sixth trial ^68^ is discussed above). ^72^ It found no benefit associated with community screening for impaired visual acuity. In addition, a trial of vision screening versus usual care was excluded because it only enrolled adults aged 40 to 64 years old. ^73^ Like the trials of screening in older adults, it found no significant differences between groups in vision outcomes.

## Key Question 2. Are there harms of vision screening in asymptomatic older adults?

### Summary

Data on harms from vision screening in older adults are sparse. None of the screening studies in primary care settings evaluated potential harms such as anxiety, complications of treatment, or exposure to unnecessary interventions due to false-positive screening tests. One trial reported an increased risk of falls following vision screening by an optometrist in frail older adults compared to usual care, and is described in more detail in KQ 1.

### Evidence

Potential harms associated with vision screening include anxiety, complications of treatment, or exposure to unnecessary interventions due to false-positive screening tests. However, none of the screening studies in primary care settings evaluated harms associated with vision screening. ^66^ – ^68,^ ^70^ One study, described in KQ 1, reported an increased risk of falls following screening by an optometrist. ^69^

## Key Question 3. What is the accuracy of screening for early impairment in visual acuity due to uncorrected refractive error, cataracts or age-related macular degeneration?

### Summary

Studies of diagnostic accuracy for various vision screening questions have methodological shortcomings, but four studies are consistent in showing that no screening question is accurate compared to visual acuity testing or a detailed ophthalmologic examination for identifying impaired visual acuity. Visual acuity tests (four studies) and the Amsler grid (one study) are associated with low diagnostic accuracy compared to a detailed ophthalmologic examination for identifying the presence of any underlying visual condition, including conditions not necessarily associated with impaired visual acuity. No study directly compared the diagnostic accuracy of the Snellen test to an established, clinical relevant reference standard for impaired visual acuity. No studies evaluated the accuracy of pinhole testing for differentiating impaired visual acuity due to correctable refractive error from impaired visual acuity due to other causes. One very small study found non-ophthalmologists able to identify cataracts on physical examination as accurately as ophthalmologists. No studies evaluated the accuracy of fundoscopic examination by primary care clinicians for identifying ARMD or other conditions.

### Evidence

Eight cross-sectional studies evaluated the accuracy of various diagnostic tests or screening questions for impaired visual acuity in older adults compared to a reference standard (Table 4, Appendices C3 and C4). ^74^ – ^81^ All of the studies had at least two methodological shortcomings. Only one study clearly reported independent interpretation of the reference standard, ^78^ only two studies clearly applied the reference standard to all patients, ^75,^ ^78^ and only one study reported sufficient data to determine that an appropriately broad spectrum of patients was evaluated. ^76^ Four of the eight studies (three ^75,^ ^76,^ ^79^ evaluated screening questions and one ^78^ compared geriatrician to ophthalmologic examination) reported diagnostic accuracy specifically in older adults; the remainder enrolled mixed populations of older and younger adults. One additional study did not meet inclusion criteria because it only enrolled patients aged 64 years and younger, but is discussed here contextually. ^73^

Table 4 Studies of Diagnostic Test Accuracy

Study, Year, Title | Type of study | Age of enrollees and sample size | Proportion with visual conditions | Reference standard | Index text | Quality score
Ariyasu et al, 1996 ^74^ Sensitivity, specificity, and predictive values of screening tests for eye conditions in a clinic-based population | Cross-sectional | “Most patients” 20 to 59 years old n=317 | 43% refractive error, 16% cataract, 4% macular degeneration, 4% strabismus, 2% amblyopia | Detailed ophthalmologic assessment | Amsler grid Near visual acuity Distance visual acuity | Poor-Fair
Eekhof et al, 2000 ^75^ Screening for hearing and visual loss among elderly with questionnaires and tests: which method is the most convincing for action? | Cross-sectional | 75 years or older n=1121 | Snellen chart <0.3: 10.8% | Snellen chart and low vision chart (testing vision at reading distance) | Screening questions | Fair
Hiller et al, 1983 ^76^ Validity of a survey question as a measure of visual acuity impairment | Cross-sectional | 25 to 74 years n=1466 for subgroup 65 to 74 years old | Snellen 20/25 or worse: 69% | Snellen chart | Screening question | Fair
Ivers et al, 2001 ^77^ Sensitivity and specificity of tests to detect eye disease in an older population | Cross-sectional | 49 years or older n=3654 | Posterior subcapsular cataract: 3.9%, cortical cataract: 19.1%, nuclear cataract: 47.0%; early ARMD 4.50%; refractive error 4.50%; any vision condition 34.50% | Detailed ophthalmologic assessment | Presenting distance visual acuity (logMAR chart) Pinhole distance visual acuity Presenting reading acuity (with current reading glasses) | Poor-Fair
McMurdo et al, 1988 ^78^ The detection of visual disability in the elderly | Cross-sectional | 64 to 97 years n=50 | 18% previously undiagnosed cataract; 8% previously undiagnosed ARMD | Ophthalmologist examination | Geriatrician examination | Fair
Teh et al, 2006 ^79^ Utility of a patient-response screening question for visual impairment | Cross-sectional | 60 years or older n=112 | Snellen 6/12 or worse: 81% | Snellen chart | Screening question | Poor-fair
Wang et al, 1998 ^80^ Evaluation of screening schemes for eye disease in a primary care setting | Cross-sectional | 40 years or older n=405 | 50.7% (13% cataract, ARMD and refractive error not reported) | Detailed ophthalmologic assessment | Screening questionnaire Presenting distance visual acuity, followed by pinhole visual acuity if worse than 20/30 | Poor-Fair
Woods et al, 1998 ^81^ Screening for ophthalmic disease in older subjects using visual acuity and contrast sensitivity | Cross-sectional | 50 years or older n=2522 | 12% (50 to 64 years) and 23% (>64 years) macular degeneration, 4.9% and 27.2% cataract | Detailed ophthalmologic assessment | Distance visual acuity (Snellen) Near visual acuity (Snellen) | Fair

Abbreviations: ARMD = age-related acular degeneration, CI = confidence interval, LogMAR = logarithmic minimum angle of resolution.

Screening questions or questionnaires. Four studies found various screening questions or questionnaires to have low accuracy for identifying impaired visual acuity compared to visual acuity testing ^75,^ ^76,^ ^79^ or a detailed ophthalmologic examination ^80^ (Table 5). No screening question or questionnaire was associated with both high sensitivity and specificity, resulting in weak PLRs and NLRs. PLRs for various screening questions or screening questionnaires ranged from 1.19 to 3.23, and NLRs ranged from 0.23 to 0.78. The DORs (PLR divided by NLR), a measure of the discriminating power of a diagnostic test, were also weak and ranged from 1.60 ^79^ to 9.45. ^75^ A study that did not meet inclusion criteria because it enrolled adults aged 40 to 64 years reported similar findings on accuracy of a screening question (PLR 3.99 [95% CI 3.09 to 5.15], NLR 0.77 [95% CI 0.71 to 0.84]). ^73^

Table 5 Studies of Diagnostic Test Accuracy, Results

Study, Year, Title | Reference standard | Target vision condition | Screening test | Sensitivity | Specificity | Positive likelihood ratio | Negative likelihood ratio | Diagnostic odds ratio
Amsler grid
Ariyasu et al, 1996 ^74^ Sensitivity, specificity, and predictive values of screening tests for eye conditions in a clinic-based population | Ophthalmologic examination | Any ocular disease, excluding refractive error | Amsler grid | 0.20 (0.14–0.27) | 0.88 (0.80–0.94) | 1.65 (0.90–3.06) | 0.91 (0.82–1.01) | 1.82 (0.90–3.69)
Physical examination
McMurdo et al, 1988 ^78^ The detection of visual disability in the elderly | Ophthalmologist examination | A: Cataract B: ARMD | Positive finding on physical examination | A: 1.0 (9/9) B: 0.75 (3/4) | A: 1.0 (41/41) B: 1.0 (46/46) | Not calculated | Not calculated | Not calculated
Screening questions
Eekhof et al, 2000 ^75^ Screening for hearing and visual loss among elderly with questionnaires and tests: which method is the most convincing for action? | Snellen chart | Visual acuity ≤ 0.3 (about 20/60 on Snellen) | Trouble recognizing face by questionnaire | 0.60 (0.51–0.69) | 0.82 (0.79–0.84) | 3.23 (2.66–3.93) | 0.49 (0.40–0.61) | 6.56 (4.42–9.72)
| | Difficulty with low vision chart at reading distance | Trouble reading newspaper by questionnaire | 0.83 (0.76–0.88) | 0.67 (0.64–0.70) | 2.47 (2.20–2.78) | 0.26 (0.18–0.37) | 9.45 (6.08–14.7)
Hiller et al, 1983 ^76^ Validity of a survey question as a measure of visual acuity impairment | Snellen chart | A: Visual acuity ≤ 20/50 B: Visual acuity ≤ 20/100 | Trouble seeing by questionnaire | A: 0.34 (0.28–0.41) B: 0.48 (0.32–0.63) | A: 0.84 (0.82–0.86) B: 0.82 (0.80–0.84) | A: 2.15 (1.72–2.69) B: 2.69 (1.94–3.74) | A: 0.78 (0.71–0.86) B: 0.64 (0.48–0.84) | A: 2.75 (2.00–3.78) B: 4.24 (2.33–7.72)
Teh et al, 2006 ^79^ Utility of a patient-response screening question for visual impairment | Snellen chart | Visual acuity ≤ 20/40 | Problem with vision by questionnaire | 0.68 (0.58–0.78) | 0.43 (0.22–0.66) | 1.19 (0.80–1.77) | 0.74 (0.42–1.33) | 1.60 (0.62–4.16)
Wang et al, 1998 ^80^ Evaluation of screening schemes for eye disease in a primary care setting | Ophthalmologic examination | Any ocular disease | A: Problem with vision by questionnaire B: Problem with vision by questionnaire followed by visual acuity ≤ 20/40 | A: 0.90 (0.85–0.94) B: 0.57 (0.50–0.64) | A: 0.44 (0.37–0.51) B: 0.79 (0.73–0.84) | A: 1.60 (1.41–1.83) B: 2.72 (2.03–3.65) | A: 0.23 (0.15–0.36) B: 0.54 (0.46–0.65) | A: 6.88 (4.06–11.7) B: 5.00 (3.23–7.74)
Visual acuity testing
Ariyasu et al, 1996 ^74^ Sensitivity, specificity, and predictive values of screening tests for eye conditions in a clinic-based population | Ophthalmologic examination | Any ocular disease, excluding refractive error | Near visual acuity ≤ 20/30 | 0.83 (0.75–0.89) | 0.32 (0.23–0.44) | 1.23 (1.04–1.46) | 0.52 (0.32–0.86) | 2.34 (1.23–4.47)
| | | ≤ 20/40 | 0.76 (0.68–0.83) | 0.49 (0.38–0.61) | 1.50 (1.19–1.90) | 0.49 (0.33–0.71) | 3.09 (1.71–5.55)
| | | ≤ 20/60 | 0.60 (0.52–0.69) | 0.64 (0.53–0.74) | 1.67 (1.22–2.30) | 0.62 (0.47–0.81) | 2.70 (1.53–4.77)
Ariyasu et al, 1996 ^74^ Sensitivity, specificity, and predictive values of screening tests for eye conditions in a clinic-based population | Ophthalmologic examination | Any ocular disease, excluding refractive error | Presenting distance visual acuity ≤ 20/30 | 0.75 (0.69–0.81) | 0.51 (0.42–0.61) | 1.54 (1.26–1.90) | 0.48 (0.36–0.65) | 3.18 (1.96–5.18)
| | | ≤ 20/40 | 0.68 (0.61–0.74) | 0.67 (0.58–0.76) | 2.08 (1.57–2.76) | 0.47 (0.37–0.60) | 4.40 (2.69–7.18)
| | | ≤ 20/60 | 0.53 (0.46–0.60) | 0.86 (0.78–0.92) | 3.76 (2.34–6.03) | 0.54 (0.46–0.64) | 6.90 (3.82–12.5)
Ivers et al, 2001 ^77^ Sensitivity and specificity of tests to detect eye disease in an older population | Ophthalmologic examination | A: Nuclear cataract B: Early ARMD C: Any eye disease | Pinhole distance acuity ≤ 20/30 | A: 0.31 (0.28–0.34) B: 0.45 (0.37–0.53) C: 0.34 (0.31–0.37) | A: 0.89 (0.87–0.91) B: 0.79 (0.78–0.80) C: 0.86 (0.84–0.87) | A: 2.83 (2.35–3.40) B: 2.16 (1.80–2.59) C: 2.43 (2.14–2.76) | A: 0.78 (0.74–0.81) B: 0.69 (0.60–0.80) C: 0.77 (0.74–0.80) | A: 3.65 (2.93–4.55) B: 3.11 (2.26–4.30) C: 3.17 (2.69–3.73)
| | | ≤ 20/40 | A: 0.13 (0.11–0.15) B: 0.21 (0.15–0.28) C: 0.15 (0.13–0.17) | A: 0.98 (0.97–0.99) B: 0.92 (0.91–0.93) C: 0.96 (0.95–0.97) | A 6.57 (4.29–10.1) B: 2.59 (1.87–3.58) C: 3.74 (2.95–4.73) | A: 0.89 (0.87–0.91) B: 0.86 (0.80–0.93) C: 0.89 (0.86–0.91) | A: 7.40 (4.78–11.5) B: 3.01 (2.01–4.49) C: 4.22 (3.27–5.45)
| | | ≤ 20/60 | A: 0.08 (0.06–0.10) B: 0.10 (0.06–0.16) C: 0.09 (0.07–0.11) | A: 0.99 (0.98–1.00) B: 0.95 (0.94–0.96) C: 0.97 (0.96–0.98) | A: 8.07 (4.44–14.7) B: 2.01 (1.24–3.28) C: 2.98 (2.23–3.97) | A: 0.93 (0.91–0.95) B: 0.95 (0.90–1.00) C: 0.94 (0.92–0.96) | A: 8.69 (4.76–15.8) B: 2.13 (1.25–3.63) C: 3.17 (2.34–4.30)
Ivers et al, 2001 ^77^ Sensitivity and specificity of tests to detect eye disease in an older population | Ophthalmologic examination | A: Nuclear cataract B: Early ARMD C: Any eye disease | Presenting distance visual acuity ≤ 20/30 | A: 0.44 (0.41–0.47) B: 0.56 (0.48–0.64) C: 0.47 (0.44–0.50) | A: 0.77 (0.74–0.79) B: 0.66 (0.64–0.68) C: 0.74 (0.72–0.76) | A: 1.91 (1.69–2.16) B: 1.65 (1.42–1.90) C: 1.81 (1.65–1.98) | A: 0.73 (0.68–0.77) B: 0.67 (0.56–0.80) C: 0.72 (0.68–0.76) | A: 2.63 (2.20–3.15) B: 2.47 (1.79–3.40) C: 2.53 (2.19–2.92)
| | | ≤ 20/40 | A: 0.25 (0.22–0.28) B: 0.34 (0.27–0.42) C: 0.27 (0.24–0.29) | A: 0.90 (0.88–0.92) B: 0.82 (0.81–0.83) C: 0.87 (0.86–0.88) | A: 2.50 (2.05–3.05) B: 1.89 (1.50–2.37) C: 2.07 (1.81–2.38) | A: 0.83 (0.80–0.87) B: 0.80 (0.72–0.90) C: 0.84 (0.81–0.87) | A: 3.00 (2.38–3.79) B: 2.34 (1.67–3.28) C: 2.47 (2.08–2.94)
| | | ≤ 20/60 | A: 0.13 (0.11–0.15) B: 0.13 (0.08–0.20) C: 0.14 (0.12–0.16) | A: 0.96 (0.95–0.97) B: 0.92 (0.91–0.93) C: 0.94 (0.93–0.95) | A: 3.22 (2.35–4.41) B: 1.65 (1.09–2.49) C: 2.33 (1.89–2.88) | A: 0.91 (0.88–0.93) B: 0.94 (0.89–1.00) C: 0.92 (0.89–0.94) | A: 3.55 (2.54–4.96) B: 1.75 (1.09–2.80) C: 2.55 (2.02–3.21)
Ivers et al, 2001 ^77^ Sensitivity and specificity of tests to detect eye disease in an older population | Ophthalmologic examination | A: Nuclear cataract B: Early ARMD C: Any eye disease | Reading acuity ≤ 20/30 | A: 0.97 (0.96–0.98) B: 0.99 (0.96–1.00) C: 0.98 (0.97–0.99) | A: 0.03 (0.02–0.04) B: 0.03 (0.02–0.04) C: 0.03 (0.02–0.04) | A: 1.00 (0.99–1.01) B: 1.02 (1.00–1.04) C: 1.01 (1.00–1.02) | A: 1.00 (0.63–1.60) B: 0.42 (0.10–1.69) C: 0.66 (0.42–1.03) | A: 1.00 (0.62–1.61) B: 2.42 (0.65–8.98) C: 1.53 (0.97–2.42)
| | | ≤ 20/40 | A: 0.88 (0.86–0.90) B: 0.95 (0.90–0.98) C: 0.89 (0.87–0.91) | A: 0.20 (0.18–0.22) B: 0.16 (0.15–0.17) C: 0.19 (0.18–0.21) | A: 1.10 (1.06–1.14) B: 1.13 (1.09–1.18) C: 1.10 (1.07–1.13) | A: 0.60 (0.49–0.73) B: 0.32 (0.16–0.62) C: 0.58 (0.49–0.68) | A: 1.84 (1.46–2.32) B: 3.59 (1.78–7.26) C: 1.90 (1.55–2.32)
| | | ≤ 20/60 | A: 0.57 (0.54–0.60) B: 0.70 (0.62–0.77) C: 0.59 (0.56–0.62) | A: 0.59 (0.56–0.62) B: 0.53 (0.51–0.55) C: 0.59 (0.57–0.61) | A: 1.39 (1.28–1.52) B: 1.48 (1.33–1.65) C: 1.44 (1.35–1.54) | A: 0.73 (0.67–0.79) B: 0.57 (0.45–0.72) C: 0.70 (0.64–0.75) | A: 1.91 (1.62–2.26) B: 2.61 (1.85–3.68) C: 2.07 (1.80–2.38)
Wang et al, 1998 ^80^ Evaluation of screening schemes for eye disease in a primary care setting | Ophthalmologic examination | Any ocular disease | Presenting distance visual acuity ≤ 20/40 | 0.61 (0.54–0.68) | 0.72 (0.65–0.78) | 2.18 (1.70–2.79) | 0.54 (0.45–0.66) | 4.02 (2.65–6.09)
Woods et al, 1998 ^81^ Screening for ophthalmic disease in older subjects using visual acuity and contrast sensitivity | Ophthalmologic examination | Any ocular disease, excluding refractive error | Near visual acuity ≤ 20/30 | 0.77 (0.74–0.80) | 0.68 (0.63–0.73) | 2.41 (2.08–2.80) | 0.34 (0.30–0.38) | 7.15 (5.52–9.26)
Woods et al, 1998 ^81^ Screening for ophthalmic disease in older subjects using visual acuity and contrast sensitivity | Ophthalmologic examination | Any ocular disease, excluding refractive error | Presenting distance visual acuity ≤ 20/30 | 0.74 (0.71–0.77) | 0.87 (0.83–0.90) | 5.66 (4.36–7.34) | 0.30 (0.27–0.33) | 18.9 (13.6–26.3)

Abbreviations: ARMD = age-related macular degeneration.

Visual acuity tests. Four studies found various visual acuity screening tests to have low accuracy compared to a full ophthalmologic examination for identifying the presence of any visual condition (Table 5). ^74,^ ^77,^ ^80,^ ^81^ Interpretation of diagnostic accuracy based on this reference standard is a challenge because the clinical significance of visual conditions not necessarily associated with impaired visual acuity is unclear. No visual acuity test was associated with both high sensitivity and specificity, resulting in generally weak PLRs and NLRs. PLRs ranged from 1.00 to 8.07 and NLRs from 0.32 to 1.00, with DORs less than 10. The exception was one study that found presenting distance acuity [underlined: <] 20/40 associated with a DOR of 18.9 (95% CI 13.64 to 26.26) for identifying any visual condition. ^81^ However, three other studies ^74,^ ^77,^ ^80^ found the same distance acuity threshold associated with DORs of 2.47 (95% CI 2.08 to 2.94) ^77^ to 4.40 (95% CI 2.69 to 7.18). ^74^ Two studies reported areas under the receiver operating curve that ranged from 0.66 to 0.83 for various tests of visual acuity. ^74,^ ^77^ One study reported diagnostic accuracy of visual acuity testing specifically for identifying cataracts or early ARMD, with results similar to those for identifying any visual condition. ^77^ No studies compared the Snellen test to an established, clinically relevant reference standard for impaired visual acuity, possibly because the Snellen is often considered the clinical standard for evaluating visual acuity.

Amsler grid. One study found the Amsler grid associated with poor accuracy for identifying any visual condition (Table 5). ^74^ The PLR was 1.65 (95% CI 0.90 to 3.06) and the NLR was 0.91 (95% CI 0.82 to 1.01). We found no other studies that evaluated diagnostic accuracy of the Amsler grid in persons without known ARMD or other retinal disease.

Clinical examination. One small (N=50) study found that among patients aged 64 to 97 and not known to have eye disease, 100% (9/9) patients with cataracts and 75% (3/4) patients with ARMD were correctly identified by a geriatrician compared to an ophthalmologist. ^78^ No false-positives were reported.

Pinhole testing. We identified no study that evaluated the accuracy of primary care clinic-based pinhole testing for differentiating impaired visual acuity due to correctible refractive error from impaired visual acuity due to other causes. One excluded study estimated a sensitivity of 79% and specificity of 98% for home pinhole testing (administered by a Census Bureau worker) compared to complete ophthalmologic exam (including refraction) for identifying uncorrectable refractive error, but did not perform an ophthalmologic exam in all patients and imputed data to calculate measures of diagnostic accuracy. ^51^ In addition, it was not designed to assess accuracy of pinhole testing for differentiating impaired visual acuity due to correctible refraction error from other causes, as it did not enroll a population of patients with impaired visual acuity on non-pinhole visual acuity testing.

Fundus examination. No studies evaluated accuracy or yield of dilated fundus examination by primary care providers. One retrospective study (N=1094) found that fundoscopic examination by an ophthalmologist identified clinically significant abnormalities in 2.7% of asymptomatic patients. ^82^

## Key Question 4. Does treatment of early impairment in visual acuity due to uncorrected refractive error, cataracts or age-related macular degeneration lead to improved morbidity/mortality or quality of life?

### Summary

A number of treatments are effective at improving visual outcomes in patients with uncorrected refractive error, cataracts, or, in the case of ARMD, slowing disease progression. For uncorrected refractive error and cataracts, there is good evidence from a large body of observational data and accumulated clinical experience that the most common treatments (refractive lenses and cataract surgery) are highly effective at restoring normal or near-normal visual acuity. A large population-based study found that about 60% of older adults with impaired visual acuity could achieve visual acuity of 20/40 or better with refractive correction. Based on numerous observational studies, over 90% of patients undergoing cataract surgery achieve visual acuity of 20/40 or better. One randomized trial found immediate cataract surgery associated with decreased risk of second (though not first) fall compared to delayed surgery, resulting in a lower overall rate of falls (rate ratio 0.66, 95% CI 0.40 to 0.96, p=0.03). For wet ARMD, there is evidence from randomized trials that laser photocoagulation (relative risk 0.67 to 6+ lines visual acuity loss; 95% CI 0.53 to 0.83, five trials), PDT (relative risk 0.22 for 3+ lines visual acuity loss, 95% CI 0.53 to 0.83, five trials) and intravitreal injection with VEGF inhibitors (for 3+ lines visual acuity loss: pegaptanib [two trials] relative risk 0.71, 95% CI 0.61 to 0.84; ranibizumab [two trials] relative risk 0.21, 95% CI 0.16 to 0.27) are effective at slowing loss of visual acuity, though serious methodological shortcomings were present in trials of laser photocoagulation. Conclusions regarding effectiveness of vitamin and mineral supplements for treating dry ARMD are largely based on a single large, good-quality trial that found a decreased risk for disease progression (adjusted OR [odds ratio] 0.68, 99% CI 0.49 to 0.93). Evidence showing that treatment of early vision impairment is associated with improvement in vision-related function is relatively sparse and not always consistent with evidence showing improvements in visual acuity. (See Appendices C5–8 for full data abstraction and quality ratings on randomized controlled trials (RCTs) and systematic reviews on efficacy and harms of treatment).

### Evidence

#### Uncorrected refractive error

Corrective lenses. In the National Health and Nutrition Examination Survey (NHANES) study, over 60% of persons over the age of 60 with presenting visual acuity worse than 20/50 could achieve visual acuity better than 20/40 with refractive correction. ^4^ We identified two fair-quality randomized trials (N=131 and 151) that found immediate correction of refractive error with eyeglasses in older (mean age 80 years) adults associated with improved short-term (2–3 month follow-up) vision-related quality of life or function compared to delayed treatment (Table 6). ^83,^ ^84^ One trial ^83^ recruited patients during community health screening, while the other ^84^ recruited nursing home patients. In both trials, patients randomized to immediate eyeglasses experienced improvements in vision-related quality of life or function relative to the delayed-treatment groups on a variety of measures. For example, General Vision subscale scores of the National Eye Institute Visual Functioning Questionnaire (NEI-VFQ) were improved by a mean of about 10 (of 100) points in the immediate-treatment group in both trials, representing a moderate clinical improvement. However, there were few between-group differences on measures of general functional status.

Table 6 Uncorrected Refractive Error - Randomized Controlled Trials

Study, Year Title | Study design Purpose of study Country | Patients | Intervention Duration of follow-up | Results | Quality score
Coleman et al, 2006 ^83^ Treatment of uncorrected refractive error improves vision-specific quality of life | RCT To evaluate the benefits of eyeglasses and magnifiers in elderly patients with uncorrected refractive error U.S. | N=131 Mean age 80.4 years (SD 8.2) 72% female 63% White; 18% Black; 8% Asian; 3% Hispanic; 8% Other Mean baseline visual acuity 20/63 | Intervention group: Received vision correction aids immediately (glasses, magnifier or both) Control group: Received a voucher and prescription to obtain vision correction aids at the conclusion of the trial (3 months later) 3-month follow-up | Mean change from baseline at 3 months, with glasses vs without glasses National Eye Institute Visual Functioning Questionnaire: Composite score: 6.5 (SD 9.3) vs -0.8 (SD 10.8); p<0.01 Selected individual components: -General health: 4.2 (SD 18.0) vs -0.4 (SD 17.4); p=.17 -General vision: 10.4 (SD 18.2) vs -2.1 (SD 14.0); p<0.01 -Near vision: 7.6 (SD 19.1) vs 0.4 (SD 17.4); p=0.04 -Distance vision: 3.3 (SD 23.2) vs -6.3 (SD 22.7); p=0.03 -Social functioning: 4.5 (SD 21.0) vs -0.9 (SD 19.6); p=0.17 -Mental health: 11.2 (SD 25.3) vs 0.4 (SD 24.2); p=0.02 GDS score -0.3 (SD 1.9) vs -0.1 (SD 2.1); p=0.58 Rosow-Breslau functioning scale: 0.07 (SD 1.3) vs -0.4 (SD 1.4); p=0.07 Distance visual acuity: 5.5 (SD 10.0) vs 3.9 (10.4); p=0.41 Near visual acuity: 6.1 (SD 13.3) vs 2.2 (SD 11.4); p=0.10 | Fair
Owsley et al, 2007 ^84^ Effect of refractive error correction on health-related quality of life and depression in older nursing home residents | RCT To examine the effect of treating uncorrected refractive error through spectacle correction on vision-targeted health-related quality of life and depressive symptoms in nursing home residents U.S. | N=151 Mean age 78.7 years (SD 8.3) 76% female | Immediate (within 1 week) refractive error correction with glasses vs delayed correction (glasses dispensed 2 months later) 2-month follow-up | Immediate vs delayed correction at 2 months: NHVQoL subscale score - range 0–100; - General vision: 77.3 vs 65.0; p<0.001; - Reading: 92.9 vs 84.7; p<0.001; - Ocular symptoms: 81.4 vs 78.3; p=0.23; - mobility: 91.5 vs 90.0; p=0.24; - Psychological distress: 76.0 vs 70.7; p=0.02; - Activities of daily living: 99.7 vs 99.1; p=0.17; - Activities and hobbies: 98.0 vs 94.0; p=0.04; - Adaptation and coping: 92.4 vs 90.0; p=0.11; - Social interaction: 97.3 vs 94.1; p=0.03; VF-14 total score - range 0–100 95.7 vs 83.1; p<0.001 SF-36 score - range 0–100; - Mental component summary 81.9 vs 80.8; p=0.96; - Physical component summary 47.6 vs 46.1; p=0.24; GDS score 3.6 vs 4.9; p=0.003 | Fair

Abbreviations: GDS = geriatric depression scale, SD = standard deviation, SF-36 = Medical Outcomes Study - Short Form Health Survey 36, VF-14 = Health survey questionnaire designed specifically for ophthalmology. “VF” stands for Visual Function, and “14” refers to the 14 questions in the main section of the questionnaire.

Refractive surgery. A systematic review of 27 RCTs and 130 observational studies found LASIK, LASEK, and PRK to be similarly and highly effective at improving refractive errors, with 92–94% of persons with myopia and 86–96% of persons with hyperopia achieving visual acuity 20/40 or better (Table 7). ^85^ Several observational studies also found refractive surgery associated with improved quality of life. ^86^ – ^88^ Preliminary results from a meta-analysis conducted for a joint task force formed by the U. S. Food and Drug Administration (FDA) found that > 95% of patients are satisfied following LASIK, though final results of this study are not yet available [http://www.ascrs.org/index.cfm]. Data on incidence of glare, visual haloes, or worsened night vision following refractive surgery are sparse and inconsistent, with rates ranging from 0% to over 50%. ^85^

Table 7 Uncorrected Refractive Error - Systematic Reviews

Study, Year, Title | Aims | Literature searches | Patients/trials | Interventions | Results | Conclusion | Quality score
Murray et al, 2005 ^85^ A systematic review of the safety and efficacy of elective photorefractive surgery for the correction of refractive error | To systematically review the evidence for safety and efficacy of PRK, LASEK and LASIK for the correction of myopia, hyperopia and astigmatism | MEDLINE, MEDLINE Extra, EMBASE, BIOSIS, Science Citation Index, Cochrane Controlled Trials Register, National Research Register Clinical Trials, Current Controlled Trials, FDA Premarket Approval (PMA) Database Web of Science Proceedings, Conference Papers Index, Zetoc, Association for Research in Vision and Ophthalmology (ARVO) Abstracts Database, American Society of Cataract and Refractive Surgery-American Society of Ophthalmic Administrators (ASCRS-ASOA) Abstracts Database; 2000-2005 | LASIK: 64 studies (73 publications; 4 RCTs); LASEK: 26 studies (40 publications; 14 RCTs); PRK: 40 (9 RCTs) case series | Primary treatment with any type of excimer laser used to perform PRK, LASEK, and LASIK for refractive correction of myopia, hyperopia or astigmatism. | Uncorrected visual acuity of 20/20 or better in myopia: PRK 70%, LASEK 62%, LASIK 64% 20/40 or better: PRK 92%, LASEK 92% and [underlined: Efficacy] LASIK 94% Highly myopic eyes achieved High myopia at baseline, 20/20: PRK14% and LASIK 44% compared with Low myopia at baseline: PRK 76% and LASIK 81% Correction of myopia/myopic astigmatism, median across all 3 treatments: 68% to 75% of eyes achieving within 0.5 D of their intended correction; 86% to 92% of eyes achieved within 1.0 D. Correction of hyperopia: 61% of eyes achieved within 0.5 D of intended correction after PRK and LASIK; 79% and 88% for PRK and LASIK respectively within 1.0 D. [underlined: Harms] Ectasia (5 LASIK studies): median rate 0.2% (range 0% to 0.87%) Loss of ≥2 lines of BSCVA in myopia: PRK 0.5%, LASEK 0% and LASIK 0.6% Loss of ≥2 lines of BSCVA in hyperopia: PRK 7.0%, LASIK 3.5% | The safety and efficacy of photorefractive surgery should be considered against the alternative methods of correction; adverse events occur rarely from a statistical standpoint. | Good
Virgili et al, 2008 ^39^ Reading aids for adults with low vision | To assess the effects of reading aids for adults with low vision | CCRCT (Cochrane Central Register of Controlled Trials), MEDLINE, EMBASE, SIGLE, LILACS (Latin American and Caribbean Health Science Literature Database) and IndMed through July 2006; Science Citation Index; hand search British Journal of Visual Impairment 1983-1999 and Journal of Visual Impairment and Blindness 1976-1991 | 9 trials: Culham 2004 (n=20); Eperjesi 2004 (n=12); Goodrich 2001 (n=22); Kleweno 2001 (n=13); Ortiz 1999 (n=10); Peterson 2003 (n=70); Smith 2005 (n=243); Spitzberg 1995 (n=39); Stelmack 1991 (n=37) | Magnifiers, CCTV (stand-mounted and hand-held); prism spectacles | Reading speed: prism spectacles were no better than conventional spectacles in the single study comparing them; for other interventions, there was no difference in reading speed among the treatments although this could have been due to problematic design and reporting among the included studies | No evidence supports any particular low vision reading aid over another; the studies included in the SR were of questionable quality and potentially biased | Good

Abbreviations: BSCVA = Best Spectacle-Corrected Visual Acuity, CCTV = closed-circuit television, LASEK = Laser Assisted Sub-Epithelial Keratomileusis, LASIK = Laser Assisted in Situ Keratomileusis, PRK = Photorefractive Keratectomy.

Low vision aids. A systematic review of nine trials compared the effect of various low vision aids, including magnifiers, prism spectacles, telescopes and electronic devices, on improving reading speed (Table 7). ^39^ Secondary outcomes of this review were change in visual acuity and improvement in quality of life, but only one of the included trials reported any of these outcomes. ^89^ It found no difference between prism eyeglasses and conventional eyeglasses in logMAR acuity or NEI-VFQ score. A non-randomized study of consecutively enrolled patients in a low vision clinic, not included in the review above, assessed quality of life outcomes 3 months following use of a variety of visual aids (including eyeglasses, magnifiers, and telescopes). ^90^ 21% of participants had visual acuity better than 20/60 at baseline. Following treatment, quality of life was improved on a number of measures, though there was no change from baseline in Medical Outcomes Study - Short Form Health Survey 36 (SF-36) scores.

#### Cataract

Surgery. We identified no randomized trials that evaluated visual outcomes associated with cataract surgery versus no surgery. A good-quality systematic review of 57 observational studies published between 1979 and 1991 (of 90 total included studies) found cataract surgery associated with post-operative visual acuity of 20/40 or better in 88.9% (95% CI 88.1% to 89.8%) of all eyes (N=17,390) and 95.2% (95% CI 94.7% to 95.7%) of eyes without preoperative ocular comorbidity (N=10,003) after weighting results by sample size and quality score (Table 8). ^91^ Only four of the studies were controlled cohort studies; the remainder were uncontrolled observational studies. The mean quality score of included studies averaged 43 out of a maximum possible 100 points. ^92^

Table 8 Cataract - Systematic Reviews

Study, Year, Title | Aims | Literature searches | Patients/trials | Interventions | Results | Conclusion | Quality score
Powe et al, 1994 ^91^ Synthesis of the literature on visual acuity and complications following cataract extraction with intraocular lens implantation | To define the effectiveness and risks of cataract surgery | MEDLINE 1975-April 1991; reference lists | 83 single-arm observational studies and 7 cohort studies Median n=231 (17 to 22,791) | 22 studies: phacoemulsification; 58 studies: extracapsular extraction; 1 study: intracapsular extraction; 18 studies: mixed phacoemulsification and extracapsular extraction | Pooled % of eyes with 20/40 acuity or better: 95.5% (CI 95.1% to 95.9%) in pts with no ocular comorbidities and 87% (CI 89.3% to 90.2%) for all eyes Harms - pooled rates - % (CI): Endophtalmitis 0.13 (0.09 to 0.17) Bullous keratopathy 0.3 (0.2 to 0.4) Malposition/dislocation of IOL 1.1 (0.9 to 1.2) Clinical cystoid macular edema 1.4 (1.2 to 1.6) Angiographic cystoid macula edema 3.5 (2.9 to 4.0) Retinal detachment 0.7 (0.6 to 0.8) Posterior capsular opacification 19.7 (19.1 to 20.3) | Cataract surgery yields excellent visual acuity and is relatively safe regardless of method of surgical extraction | Good
Schaumberg et al, 1998 ^163^ A systematic overview of the incidence of posterior capsule opacification | To obtain an estimate of the incidence of posterior capsule opacification (PCO) and to explore factors that may influence its development | MEDLINE 1979-1996; reference lists | 49 studies (design NR); total n=NR | 27 studies: extracapsular extraction; 9 studies: phacoemulsification; 13 studies: mixed extracapsular extraction and phacoemulsification | Pooled rate, incidence of posterior capsule opacification: 1 year: 11.8% (9.3%–14.3%) 3 years: 20.7% (16.6%–24.9%) 5 years: 28.4% (18.4%–38.4%) | Visually significant PCO develops in more than 25% of patients undergoing extracapsular extraction or phacoemulsification with IOL within 5 years of surgery | Fair
Taban et al, 2005 ^164^ Acute endophthalmitis following cataract surgery | To determine the reported incidence of acute endophthalmitis following cataract extraction and to explore possible contributing factors | Cochrane (database not specified); MEDLINE 1963-March 2003; reference lists; textbook hand search; conference proceedings and abstracts | 215 studies (design NR); total n=NR | NR | Pooled rate, incidence of endophthalmitis: 0.128% Rate 1963-1999: 0.109% Rate 2000-2003: 0.265% (RR 2.44. CI 2.27 to 2.61) | Incidence of endophthalmitis associated with cataract extraction has increased over the last decade and may be linked to the increasing use of sutureless clear corneal incisions. | Fair

Abbreviations: CI = confidence interval, IOL = intraocular lenses, NR = not relevant, PCO = posterior capsule opacification, RR = relative risk.

Benefits of cataract surgery on visual acuity may be lower at very advanced ages (e.g., older than 85 years). Some studies found very advanced age associated with a three- to four-fold difference in likelihood of achieving good visual outcomes after adjusting for potential confounders. ^93^ – ^95^ However, cataract surgery still appears to be associated with positive effects in the great majority of patients in this age group. One of the few studies specifically evaluating outcomes in this population found 85% of persons 85 years or older experienced improved visual acuity. ^96^

Three good-quality, prospective observational studies found cataract surgery associated with clinically significant improvement in vision-related quality of life and function assessed using validated measures. ^97^ – ^99^ Two studies (N=464 and 772) ^98,^ ^99^ prospectively enrolled and assessed quality of life in patients prior to cataract surgery and again following surgery. The other study was a controlled cohort study, ^97^ but enrolled a much smaller patient population (N=45). Four months following cataract surgery, two studies found mean Visual Function 14 (VF-14) scores increased by 17 to 25 points; ^97,^ ^98^ one of these studies also found Nursing Home Vision-Targeted Health-Related Quality of Life Questionnaire (NHVQoL) scores increased an average of 22.1 points; ^97^ and a third study found Activities of Daily Vision Scale (ADVS) scores increased from 14.7 to 22.4 points (of 100). ^99^ Studies that reported patients' subjective assessment of vision-related function following surgery ^100^ – ^102^ are consistent with studies reporting improvements in formal vision-related quality of life measures, as are studies that assessed vision-related quality of life in the subgroup of persons over 80 years of age. ^96,^ ^103,^ ^104^

The effect of cataract surgery on functional status or quality of life not directly related to vision is less clear. Results from a 4-month study found no significant difference in SF-36 scores from baseline following surgery, while a 12-month study found a worsening in SF-36 score compared to baseline. ^97,^ ^99^ Another study found small or no statistically significant changes in domains of the functional assessment inventory, ^101^ and one study found no changes in depression scores (Center for Epidemiologic Studies Depression Scale [CES-D]) following cataract surgery. ^105^

Two good-quality trials (N=545) compared effects of immediate (within 4 weeks) versus delayed (12 month waiting list) cataract surgery on falls in high-risk women ^106,^ ^107^ (Table 9). Baseline fall rates in enrollees ranged from 45–51% during the 12 months preceding study entry. One trial evaluated initial (first-eye) cataract surgery ^106^ while the other evaluated second-eye cataract surgery. ^107^ Both trials adjusted for activity level following surgery. Immediate first-eye cataract surgery was associated with no significant difference compared to delayed surgery in risk of first fall (hazards ratio 0.95, 95% CI 0.69 to 1.35; p=0.77), though the risk of second fall was reduced (hazards ratio 0.60, 95% CI 0.36 to 0.98; p=0.04), resulting in a lower overall rate of falls per 1000 patient days (relative risk 0.66, 95% CI 0.40 to 0.96, p=0.03). ^106^ Immediate second-eye surgery was not associated with a reduction in incidence of first or second fall or overall falls per 1,000 patient days (relative risk 0.68, CI 0.39 to 1.19; p=0.18). ^107^ However, statistical power was limited because this trial was unable to enroll the prespecified number of patients.

Table 9 Cataract - Randomized Controlled Trials

Study, Year, Title | Study design Purpose of study | Patients | Intervention Duration of follow-up | Results | Quality score
Chylack et al, 2002 ^109^ The Roche European American Cataract Trial (REACT): a randomized clinical trial to investigate the efficacy of an oral antioxidant micronutrient to slow progression of age-related cataract | To determine if a mixture of oral antioxidants would modify progression of cataract Double-blind PCT of consecutively enrolled patients | Able to provide written informed consent; able to attend for all visits; ≥ 40 years old; at least one eye met the following ocular criteria: cataract extraction unlikely within two years, immature idiopathic ‘senile’ cataract present in one or both eyes, U.S. patients: presence of minimal cataract by Lens Opacities Classification System [LOCS II]14 criteria, U.K. patients: presence of cataract of minimal Oxford grade; logMAR acuity ≤0.5; ocular media clear enough to capture good images of the lens; remote risk of angle closure glaucoma; pupil dilatable to 6mm; oscillatory movement displacement threshold ≤50S; no visually significant fundus pathology; no clinical signs of glaucoma and intraocular pressure; no history of amblyopia, eye surgery, argon or YAG laser eye treatment, or major eye trauma; no history of iritis, retinal crystalline deposits, or optic nerve disease; no extended (daily for >3 months) use of ocular corticosteroid or glaucoma therapy; no participation in another clinical trial investigating an anticataract formulation within the last year. | Antioxidant multivitamin (250mg vitamin C + 200mg vitamin E + 6mg beta carotene) tid vs placebo 3 years follow-up | Multiple methods used to evaluate changes in lens opacities; following 3 years of treatment there was a marginally significant between group difference in cataract progression (p=0.048) based on the primary outcome measure only (% pixels opaque) and not for other measure of cataract progression (e.g. LOCS) | Fair
Foss et al, 2006 ^107^ Falls and health status in elderly women following second eye cataract surgery: a randomized controlled trial | RCT To determine if second eye cataract surgery reduces the risk of falling and to measure associated health gain | Women in the UK age ≥70 yrs with a previous, successful cataract operation who had a second, operable cataract | Cataract surgery vs no/delayed treatment 1 year follow-up | Proportion of patients with falls: 48/120 (40%) immediate surgery group vs 41/119 (34%) delayed treatment group; HR 1.06 (CI 0.69 to 1.61; p=0.80) Proportion of patients with second falls: 22/120 (18%) immediate surgery group vs 22/119 (18%) delayed treatment group; HR 0.85 (CI 0.49 to 1.56; p=0.61) Rate of falling per 1,000 patient days: 2.9 immediate treatment group vs 4.3 delayed treatment group; Rate ratio 0.68 (CI 0.39 to 1.19; p=0.18) | Good
Harwood et al, 2004 ^106^ Falls and health status in elderly women following first eye cataract surgery: a randomized controlled trial | RCT To determine if first eye cataract surgery reduces the risk of falling and to measure associated health gain | Women in the UK age ≥70 yrs with cataract who were suitable for surgery and had not had previous ocular surgery | Cataract surgery (phacoemulsification) vs no/delayed treatment 1 year follow-up | Proportion of patients with falls: 76/154 (49%) immediate surgery group vs 69/152 (45%) delayed treatment group; HR 0.95 (CI 0.69 to 1.35; p=0.77) Proportion of patients with second falls: 28/154 (18%) immediate surgery group vs 38/152 (25%) delayed treatment group; HR 0.60 (CI 0.36 to 0.98; p=0.04) Rate of falling per 1,000 patient days: 1.0 immediate treatment group vs 1.52 delayed treatment group; Rate ratio 0.66 (CI 0.45 to 0.96; p=0.03) Fracture incidence: 4/154 (3%) immediate treatment group vs 12/152 (8%) delayed treatment group; Risk ratio 0.33 (CI 0.1 to 1.0; p=0.04) | Good

Abbreviations: CI = confidence interval, PCT = placebo controlled trial, RCT = randomized controlled trial.

Both trials reported fracture incidence as a secondary outcome. Results were mixed and had limited statistical power due to small numbers of events. Relative to the delayed-treatment group, the first-eye trial found an immediate surgery associated with a lower risk of fracture (relative risk 0.33, 95% CI 0.1 to 1.0; p=0.04). ^106^ The second-eye trial found no difference between immediate and delayed surgery in fracture risk, but the estimate was imprecise (relative risk 2.5, 95% CI 0.5 to 12.5; p=0.45). ^107^

Incidence of motor vehicle crashes was assessed in one well-designed cohort study that prospectively followed 277 older drivers with cataracts who did or did not undergo cataract surgery. ^108^ The no-surgery group included more men and fewer whites than the surgery group, and the surgery group had worse visual acuity in both eyes at baseline relative to the surgery group. After 4 to 6 years, patients in the cataract surgery group had a lower risk of motor vehicle accidents compared to the no-surgery group (adjusted rate ratio of 0.47 [CI 0.23 to 0.94], absolute rate reduction 4.74 crashes per million miles driven).

One prospective cohort study (N=384) found that patients with cataracts who did not have surgery have increased mortality risk through up to 6 years of follow-up. ^23^ There were statistically significant baseline differences among the three enrolled groups (cataract surgery versus no surgery versus no cataract). Persons with cataracts who did not undergo surgery experienced 6.8 deaths per 100 patient-years, compared to 3.6 deaths per 100 patient-years in persons with cataracts who underwent surgery, and 0.9 deaths per 100 patient-years in those without cataracts (adjusted risk ratio 3.2 [CI 1.2 to 9.0] for cataract/no-surgery versus no-cataract).

Vitamins. One fair-quality trial found no clear difference between antioxidant vitamins versus placebo for progression of opacities in patients with cataracts ^109^ (Table 9). Although epidemiologic and other observational studies suggest that diets high in antioxidants or use of antioxidants is associated with a lower risk of cataract development, ^110^ randomized trials in patients without cataracts at baseline or in mixed populations of persons with and without cataracts failed to demonstrate positive effects of antioxidant supplements on cataract development or progression. ^41,^ ^42,^ ^44,^ ^111^ – ^113^

#### Dry (nonexudative) Age-related Macular Degeneration

Antioxidant vitamins and minerals. The large, good-quality Age-Related Eye Disease Study (AREDS; n=3640) found a multivitamin (vitamins C and E and beta carotene) plus zinc associated with reduced likelihood of progression to advanced ARMD (adjusted OR 0.68 [CI, 0.49 to 0.93]), though the difference in the likelihood of losing 15 or more letters of visual acuity did not reach statistical significance (adjusted OR 0.77 [CI, 0.58 to 1.03]). ^114^ A good-quality systematic review included nine randomized controlled trials (n=5569), but results were heavily influenced by AREDS (Table 10). ^43^ All trials enrolled patients with mild to advanced dry ARMD, with the exception of the Vitamin E, Cataract and Age-Related Maculopathy (VECAT) study (N=1204), which included some patients with no ARMD. ^115^ VECAT found no difference between vitamin E and placebo in likelihood of visual acuity loss of 15 or more letters, though results remain unpublished. ^43^ The systematic review also included a small (n=58) trial of zinc supplementation published only as a conference abstract ^116^ and a Chinese-language trial of zinc, vitamin C, and vitamin E that reported results poorly. ^117^ We rated the other trials included in the systematic review fair- ^118^ – ^122^ or poor-quality ^123^ (Appendix C6). The composition and doses of the antioxidant or mineral regimens varied in these trials. The systematic review found insufficient evidence to determine efficacy of vitamins and minerals other than the AREDs combination. ^118,^ ^120^ – ^123^ A small (n=101), fair-quality trial that was not included in the systematic review found the combination of acetyl-L-carnitine, n-3 fatty acids, and coenzyme Q10 more effective than placebo for experiencing no deterioration in Snellen visual acuity (23% vs. 45%, p=0.015), but the proportion of patients experiencing clinically significant visual acuity loss was not reported. ^124^

Table 10 Armd - Systematic Reviews

Study, Year, Title | Aims | Literature searches | Patients/trials | Interventions | Results | Conclusion | Quality score
Evans et al, 2008 ^43^ Antioxidant vitamin and mineral supplements for slowing the progression of age-related macular degeneration | To assess the effects of antioxidant vitamin or mineral supplementation, alone or in combination, on the progression of ARMD | CCRCT, MEDLINE, EMBASE, National Research Register through 2007, PubMed in process through 24 January 2006, AMED 1985-January 2006, SIGLE 1980-March 2005 | 9 trials (18 publications) Primary publications: Richer 1996 - AMDSG (n=71); Age-Related Eye Disease Study Research Group 2001 - AREDS (n=3640); Holz 1993 (n=58); Kaiser 1995 (n=20); Newsome 1988 (n=174); Stur 1996 (n=112); Garrett 1999 - VECAT study (n=1204); Richer 2004 - LAST study (n=90); Wang 2004 (n=400); total n=5769 | 3 trials: zinc 200 mg QD vs placebo 2 trials: broad-spectrum antioxidant compound vs placebo 1 trial: vitamin E 500 mg QD vs placebo 1 trial: zinc 80 mg QD vs antioxidant combination vs zinc + antioxidants vs placebo 1 trial: lutein 10 mg QD v lutein + broad-spectrum antioxidant 1 trial: zinc oxide 80 mg QD, vitamin C, vitamin E vs placebo | All comparisons Any multivitamin or antioxidant vs placebo: Change in visual acuity - defined as a loss of 3 or more lines (15 or more letters) on a logMAR chart (AREDS, Newsome 1988, VECAT; I^2^=27.7%) Random effects model: pooled OR 0.83 (CI 0.63 to 1.09; p=0.18); Fixed effects model: pooled OR 0.81 (CI 0.67 to 0.98; p=0.03) Mean difference visual acuity (AMDSG, Kaiser 1995, Newsome 1988, Stur 1996, LAST; I^2^=0%): pooled SMD 0.02 (CI -0.21 to 0.26) ARMD progression as a dichotomous variable: (AREDS, Holz 1993, Stur 1996. VECAT; I^2^=64.2%) OR range: 0.50 to 2.31; no pooled analysis due to heterogeneity of studies ARMD progression as a continuous variable (AMDSG): mean difference -0.06 (CI -0.62 to 0.50) Individual comparisons Multivitamin supplements vs placebo (AREDS, Kaiser 1995, Richer 1996, Richer 2004) Change in visual acuity - defined as a loss of 3 or more lines (15 or more letters) on a logMAR chart (AREDS): OR 0.77 (CI 0.62 to 0.96) vs placebo Mean difference visual acuity (Kaiser 1995, AMDSG, LAST; I^2^=0%): pooled SMD 0.16 (CI -0.19 to 0.51) ARMD progression as a dichotomous variable (AREDS): adjusted OR 0.68 (CI 0.53 or 0.87) ARMD progression as a continuous variable (AMDSG): mean difference -0.06 (CI -0.62 to 0.50) Vitamin E vs placebo (VECAT) Change in visual acuity - defined as a loss of 3 or more lines (15 or more letters) on a logMAR chart: OR 1.05 (CI 0.70 to 1.57) ARMD progression: OR 0.11 (CI 0.80 to 1.55) Zinc vs placebo (AREDS, Holz 1993, Newsome 1988, Stur 1996) Change in visual acuity - defined as a loss of 3 or more lines (15 or more letters) on a logMAR chart (AREDS, Newsome 1988; I^2^=0%): OR 0.81 (CI 0.66 to 0.99) Mean difference visual acuity (Newsome 1988, Stur 1996; I^2^=56.6%): results somewhat inconsistent but no statistically significant difference found between treatment and control groups in both trials ARMD progression as a dichotomous variable (AREDS, Holz 1993, Stur 1996; I^2^=29.0%): pooled OR 0.73 (0.58–0.93) Lutein vs placebo (LAST): Mean difference visual acuity: 0.04 (-0.15 to 0.23) | Limited evidence, based primarily on AREDS, suggests a benefit in the use of antioxidant vitamins and minerals in slowing ARMD progression (risk reduction ~20–25%.) The AREDS population was relatively well-nourished at the trial's initiation and this may have had some effect on the trial results. Prolonged antioxidant use had been found to be harmful in some other populations (e.g. smokers) | Good
Evans et al, 2008 ^126^ Ginkgo biloba extract for age-related macular degeneration | To determine the effect of ginkgo biloba extract on the progression of ARMD | CCRCT (Quarter 4, 2005), MEDLINE (1966-January 2006, week 3), EMBASE (1980-January 2006), SIGLE (1980-2005/03), AMED (1985-January 2006), NRR (2005, Issue 4); reference lists, Science Citation Index; expert recommendation | 2 trials: Fies 2002 (n=99); Lebuisson 1986 (n=20); total n=119 pts | Gingko biloba extract EGb 761, doses 60–160 mg QD; placebo | Gingko biloba 160 mg QD vs placebo (1 trial; n=20): Change in visual acuity: WMD 1.70 (CI 1.21 to 2.19) Clinical improvement: OR 36.00 (2.72 to 476.28) Gingko biloba 60 mg QD vs 240 mg QD (1 trial; n=99): Mean visual acuity: WMD 0.05 (CI -0.03 to 0.13) >0.2 improvement in visual acuity score: OR 2.29 (CI 0.90 to 5.80) No serious AEs reported in either trial (headache, blood in stool and abdominal pain reported in 3/99 patients) | There is inadequate evidence from 2 small, short-term trials to draw conclusions regarding the effect of gingko biloba on ARMD progression. There may be harms associated with gingko biloba use, but they too have been inadequately reported. | Good
Meads et al, 2003 ^133^ Clinical effectiveness and cost-utility of photodynamic therapy for wet age-related macular degeneration: a systematic review and economic evaluation | To establish the clinical and cost-effectiveness of photodynamic therapy for neovascular ARMD | Cochrane Library (2001, Issue 3), MEDLINE (199-Aug 2001), EMBASE (1993-Aug 2001), Science Citation Index (1993-2001); health technology assessment web sites; internet sites of verteporfin manufacturers; reference lists; industry submissions | 2 trials: Treatment of Age-related Macular Degeneration with Photodynamic Therapy Study Group - TAP 1999 (n=609); Verteporfin in Photodynamic Therapy Study Group - VIP 2001 (n=2001); total n=2610 pts | IV verteporfin 6 mg/m2 + cold laser vs placebo + cold laser | Results not pooled TAP Loss of >15 letters (3 lines) at 24 months: 47.0% verteporfin vs 62.3% placebo; RR 0.75 (CI 0.65 to 0.88) Loss of >30 letters (6 lines) at 24 months: 18.2% verteporfin vs 30.0% placebo; RR 0.61 (CI 0.45 to 0.81) Proportion of pts with visual acuity of <34 letters at 24 months: 41.0% verteporfin vs 55.1% placebo; RR 0.75 (CI 0.63–0.88) VIP Loss of >15 letters (3 lines) at 24 months: 54.0% verteporfin vs 67% placebo; RR 0.81 (CI 0.68 to 0.96) Loss of >30 letters (6 lines) at 24 months: 30% verteporfin vs 47% placebo; RR 0.63 (CI 0.48 to 0.83) Proportion of pts with visual acuity of <34 letters at 24 months: this outcome not reported Harms: TAP mortality at 24 months: 3.2% verteporfin vs 3.9% placebo; RR 0.84 (0.35–1.99) VIP mortality at 24 months: 1.8% verteporfin vs 2.6% placebo; RR 0.68 (CI 0.15 to 2.97) | Photodynamic therapy is effective at preventing further visual loss due to AMD, although this conclusion is based largely on the results of the TAP trial. With the addition of a cost effectiveness analysis included in this review, the authors concluded that there is a need for further research on this topic. | Good
Vedula et al, 2008 ^142^ Antiangiogenic therapy with anti-vascular endothelial growth factor modalities for neovascular age-related macular degeneration | To investigate the effects of anti-vascular endothelial growth factor (anti-VEGF) modalities for treating neovacular ARMD | CCRCT, MEDLINE, EMBASE, LILACs through February 2008; hand search of Association for Research in Vision & Ophthalmology meeting abstracts | 5 trials (15 publications) Primary publications: Brown 2006 - ANCHOR Trial (n=423); Macugen 2007 - EOP 1003 Trial (n=578); Leys 2007 - EOP 1004 Trial (n=612); Heier 2006 - FOCUS Trial (n=162); Rosenfeld 2006 - MARINA Trial (n=716) | Pegaptanib 0.3, 1.0 or 3.0mg Ranibizumab 0.3 or 0.5mg Verteporfin PDT sham injection/sham PDT | Change in visual acuity (% of patients losing ≥3 lines of acuity at 1 year) Pegaptanib (all doses) vs sham: RR 0.71 (CI 0.60 to 0.84); NSD for 3.0mg dose vs sham; NNT 6.67 0.3mg dose, 6.25 1.0mg dose, 14.28 3.0mg dose Ranibizumab (both doses) vs sham: RR 0.14 (CI 0.08 to 0.25); NNT 3.13 (both doses) Blindness Pegaptanib RR 0.69 (CI 0.59 to 0.82) Ranibizumab RR 0.28 (CI 0.21 to 0.37) Quality of life - Mean change in NEI-VFQ scores at 2 years follow-up ANCHOR Trial: 5.9 ranibizumab 0.3mg vs 8.1 ranibizumab 0.5mg vs 2.2 verteprofin MARINA Trial: 4.8 ranibizumab 0.3mg vs 4.5 0.5mg ranibizumab vs -6.4 sham injection Ranibizumab: similar rates of serious AEs including mortality Unpublished data from SAILOR Trial reported by the drug's manufacturer showed a significantly higher stroke risk with 0.5mg dose relative to 0.3mg dose(p=0.02; no sham control in this trial) Pegaptanib: Serious ocular AEs (endophthalmitis, retinal detachment, traumatic cataract) in tx groups, none in sham group | Both interventions effective a reducing visual acuity loss and progression to blindness with improved QoL outcomes | Good
Virgili et al, 2008 ^45^ Laser photocoagulation for age-related macular degeneration | To examine the effect of laser photocoagulation on neovascular (wet) ARMD | CCRCT, MEDLINE, EMBASE, LILACS, National Research Register (NRR), ZETOC through March 2007 | 15 trials (34 publications) Primary publications: Arnold 1997; Canadian Ophthalmology Study Group 1993 (n=55); Bressler 1996 (n=100); Canadian Ophthalmology Study Group 1993 (n=191); Cardillo 1993 (n=23); Coscas 1983 (n=60); Coscas 1991 (n=160); Duch Mestres 1993 (n-41); Moorfields 1982 (n=128); Macular Photocoagulation Study Group - MPS Argon Extra 1982 (n=224); Macular Photocoagulation Study Group - MPS Krypton Juxta 1990 (n=496); Macular Photocoagulation Study Group - MPS Subf. New 1991 (n=371); Macular Photocoagulation Study Group - MPS Subf. Recurrent 1991 (n=206); Bressler 2000 & Submacular Surgery Trials Research Group 2000 - SST 2000 (n=70); Versteeg-Tijmes 1982 (n=13, excluding 13 non-ARMD eyes); Yassur 1982 (n=96) | 12 studies: Photocoagulation vs no treatment 1 study: photocoagulation vs surgery 1 study: argon vs krypton laser wavelength 1 study: argon vs dye red laser wavelength | Direct photocoagulation vs no treatment Visual acuity at 3 months: NNH 20 (CI 13 to 100) Reading ability at 3 years: NNT 6 (CI 3 to 33); at 5 years: NNT 7 (CI 4 to 33) Perifoveal photocoagulation of subfoveal CNV Visual acuity, loss of 6 lines or more at 2 years*: NNT 3 (CI 2 to 8) *only timepoint with SS difference b/t treatment and control, although photocoagulation was favored for other timepoints Grid photocoagulation of subfoveal CNV Visual acuity, loss of 2 or more lines: RR 1.83 (CI 1.10 to 3.05); NNT 5 (CI 3 to 20) Photocoagulation vs surgery No SS difference between treatments, although surgery was favored for visual acuity and QOL outcomes Argon vs krypton lasers No difference between argon and krypton at 2 years in visual acuity changes | Photocoagulation is effective for certain types of ARMD (extrafoveal CNV). For juxta-or sub- foveal CNV patients, the benefit of laser photocoagulation is less clear, | Good
Wormald et al, 2008 ^134^ Photodynamic therapy for neovascular age-related macular degeneration | To examine the effects of photodynamic therapy in the treatment of ARMD | CCRCT, MEDLINE EMBASE through March 2007; Science Citation Index (no date specified); expert recommendation | 3 trials (7 publications) Primary publications: Treatment of Age-related Macular Degeneration with Photodynamic Therapy Study Group - TAP 1999 (n=609); Visudyne in minimally classic choroidal neovascularization study - VIM 2005 (n=117); Verteporfin in Photodynamic Therapy Study Group - VIP 2001 (n=2001); total n=1065 pts | IV verteporfin (2 trials: 6 mg/m2; 1 trial dose NR) + cold laser vs placebo + cold laser | Loss of >3 lines of visual acuity at 24 months: pooled RR (2 trials: TAP, VIP) 0.78 (CI 0.7–0.87); risk ratio reduction 0.22 (CI 0.13 to 0.30); NNT: 7 (population: patients with subfoveal choroidal neovascularization with baseline visual acuity 20/40–20/200) Loss of >6 lines of visual acuity at 24 months: pooled RR (2 trials: TAP, VIM) 0.60 (CI 0.49–0.73); risk ratio reduction 0.40 (CI 0.27–0.51); NNT: 7 (population: patients with subfoveal choroidal neovascularization with baseline visual acuity 20/40–20/200) Mean number of lines of vision lost at 24 months (1 trial: TAP): 2.7 lines verteporfin vs 1.2 control; mean difference 1.2 (p<0.001) No QoL outcomes reported Acute severe visual acuity decrease (within 13 days of tx): Absolute risk difference 0.01 (CI 0.01 to 0.03); NNH 30 (range 30–100) | Photodynamic therapy is effective in preventing further visual loss due to AMD although the effect size is unclear. | Good

Abbreviations: ARMD = age-related macular degeneration, CI = confidence interval, logMAR = logarithmic minimum angle of resolution, NEI -VFQ = national eye institute visual functioning questionnaire, NNH = number needed to harm, NNT = number needed to treat, NR = not relevant, PDT = photodynamic therapy, QoL = quality of life, RR = relative risk, VECAT = vitamin E, cataract and age-related maculopathy study, VEGF = vascular endothelial growth factor.

A review of four trials and eight observational studies conducted by the FDA found insufficient evidence to show use of lutein and zeaxanthin is associated with reduced risk of ARMD. ^125^ AREDS 2, an ongoing Phase III trial, is studying the effect of these and other antioxidants.

Other treatments. A systematic review of two small trials found gingko biloba associated with no beneficial effects on the rate of ARMD progression and no differences in visual acuity compared to placebo after 6 months of treatment. ^126^ Quality of life or mortality outcomes were not reported in either of the included trials. Rheopheresis was evaluated in one trial, but results were inconclusive and the trial had methodological shortcomings. ^127^ Further research on rheopheresis by this study's funder was halted in November 2007 (http://www.occulogix.com/pressreleases.htm).

#### Wet (exudative) Age-related Macular Degeneration

Laser photocoagulation. A good-quality systematic review found laser photocoagulation superior to no treatment for progression of vision loss (loss of 6+ lines of visual acuity) after 3 months (relative risk 1.41, 95% CI 1.08 to 1.82, five trials, N=1413) and 2 years (relative risk 0.67; 95% CI 0.53 to 0.83, five trials, N=1258) (Table 10). ^45^ We rated all trials poor-quality ^128^ – ^132^ due to methodological shortcomings, including use of an open-label design, incomplete follow-up, and lack of intention-to-treat analysis (Table 11 and Appendix C6). In addition, clinical and statistical heterogeneity (I^2^=58%) were present in the pooled analysis. The trials enrolled subjects with visual acuity ranging from normal to worse than 20/200; and the proportion of patients with baseline vision worse than 20/200 ranged from 0% to 34%. The location of choroidal neovascularization (foveal, juxtafoveal, or extrafoveal) also varied. Nonetheless, all trials found a benefit in favor of laser photocoagulation. No trial compared laser photocoagulation to PDT or VEGF inhibitors.

Table 11 Armd - Randomized, Placebo-Controlled Trials

Study, Year, Title | Study design Purpose of study | Patients | Intervention Duration of follow-up | Results | Quality Score
ARMD (Dry)
AREDS Research Group, 2001 ^114^ A randomized, placebo-controlled clinical trial of high-dose supplementation with vitamins C and E, beta carotene and zinc for age-related macular degeneration and vision loss: AREDS Report No. 8 | To evaluate the effect of high-dose vitamins C and E, beta carotene and zic supplements on AMD progression and visual acuity PCT | n=3640 Median age 56 yrs 56% female 96% White; 3% Black; <1% other Mean BCVA at baseline better than 20/32 for all participants | Antioxidant multivitamin - 500 mg vitamin C+400 IU vitamin E+5 mg beta carotene/day zinc 80mg/day antioxidant multivitamin + zinc placebo 7 years | Progession to advanced ARMD: antioxidants vs placebo: OR 0.77 (0.56 to 1.05; p=0.03) zinc vs placebo: OR 0.71 (0.51 to 0.98; p=0.005) antioxidants + zinc vs placebo: OR 0.68 (0.49 to 0.93; p=0.002) Loss of ≥15 letters of VA: antioxidants vs placebo: OR 0.87 (0.67 to 1.15; p=0.20) zinc vs placebo: OR 0.82 (0.63 to 1.08; p=0.07) antioxidants + zinc vs placebo: OR 0.77 (0.58 to 1.03; p=0.02) ORs adjusted for age, sex, race, baseline ARMD category amd smoking status | Good
Feher et al, 2005 ^124^ Improvement of visual functions and fundus alterations in early age-related macular degeneration treated with a combination of acetyl-L-carnitine, n-3 fatty acids and coenzyme Q10 | To determine how a combination of acetyl-L-carnitine, n-3 fatty acids and coenzyme Q10 influenced visual function in patients with early ARMD PCT | n=106 Age 55–70 years; diagnosis of early bilateral ARMD; visual acuity between 8/10 and 4/10 (Snellen decimal scale); agree to discontinue current vitamin regimen; be highly motivated, alert, oriented, mentally competent and able to understand and comply w the requirements of the study | 100mg ALC + 530mg n-3 fatty acids + 10mg CoQ10 2×/day placebo (soy oil) 2×/day 12 month follow-up | Visual acuity in months affected eye (secondary outcome): mean change from baseline at 12 months (Snellen chart) patients ‘improved or unchanged’: 77% (37/48) treatment vs 55% (29/53) placebo patients ‘deteriorated’ 23% (11/48) vs 44% (24/53) NSD in less affected eyes AEs not reported; 3 withdrawals dues to AEs (2 treated group; 1 placebo group) | Fair
Kaiser et al, 1995 ^123^ Visaline in the treatment of age-related macular degeneration | To assess the effect of a multivitamin supplement on ARMD progression | n=20 Mean age 72 yrs 65% female Mean far VA 0.57 | 1.5mg buphenine HCl, 10mg beta carotene, 10mg tocopherol acetate, 50mg ascorbic acid 2 tablets, 2×/day placebo 6 months | Change in mean far VA: multivitamin 0.07 (SD 0.05) vs placebo 0.05 (SD 0.07); p=NS | Fair
Newsome et al, 1988 ^118^ Oral zinc in macular degeneration | To assess the effect of zinc on ARMD progression | n=174 Mean age 67.9 yrs 65% female 32% VA >20/25 | zinc 100mg bid placebo 24 months | Proportion of patients with loss of 3 lines (15 letters) or more: zinc 6/80 (7.5%) vs placebo 11/71 (15.5%) Change in VA (letters lost): zinc -4.1 vs placebo -7.1 | Fair
Richer et al, 1996 ^120^ ARMD Study Group, Multicenter ophthalmic and nutritional age-related macular degeneration study -part 2: antioxidant intervention and conclusions | To assess the effect of a broad-spectrum antioxidant supplement on ARMD PCT | n=71 Mean age 72 yrs 7% female Mean far VA (LogMAR, right eyes) 0.26 | Antioxidant multivitamin (beta carotene 20,000 IU, vitamin E 200 IU, vitamin C 750 mg, citrus bioflavonoid complex 125 mg, quercitin (bioflavonoid) 50 mg, bilberry extract (bioflavonoid) 5 mg, rutin (bioflavonoid) 50 mg, zinc picolinate 12.5 mg, selenium 50 mcg, taurine 100 mg, n-acetyl cysteine 100mg, l-glutathione 5 mg, vitamin B2 25 mg, chromium 100 mcg) qd placebo 18 months | Mean visual acuity at 18 months (Log MAR): antioxidant 0.33 (SE 0.07) vs placebo 0.29 (SE 0.05) | Fair
Richer et al, 2004 ^121^ Double-masked, placebo-controlled, randomized trial of lutein and antioxidant supplementation in the intervention of atrophic age-related macular degeneration: the Veterans LAST study | To determine whether nutritional supplementation with lutein or lutein together with antioxidants, vitamins and minerals improves visual function and symptoms in atrophic ARMD | n=90 Mean age 73 yrs 4% female Mean VA (right eye, LogMAR) 0.377 | 10mg lutein, with or without additional multivitamin 12 months | Change in Snellen letter equivalent: lutein alone +5.4 letters vs lutein/multivitamin +3.5 letters vs placebo -2.1 letters Change in visual acuity: lutein alone -0.10 vs lutein+multivitamin -0.03 vs placebo -0.14 | Fair
Stur et al, 1996 ^122^ Oral zinc and the second eye in age-related macular degeneration | To investigate the short-term effect of oral zinc substitution on the development of age-related macular degeneration in the second eye with exudative ARMD in the first eye | n=112 Mean age 71.5 yrs 57% female Mean VA (LogMAR) 0.0745 | 200mg zinc sulfate placebo 2 years | Change in VA at 24 months: zinc -0.013 (SD 0.01) vs placebo -0.024 (SD 0.01); p=0.52 | Fair
ARMD (Wet)
Laser photocoagulation
Macular Photocoagulation Study Group, 1982 ^128^ Argon laser photocoagulation for senile macular degeneration | To determine if argon laser photocoagulation is useful in preventing severe vision loss in eyes with evidence of macular degeneration | n=224 Mean age not reported: 52/224 age 50–64; 104/224 (46%) age 65–75; 68/224 (30%) age >75 yrs 51% female BCVA 20/32 or better: 105/224 | laser photocoagulation vs no treatment | Increase in lines of VA or no change from baseline at 18 months: treatment group 61/100 (61.0%) vs no-treatment group 30/98 (30.6%) Loss of 2–5 lines of VA at 18 months: treatment group 23/100 (23.0%) vs no-treatment group 16/98 (16.3%) Loss of 6–9 lines of VA at 18 months: treatment group 8/100 (8.0%) vs no-treatment group 24/98 (24.5%) Loss of 10 or more lines of VA at 18 months: treatment group 8/100 (8.0%) vs no-treatment group 16/98 (16.3%) | Poor
Macular Photocoagulation Study Group, 1990 ^129^ Krypton laser photocoagulation for neovascular lesions of age-related macular degeneration | To determine whether krypton laser photocoagulation would be of benefit in preventing visual acuity loss in eyes with ARMD | n=496 Mean age not reported: 26/496 (5%) age 50–59 yrs; 147/496 (29%) age 60–69 yrs; 240/496 (48%) age 70–79 yrs; 83/497 (17%) age ≥80 yrs 53% female BCVA 20/40 or better: 157/496 (32%) Median length of follow-up: 48 months | laser photocoagulation vs no treatment | Increase in lines of VA or no change from baseline at 36 months: treatment group 47/174 (27.0%) vs no-treatment group 29/169 (17.2%) Loss of 2–5 lines of VA at 36 months: treatment group 41/174 (23.6%) vs no-treatment group 42/169 (24.9%) Loss of 6–9 lines of VA at 36 months: treatment group 55/174 (31.6%) vs no-treatment group 54/169 (32.0%) Loss of 10 or more lines of VA at 36 months: treatment group 31/174 (17.8%) vs no-treatment group 44/169(26.0%) | Poor
Macular Photocoagulation Study Group, 1991 ^130^ Laser photocoagulation of subfoveal neovascular lesions in age-related macular degeneration | To determine the effect of laser photocoagulation of subfoveal neovascularization in eyes with ARMD but without previous photocoagulation of the macula | n=373 Mean age not reported: 16/373 (4%) age 50–59 yrs; 80/373 (21%) age 60–69 yrs; 186/373 (50%) age 70–79 yrs; 91/373 (24%) age ≥80 yrs 56% female BCVA 20/20 or better: 106/373 (28%); 20/25–20/100: 190/373 (51%); 20/250 or worse: 76/373 (20%) | laser photocoagulation vs no treatment | Loss of <2 lines of VA at 24 months: treatment group 37/114 (32.5%) vs no-treatment group 20/112 (17.9%) Loss of 2–3 lines of VA at 24 months: treatment group 27/114 (23.7%) vs no-treament group 20/112 (17.9%) Loss of 4–5 lines of VA at 24 months: treatment group 27/114 (23.7%) vs no-treament group 31/112 (27.7%) Loss of ≥6 lines of VA at 24 months: treatment group 23/114 (20.2%) vs no-treament group 41/112 (36.6%) | Poor
Macular Photocoagulation Study Group, 1991 ^131^ Laser photocoagulation of subfoveal recurrent neovascular lesions in age-related macular degeneration | To determine the effect on vision of laser treatment of subfoveal neovascular lesions compared with no treatment | n=206 Mean age not reported: 4/206 (2%) age 50–59 yrs; 57/206 (28%) age 60–69 yrs; 112/206 (54%) age 70–79 yrs; 33/206 (16%) age ≥80 yrs 52% female BCVA 20/20 or better: 70/206(34%); 20/25–20/100: 73/206 (35%); 20/250 or worse: 63/206 (31%) | laser photocoagulation vs no treatment | Loss of <2 lines of VA at 24 months: treatment group 10/35 (28.6%) vs no-treatment group 15/46 (32.6%) Loss of 2–3 lines of VA at 24 months: treatment group 10/35 (28.6%) vs no-treatment group 10/46 (21.7%) Loss of 4–5 lines of VA at 24 months: treatment group 12/35 (34.3%) vs no-treatment group 8/46 (17.4%) Loss of ≥6 lines of VA at 24 months: treatment group 3/35 (8.6%) vs no-treatment group 13/46 (28.3%) | Poor
Moorfields et al, 1982 ^132^ Treatment of senile disciform macular degeneration: a single-blind randomized trial by argon laser photocoagulation | To determine the effects of argon laser photocoagulation in the treatment of neovascular disciform macular degeneration in the elderly | n=128 Baseline characteristics not reported Inclusion criteria required age 50–80 yrs; no description of BCVA at baseline | laser photocoagulation vs no treatment | Loss of <2 lines of VA at 24 months: treatment group 3/51 (5.9%) vs no-treatment group 3/50 (6.0%) Loss of 2–3 lines of VA at 24 months: treatment group 11/51(21.6%) vs no-treatment group 10/50 (20.0%) Loss of 4–5 lines of VA at 24 months: treatment group 14/51 (27.4%) vs no-treatment group 16/50 (32.0%) Loss of ≥6 or more lines of VA at 24 months: treatment group 9/51 (17.6%) vs no-treatment group 14/50 (28%) | Poor
Photodynamic therapy
Azab et al, 2005 ^137^ (VIM Study Group) Verteporfin therapy of subfoveal minimally classic choroidal neovascularization in age-related macular degeneration | To compare the treatment effect and safety of photodynamic therapy with verteporfin using a standard or reduced light fluence rate with that of placebo in patients with subfoveal minimally classic choroidal neovascularization with ARMD | n=117 Mean age 78 yrs Mean BCVA: 20/80 92% subfoveal lesion(s) | verteporfin or placebo IV + photodynamic therapy | Loss of 3 or more lines of VA at 12 months: verteporfin 15/72 (20.8%) vs placebo 18/38 (47.4%); RR 0.93 (ci 0.75 TO 1.15) Loss of 6 or more lines of VA at 12 months: verteporfin 3/72 (4.2%) vs placebo 6/38 (15.8%); RR | Good
TAP Study Group, 1999 ^135^ Photodynamic therapy of subfoveal choroidal neovascularization in age-related macular degeneration: one-year results of 2 randomized clinical trials - TAP Report 1(TAP). [underlined: Other publications]: Kaiser, 2006, TAP and VIP Report 3 | To determine if photodynamic therapy with verteporfin can safely reduce the risk of vision loss in patients with subfoveal choroidal neovascularization | n=609 Mean age 75.3 yrs 56% female 98% White, 2% other Mean BCVA: 20/80-2 89% subfoveal lesion(s) | verteporfin or placebo IV + photodynamic therapy | Loss of 6 or more lines of VA at 12 months: verteporfin 59/402 (14.7%) vs placebo 49/207 (23.7%); RR 0.62 (CI 0.44 to 0.87) Loss of 3 or more lines of VA at 12 months: verteporfin 156/402 (38.8%) vs placebo 111/207 (53.6%); RR 0.72 (CI 0.61 to 0.86) | Good
VIP Study Group, 2001 ^136^ Verteporfin therapy of subfoveal choroidal neovascularization: two-year results of a randomized clinical trial including lesions with occult with no classic choroidal neovascularization - Verteporfin in Photodynamic Therapy Report 2 (VIP) | To determine if photodynamic therapy with verteporfin can safely reduce the risk of vision loss compared with a placebo | n=339 Mean age 75 yrs 99% White; 1% other Mean BVCA: 20/50+1 83.4% subfoveal lesion(s) | verteporfin or placebo IV + photodynamic therapy | Loss of 3 or more lines of VA at 12 months: verteporfin 114/225 (50.7%) vs placebo 62/114 (54.3%); RR 0.44 (CI 0.25 to 0.77) | Good
VEGF inhibitors
Gragoudas et al, 2004 ^144^ Pegaptanib for neovascular age-related macular degeneration (VISION; 2 trials) also: VEGF Inhibitor Study Group, 2006; Leys, 2007 | To test the short-term safety and effectiveness of pegaptanib | n=1208 Mean age NR; Age range 50–64 years: 6%; 65–74 years: 32%; 75–84 years: 52%; ≥85 years: 10% 58% female 96% White; 4% Other Mean visual acuity, study eye: 51.8 letters (SD 12.8) | 0.3mg, 1.0mg or 3.0mg pegaptanib every 6 weeks up to 48 weeks (9 txs) vs sham injection | Patients with loss of <15 letters at 54 weeks: 0.3mg pegaptanib 206/294 (70%) vs. 1.0mg pegaptanib 213/300 (71%) vs. 3.0mg pegaptanib 193/296 (65%) vs. sham injection 164/296 (55%); p<0.05 for all active doses vs. sham injection; NSD between pegaptanib doses. Pooled RR all doses 0.71 (0.60 to 0.84). VA worse than 20/200 at 54 weeks: 0.3mg pegaptanib 111/294 (38%) vs. 1.0mg pegaptanib 128/300 (43%) vs. 3.0mg pegaptanib 129/296 (44%) vs. sham injection 165/296 (56%). Pooled RR all doses 0.69 (0.59 to 0.82). | Fair
Regillo et al, 2008 ^143^ Randomized, double-masked, sham-controlled trial of ranibizumab for neovascular age-related macular degeneration: PIER study year 1 | To evaluate the effectiveness and safety of ranibizumab for the treatment of minimally classic or occult with no classic choroidal neovasculatization associated with ARMD. Prospective, double-blind RCT | n=184 Mean age ~78 yrs 60% female neovascular ARMD | 0.3mg or 0.5mg ranibizumab vs sham injection; dosing 1×/month for 3 months followed by 1× every 3 months 12 months | Mean change from baseline VA at 12 months: 0.3mg -1.6 letters vs 0.5mg -0.2 letters vs sham injection -16.3 letters. Proportion of patients losing ≤15 letters of VA at 12 months: 0.3mg 83.3% vs 0.5mg 90.2% vs sham injection 49.2%; p<0.001 for both doses vs sham Proportion of patients gaining ≥ letters of VA at 12 months: 0.3mg 11.7% vs 0.5mg 13.1% vs sham injection 9.5% Proportion of patients with VA worse than 20/200 at 12 months: 0.3mg 23.3% vs 0.5mg 24.6% v sham injection 52.4% (p=0.001 both doses vs sham) No statistically significant difference between groups in NEI-VFQ 25 subscale score (data not reported) | Good
Rosenfeld et al, 2006 ^145^ MARINA Trial Ranibizumab for neovascular age-related macular degeneration. Other publications: Boyer et al, 2007 | To evaluate the effectiveness and safety of ranibizumab for the treatment of minimally classic or occult with no classic choroidal neovasculatization associated with ARMD. Double-blind PCT | n=716 Mean age 77 years (SD 8) 65% female ARMD | 0.3mg or 0.5mg ranibizumab 1×/month (range 23–37 days) for 2 years vs sham injection 2 years | Mean change in visual acuity at 12 months: ranibizumab 0.3mg 6.5 letters vs. ranibizumab 0.5mg 7.2 letters vs. placebo -10.4 letters; p<0.001 for both doses ranibizumab vs. placebo. Mean change in visual acuity at 24 months: ranibizumab 0.3mg 5.4 letters vs. ranibizumab 0.5mg 6.6 letters vs. placebo -14.9 letters; p<0.001 for both doses ranibizumab vs. placebo. % of patients with <15 letters lost at 12 months: ranibizumab 0.3mg 94.5% vs. ranibizumab 0.5mg 94.6% vs. placebo 62.2%; p<0.001 for both doses ranibizumab vs. placebo. % of patients with <15 letters lost at 24 months: ranibizumab 0.3mg 92.0% vs. ranibizumab 0.5mg 90.0% vs. placebo 52.9%; p<0.001 for both doses ranibizumab vs. placebo | Fair

Abbreviations: AE = adverse event, ARMD = age-related macular degeneration, CCT = center for clinical trials, CRVO = central retinal vein occlusion, ETDRS = early treatment diabetic retinopathy study, PCT = placebo controlled trial.

Photodynamic therapy with verteporfin. Two good-quality systematic reviews of PDT found verteporfin superior to placebo for preventing loss of visual acuity (Table 10). ^133,^ ^134^ Both reviews included the Treatment of Age-Related Macular Degeneration With Photodynamic Therapy (TAP) Investigation ^135^ and the Verteporfin in Photodynamic Therapy (VIP) Trial. ^136^ The more recent of the two reviews ^134^ also included a third trial, the Visudyne in Minimally Classic Choroidal Neovascularisation (VIM) Trial. ^137^ We rated VIM fair-quality ^137^ and TAP and VIP good-quality (Table 11 and Appendix C6). ^135,^ ^136^ Pooling all three trials (N=1065), one systematic review found verteprofin associated with a risk ratio reduction in loss of 3 or more lines of visual acuity of 0.22 after 2 years (CI 0.13 to 0.30), with a number-needed-to-treat of seven. ^134^ Three and 5-year results of open-label extension of the TAP study were similar to 2-year results. ^138,^ ^139^

None of the verteporfin trials reported quality of life outcomes. Two small, prospective observational studies that enrolled a total of 130 patients, most with classic choroidal neovascularization, found VF-14 scores decreased (indicating worse vision-related quality of life) following treatment, but the decrease was not statistically significant. ^140,^ ^141^ Neither the TAP nor VIP trials found significant differences between verteporfin and placebo in risk of deaths two years after treatment, ^133^ and no deaths were reported during the 2-year VIM trial. ^137^

Intravitreal injection of VEGF inhibitors. A good-quality systematic review found intravitreal injection with the VEGF inhibitors pegaptanib or ranibizumab effective for preventing visual acuity loss (defined as > 15 letters or 3 lines loss) and reducing the risk of blindness (defined as visual acuity worse than 20/200), based on three fair-quality, placebo-controlled trials (Tables 10 and 11). ^142^ A good-quality trial of ranibizumab that was not included in the systematic review also found it to be effective for outcomes related to visual acuity. ^143^ For pegaptanib at doses of 0.3, 1, or 3 mg, the systematic review found a pooled relative risk versus placebo of 0.71 for visual acuity loss (CI 0.60 to 0.84, two trials, ^144^ N=1186) at 12 month follow-up; the number-needed-to-treat to prevent one case of visual acuity loss ranged from 7 to 14 depending on the dose evaluated. ^142^ Pegaptanib also reduced the risk of blindness (visual acuity worse than 20/200) compared to placebo (relative risk 0.69; 95% CI 0.59 to 0.82, two trials). In two trials (N=900), ranibizumab at 0.3 or 0.5 mg was also associated with decreased risk of visual acuity loss (relative risk 0.21, 95% CI 0.16 to 0.27, Figure 2) and blindness (relative risk 0.35, 95% CI 0.21 to 0.57, Figure 3) compared to placebo at 12 months, with a number-needed-to-treat of about 2.5. ^143,^ ^145^ Results at 24 months were similar to those at 12 months in one of the trials. ^145^

Figure 2. Visual Acuity Loss >15 Letters, Ranibizumab vs. Placebo

Figure 3. Visual Acuity Worse Than 20/200, Ranibizumab vs. Placebo

Vision-associated function was assessed in three good-quality trials of VEGF inhibitors, though they were not primary outcomes in any study. ^143,^ ^146,^ ^147^ One trial found ranibizumab associated with a 5.2 to 5.6 point increases in composite NEI-VFQ scores at 1-year, compared to a decrease of 2.8 points with placebo (p<0.01 for difference). ^146^ Benefits were largely sustained through two years. A second trial found no difference between ranibizumab and placebo in mean scores on the near activities, distance activities, or vision-specific dependency subscales on the NEI-VFQ at one year. ^143^ One trial of pegaptanib reported outcomes on four (of 12) NEI-VFQ domains, including near vision, distance vision, role limitations and dependency. ^147^ While there was a trend towards improvement in the near and distance vision domains, differences were not statistically or clinically significant. Composite NEI-VFQ scores were not reported.

One fair-quality, head-to-head trial (N=423) found ranibizumab superior to verteprofin PDT after 12 months for likelihood of losing < 15 letters (94–96% vs 64%) or gaining > 15 letters (36–40% vs 6%) of visual acuity. ^148^ Quality of life outcomes were not evaluated.

Combination therapy. The efficacy of PDT in combination with an intravitreal injection (ranibuzumab or corticosteroid) was studied in two trials (reported in three publications). ^149^ – ^151^ Based on the proportion of patients losing < 15 letters of visual acuity, one study (N=162) found combination therapy with ranibizumab superior to PDT alone (90.5% vs 67.9%; p<0.001) after 1-year of follow-up. ^151^ These results were attenuated but remained statistically significant at 2-years (87.6% vs 75.0%; p=0.04). ^149^ In the other trial, there was no significant difference between combination therapy with triamcinolone plus PDT versus PDT alone on this outcome (74.1% vs. 61.5%; p=0.78, N= 61). ^150^ Neither trial evaluated quality of life.

Other therapies. Good-quality Cochrane reviews found insufficient evidence to conclude that radiotherapy (11 trials), ^50^ intravitreal corticosteroids (three trials), ^48^ or intravitreal injection of interferon alfa (one trial) ^49^ are effective for treatment of wet ARMD. Macular translocation surgery was effective but associated with high rates of adverse events in a pilot trial and is not recommended as first-line therapy. ^152,^ ^153^ Submacular surgery was no more effective than observation. ^154^

## Key Question 5. Are there harms of treating early impairment in visual acuity due to uncorrected refractive error, cataracts or age-related macular degeneration?

### Summary

Data on harms associated with eyeglasses are limited to a small observational study showing an association between multifocal lens use and increased risk of falls in older adults (adjusted OR 2.09, 95% CI 1.06 to 4.92). Harms associated with other treatments for uncorrected refractive errors have also not been well-studied, but available data suggest a low incidence of serious harms such as infectious keratitis (contact lenses 0.3 to 0.9 cases per 10,000 wearers and photorefractive surgery 0% to 3.4%) and corneal ectasia (photorefractive surgery median rate 0.2%). The most common long-term complication of cataract extraction and intraocular lens implantation is posterior capsule opacification, which is present in over one-quarter of patients after 5 years. Serious complications such as endophthalmitis are rare (0.13%). For dry ARMD, data from the large AREDS trials found antioxidant vitamins and minerals associated with increased risk of hospitalization for genitourinary causes (zinc) and yellow skin (antioxidants). In patients with wet ARMD, laser photocoagulation and PDT are associated with acute vision loss, including severe loss with the latter treatment (2% with PDT vs. 0.2% with placebo). However, long-term visual outcomes favor both of these treatments (see KQ 4). Serious harms appear to be uncommon following intravitreal injection with the VEGF inhibitors pegaptanib and ranibizumab, but evidence on long-term harms is not yet available.

### Evidence

#### Uncorrected refractive error

Corrective lens. We identified no studies that evaluated harms associated with monofocal eyeglasses. One prospective study (N=87) found multifocal lens (bifocals, trifocals or progressive lens) associated with higher risk of falls in older adults (adjusted OR 2.09, 95% CI 1.06 to 4.92). ^155^

Contact lens use, particularly the extended-wear type, is associated with keratitis, or inflammation (infectious or non-infectious) of the cornea. ^156,^ ^157^ Two large (each enrolling > 10,000 subjects) prospective observational studies found incidence of vision loss due to infectious keratitis ranged from 0.3 to 0.9 cases per 10,000 wearers, regardless of age. ^158,^ ^159^ Risk of keratitis increased substantially in a prospective study of extended-wear contact lens to 3.6 (CI 0.4 to 12.9) cases per 10,000 wearers; ^160^ and age > 50 years was found to increase risk of developing keratitis compared to age ≤ 25 years (OR 2.04; CI 1.40 to 2.98) in another prospective study. ^161^

Photorefractive surgery. Photorefractive surgery is associated with subsequent corneal ectasia (bulging forward of the cornea due to weakening of supporting structures following surgery) and infectious keratitis, although their incidence has not been well reported. A good-quality systematic review of 27 trials and 130 observational studies only identified five studies reporting rates of corneal ectasia, with a median rate of 0.2% (range 0% to 0.87%) following LASIK surgery. ^85^ No studies reported rates of ectasia in PRK or LASEK-treated patients. It also found rates of infectious keratitis ranged from 0% to 0.16% following LASIK and 0% to 3.4% following LASEK, but this outcome was only reported in six LASIK (including four studies reporting no cases) and four LASEK studies. ^85^

#### Cataract

Posterior capsule opacification of surgically implanted lens is the most common long-term complication following cataract surgery, ^162^ though it is usually readily treated with a brief external laser procedure. In one good-quality systematic review, 41 primarily uncontrolled studies published between 1979 and 1991 reported rates of posterior capsule opacification which ranged from 0.7% to 47.6% after 60 days to 5 years (pooled rate 19.7%; CI 19.1 to 20.3). ^91,^ ^92^ A more recent systematic review of 49 studies found a pooled incidence of posterior capsule opacification of 11.8% (range 9.3 to 14.3%) at 1-year, 20.7% (range 16.6 to 24.9%) at 3-years and 28.4% (range 16.6 to 24.9%) at 5-years. ^163^

A fair-quality systematic review of 215 observational studies (quality of included studies was not assessed) found a 0.13% rate of endophthalmitis, a serious inflammation of the intraocular cavities potentially associated with permanent vision loss, following cataract surgery. ^164^ Additional analyses suggested that the rate of endophthalmitis may be increasing, with a relative risk of 2.44 (CI 2.27 to 2.61) for surgeries completed since the year 2000 compared to surgeries in earlier decades, a finding that temporally coincides with increased use of sutureless clear corneal incisions. ^164^

Other major complications associated with cataract surgery include bullous keratopathy (0.13%, 95% CI 0.2 to 0.4), dislocation of intraocular lens (0.3%, 95% CI 0.9 to 1.2), clinical cystoid macular edema (95% 1.4%, CI 1.2 to 1.6), and retinal detachment (0.7%, 95% CI 0.6 to 0.8%). ^91^

#### Dry (nonexudative) Age-related Macular Degeneration

Antioxidant vitamins and minerals. A good-quality systematic review of nine trials found no clear association between zinc supplementation for treatment of dry ARMD and withdrawal due to gastrointestinal symptoms, but the number of events was small (5/146 in zinc-treated patients versus 2/140 in controls). ^43^ The large AREDS trial found treatment with zinc associated with significantly increased risk of hospitalization for genitourinary causes compared to non-use of zinc (11.1% versus 7.6%; p=0.0003) and treatment with antioxidants associated with increased risk of yellow skin compared to non-use of antioxidants (8.3% vs. 6.0%, p=0.008). ^113,^ ^165^ There was no association between antioxidant supplementation and increased hospitalizations, mortality, or lung cancer. Risk of congestive heart failure was not specifically reported. Other trials of antioxidants for dry ARMD found no clear association with adverse events at the doses evaluated, ^121,^ ^123^ though assessment and reporting of harms was generally suboptimal.

#### Wet (exudative) Age-related Macular Degeneration

Laser photocoagulation. A good-quality systematic review of 15 trials found laser photocoagulation associated with increased risk of visual acuity loss ≥ 6 lines compared to observation 3 months after treatment (absolute rate 16.6%; relative risk 1.41, 95% CI 1.08 to 1.82, five trials). ^45^ However, laser photocoagulation was superior to observation on visual acuity outcomes by 2 years (see KQ 4).

Photodynamic therapy with verteporfin. A good-quality systematic review of three trials found verteporfin associated with greater risk of acute severe visual acuity loss (20 letter loss within 7 days of treatment) compared to placebo (2% vs. 0.2%, relative risk 0.02, 95% CI 0.01 to 0.03, number needed to harm 50). ^134^ The systematic review also found verteporfin associated with a greater risk of infusion-related back pain compared to placebo (3.4% vs. 0.3%, relative risk 6.50, 95% CI 1.52 to 27.78).

Intravitreal injection of vascular endothelin growth factor inhibitors. A good-quality trial found 5 cases of presumed endophthalmitis, 6 cases of uveitis, and 11 cases of post injection intraocular pressure greater than 40 mm Hg among 477 patients treated with ranibizumab, compared to 0 cases for any of these adverse events among 236 patients treated with sham injections. ^145^ There were no clear differences in rates of hypertension or thromboembolic events. A second, smaller trial reported no cases of endophthalmitis or uveitis following ranibizumab intraveitreal injection, and did not report post injection intraocular pressure. ^143^

A study that pooled data from two similarly designed trials of pegaptanib (N=892 pegaptanib-treated patients) found a rate of endophthalmitis of 1.3% (0.16% per injection, with 1 of 12 cases associated with 6+ lines of vision loss), 0.6% for traumatic cataract (0.07% per injection, 1 of 5 cases associated with severe vision loss), and 0.7% for retinal detachment (0.08% per injection, no cases associated with severe vision loss) following 1 year of treatment. ^166^ There were no differences between pegaptanib and placebo in rates of hypertensive or thromboembolic events.

A head-to-head trial reported 2 cases of endophthalmitis and 1 case of uveitis among 277 patients treated with ranibizumab, compared to no cases among 143 patients treated with verteporfin, with no differences in rates of hypertension or arterial thromboembolic events. ^148^ A second trial found 18 serious ocular adverse events among 105 patients treated with ranibizumab plus verteporfin, compared to 8 cases among 56 patients treated with photodynamic therapy alone. ^149^ Among the serious adverse events in the combination therapy group were 3 cases of endophthalmitis and 4 cases of uveitis (none reported in the PDT alone arm).

The manufacturer of ranibizumab sent a letter to clinicians in January 2007 regarding preliminary results of an ongoing trial that found increased stroke rates in patients treated with higher doses of intravitreal ranibizumab. Results of that trial have not yet been published, although 1-year data reported at a conference in February 2008 showed no difference in stroke rates regardless of dose (http://www.retinatoday.com/issues/0308/0308_01.php).