# Acknowledgements

The authors acknowledge Andrew Hamilton, MLS, MS, Oregon Health & Science University, for assistance with literature searches, Michelle Pappas, BA, Oregon Health & Science University, for administrative and formatting assistance, Rongwei Fu, PhD, Oregon Health & Science University, for statistical assistance, and Rebecca Armour, MD, Oregon Health & Science University, for her expertise. We also thank AHRQ Medical Officer Tracy Wolff, MD, MPH and U.S. Preventive Services Task Force leads Rosanne Leipzig, MD, PhD; Michael LeFevre, MD, MSPH; Timothy Wilt, MD, MPH; and Diana Petitti, MD, MPH; for their contributions to this report.