# Appendix 1: PubMed search terms and exclusion criteria

PubMed search terms and limits:

(“neural tube defects”[MeSH Terms] OR “spina bifida”[All Fields] OR “neural tube damage”[All Fields] OR “neural tube defect”[All Fields] OR “neural tube defects”[All Fields] OR “neural tube disorders”[All Fields] AND ((“1995/01/01”[PDAT] : “2007/11/30”[PDAT]) AND English[lang])) AND ((“folic acid”[MeSH Terms] OR folic acid[Text Word]) AND ((“1995/01/01”[PDAT] : “2007/11/30”[PDAT]) AND English[lang])) AND ((“pregnancy”[MeSH Terms] OR pregnancy[Text Word]) AND ((“1995/01/01”[PDAT] : “2007/11/30”[PDAT]) AND English[lang])) AND

[underlined: Exclusion Criteria for Folic Acid in Pregnancy Review]

1 A study not on folic acid supplementation
2 Incorrect study type
3 In a setting not generalizable to US
4 Not in women of child bearing age
5 No outcomes of interest
6 High risk or special population (ex. Prior NTD)
7 n < 100
8 Duplicate study