# References

1 Bentley TG, Willett WC, Weinstein MC, Kuntz KM. Population-level changes in folate intake by age, gender, and race/ethnicity after folic acid fortification. Am J Public Health. 2006;96(11):2040-7. [pmid: 17018833].
2 Force USPST. Screening for Neural Tube Defects - Including Folic Acid/Folate Prophylaxis. In: Guide to Clinical Preventive Services. Second Edition ed. Washington, DC Office of Disease Prevention and Health Promotion; 1996:467–83.
3 Mathews TJ. Trends in Spina Bifida and Anencephalus in the United States, 1991-2005: National Center for Health Statistics; 2007.
4 Tamura T, Picciano MF. Folate and human reproduction. Am J Clin Nutr. 2006;83(5):993-1016. [pmid: 16685040].
5 Eichholzer M, Tonz O, Zimmermann R. Folic acid: a public-health challenge. Lancet. 2006;367(9519):1352-61. [pmid: 16631914].
6 Lumley J, Watson L, Watson M, Bower C. Periconceptional supplementation with folate and/or multivitamins for preventing neural tube defects. Cochrane Database Syst Rev. 2001(3):CD001056.
7 American College of Obstetricians and Gynecologists. Neural tube defects. ACOG Practice Bulletin No. 44. Obstet Gynecol. 2003;102:203-13. [pmid: 12850637].
8 Nussbaum RL, McInnes RR, Willard HF. Genetics of disorders with complex inheritance. In: Thompson & Thompson Genetics in Medicine. 6th ed. Philadelphia: WB Saunders; 2001:289–310.
9 Botto LD, Moore CA, Khoury MJ, Erickson JD. Neural-tube Defects. NEJM. 1999;341:1509-19. [pmid: 10559453].
10 Feuchtbaum LB, Currier RJ, Riggle S, Roberson M, Lorey FW, Cunningham GC. Neural tube defect prevalence in California (1990-1994): Eliciting patterns by type of defect and maternal race/ethnicity. Genet Test. 1999;3:265-72. [pmid: 10495925].
11 Shaer CM, Chescheir N, Schulkin J. Myelomeningocele: a review of the epidemiology, genetics, risk factors for conception, prenatal diagnosis, and prognosis for affected individuals. Obstet Gynecol Surv. 2007;62(7):471-9. [pmid: 17572919].
12 Knowledge and use of folic acid by women of childbearing age—United States, 1997. MMWR Morb Mortal Wkly Rep. 1997;46(31):721-3. [pmid: 9262072].
13 Use of supplements containing folic acid among women of childbearing age—United States, 2007. MMWR. 2008;57(01):5-8. [pmid: 18185493].
14 Yang QH, Carter HK, Mulinare J, Berry RJ, Friedman JM, Erickson JD. Race-ethnicity differences in folic acid intake in women of childbearing age in the United States after folic acid fortification: findings from the National Health and Nutrition Examination Survey, 2001-2002. Am J Clin Nutr. 2007;85(5):1409-16. [pmid: 17490980].
15 Honein MA, Paulozzi LJ, Mathews TJ, Erickson JD, Wong LYC. Impact of Folic Acid Fortification of the US Food Supply on the Occurrence of Neural Tube Defects. JAMA. 2001;285(23):2981-86. [pmid: 11410096].
16 Spina bifida and anencephaly before and after folic acid mandate—United States, 1995-1996 and 1999-2000. MMWR Morb Mortal Wkly Rep. 2004;53(17):362-5. [pmid: 15129193].
17 Vollset SE, Gjessing HK, Tandberg A, et al. Folate supplementation and twin pregnancies. Epidemiology. 2005;16(2):201-5. [pmid: 15703534].
18 Czeizel A, Dudas I. Prevention of the first occurrence of neural-tube defects by periconceptional vitamin supplementation. NEJM. 1992;327:1832-35. [pmid: 1307234].
19 Werler M, Shapiro S, Mitchell A. Periconceptional folic acid exposure and risk of occurrent neural tube defects. JAMA. 1993;269:1257-61. [pmid: 8437302].
20 Daly LE, Kirke PN, Molloy A, Weir DG, Scott JM. Folate levels and neural tube defects. Implications for prevention. Jama. 1995;274(21):1698-702. [pmid: 7474275].
21 Daly S, Mills J, Molloy A, et al. Minimum effective dose of folic acid for food fortification to prevent neural-tube defects. Lancet. 1997;350:1666-69. [pmid: 9400511].
22 MRC Vitamin Study Research Group. Prevention of neural tube defects: results of the Medical Research Council Vitamin Study. Lancet. 1991;338:132-37.
23 CDC. Use of folic acid for prevention of spina bifida and other neural tube defects: 1983-1991. MMWR. 1991;40:513-16. [pmid: 2072886].
24 Wald NJ, Law MR, Morris JK, Wald DS. Quantifying the effect of folic acid. Lancet. 2001;358(9298):2069-73. [pmid: 11755633].
25 Moore LL, Bradlee ML, Singer MR, Rothman KJ, Milunsky A. Folate intake and the risk of neural tube defects: an estimation of dose-response. Epidemiology. 2003;14(2):200-5. [pmid: 12606886].
26 Thompson SJ, Torres ME, Stevenson RE, Dean JH, Best RG. Periconceptional multivitamin folic acid use, dietary folate, total folate and risk of neural tube defects in South Carolina. Ann Epidemiol. 2003;13(6):412-8. [pmid: 12875798].
27 Berry RJ, Li Z, Erickson JD, et al. Prevention of neural-tube defects with folic acid in China. China-U.S. Collaborative Project for Neural Tube Defect Prevention. N Engl J Med. 1999;341(20):1485-90. [pmid: 10559448].
28 Czeizel A, Metneki J, Dudas I. The higher rate of multiple births after periconceptional multivitamin supplementation: an analysis of causes. Acta Genet Med Gemellol (Roma). 1994;43(34):175-84.
29 Li Z, Gindler J, Wang H, et al. Folic acid supplements during early pregnancy and likelihood of multiple births: a population-based cohort study. Lancet. 2003;361(9355):380-4. [pmid: 12573374].
30 Berry R, Kihlberg R, Devine O. Impact of misclassification of in vitro fertilisation in studies of folic acid and twinning: modelling using population based Swedish vital records. BMJ. 2004;330:815. [pmid: 15722370].
31 Lumley J, Watson L, Watson M, Bower C. Modelling the potential impact of population-wide periconceptional folate/multivitamin supplementation on multiple births. Bjog. 2001;108(9):937-42. [pmid: 11563463].
32 CDC. Blood folate and vitamin B12: United States: 1988-94. Vital Health Statistics. 1998;11(243).
33 Mills J, Von Kohorn I, Conley M, et al. Low vitamin B-12 concentrations in patients without anemia: the effect of folic acid fortification of grain. Am J Clin Nutr. 2003;77:1474-7. [pmid: 12791626].
34 Czeizel AE, Toth M, Rockenbauer M. Population-based case control study of folic acid supplementation during pregnancy. Teratology. 1996;53(6):345-51. [pmid: 8910980].
35 Locksmith GJ, Duff P. Preventing neural tube defects: the importance of periconceptional folic acid supplements. Obstet Gynecol. 1998;91(6):1027-34. [pmid: 9611019].
36 Kallen BA, Olausson PO. Use of folic acid and delivery outcome: a prospective registry study. Reprod Toxicol. 2002;16(4):327-32. [pmid: 12220592].
37 Lumley J, Watson L, Watson M, Bower C. Periconceptional supplementation with folate and/or multivitamins for preventing neural tube defects. Cochrane Database Syst Rev. 2001(3):CD001056.
38 Medveczky E, Puho E. Parental employment status and neural-tube defects and folic acid/multivitamin supplementation in Hungary. Eur J Obstet Gynecol Reprod Biol. 2004;115(2):178-84. [pmid: 15262352].
39 Shaw GM, Nelson V, Carmichael SL, Lammer EJ, Finnell RH, Rosenquist TH. Maternal periconceptional vitamins: interactions with selected factors and congenital anomalies?. Epidemiology. 2002;13(6):625-30. [pmid: 12410002].
40 Shaw GM, Rozen R, Finnell RH, Wasserman CR, Lammer EJ. Maternal vitamin use, genetic variation of infant methylenetetrahydrofolate reductase, and risk for spina bifida. Am J Epidemiol. 1998;148(1):30-7. [pmid: 9663401].
41 Shaw GM, Todoroff K, Carmichael SL, Schaffer DM, Selvin S. Lowered weight gain during pregnancy and risk of neural tube defects among offspring. Int J Epidemiol. 2001;30(1):60-5. [pmid: 11171858].
42 Shaw GM, Velie EM, Schaffer D. Risk of neural tube defect-affected pregnancies among obese women. Jama. 1996;275(14):1093-6. [pmid: 8601928].
43 Suarez L, Hendricks KA, Cooper SP, Sweeney AM, Hardy RJ, Larsen RD. Neural tube defects among Mexican Americans living on the US-Mexico border: effects of folic acid and dietary folate. Am J Epidemiol. 2000;152(11):1017-23. [pmid: 11117610].
44 Ericson A, Kallen B, Aberg A. Use of multivitamins and folic acid in early pregnancy and multiple births in Sweden. Twin Res. 2001;4(2):63-6. [pmid: 11665336].
45 Czeizel AE, Vargha P. Periconceptional folic acid/multivitamin supplementation and twin pregnancy. Am J Obstet Gynecol. 2004;191(3):790-4. [pmid: 15467542].
46 Kallen B. Use of folic acid supplementation and risk for dizygotic twinning. Early Hum Dev. 2004;80(2):143-51. [pmid: 15500994].
47 Czeizel AE, Dobo M, Vargha P. Hungarian cohort-controlled trial of periconceptional multivitamin supplementation shows a reduction in certain congenital abnormalities. Birth Defects Res A Clin Mol Teratol. 2004;70(11):853-61. [pmid: 15523663].
48 Goh YI, Bollano E, Einarson TR, Koren G. Prenatal multivitamin supplementation and rates of congenital anomalies: a meta-analysis. J Obstet Gynaecol Can. 2006;28(8):680-9. [pmid: 17022907].
49 Shaw GM, Schaffer D, Velie EM, Morland K, Harris JA. Periconceptional vitamin use, dietary folate, and the occurrence of neural tube defects. Epidemiology. 1995;6(3):219-26. [pmid: 7619926].