# Discussion

## Dose of Folic Acid Supplementation

There are considerable difficulties in determining the most effective dose, form, and timing of folic acid supplementation for prevention of first NTDs. RCTs provide the best opportunity to make these determinations, but there has only been a single RCT assessing women without a history of a previously affected child.(18) In this study, women who were treated periconceptionally with 0.8 milligrams per day had a statistically significantly lower risk of NTDs, but there was no opportunity to study other doses in the setting of this RCT. Observational studies have also attempted to answer these questions about dosage, but are plagued by difficulties of accurate exposure assessment (dose, form, and timing); heterogeneity with respect to whether studies accounted for supplements, fortified foods, and dietary intake of naturally-occurring folate; and variability in bioavailability of various sources.

One of the studies cited in the 1996 USPSTF report presented findings that could serve as an estimate of the minimal dose effective at reducing NTD risk.(19) This study derived relative risks according to daily folic acid dose among 18 case mothers and 322 control mothers, and found that patients taking 0.4 mg/day from one month before to one month after the last menstrual period had a 70% reduction in risk of NTD (RR 0.3, 95% CI 0.1,-0.6), while those taking less than 0.4 mg (but still taking some supplementation) had a non-statistically significant reduced risk of 50% (RR 0.5, 95% CI 0.2–1.5); the latter group consisted of only 53 women however, making definitive conclusions difficult.(19)

Due to the difficulty of assessing doses in observational studies, other studies have attempted to answer this question by relating the risk of NTDs instead to serum or red blood cell folate levels. In a case-control study in Dublin, Ireland, that examined maternal red-cell and plasma folate levels and risk of NTD, the risk of NTD decreased from 6.6 per 1000 births when red-cell folate levels were below 150 nanograms/mL to 0.8 per 1000 births at a level of greater than 400 nanograms/mL.(20) Most importantly, NTD risk was found to be inversely associated with red-cell folate levels in a continuous relationship. In another study by Daly (21), data demonstrated that women living in a country without mandatory fortification who take 200 micrograms of additional folic acid per day achieve red cell folate levels that exceed 400 nanograms/mL, the level shown in the previous study to be associated with decreased NTD risk. The authors estimated that adding 400 micrograms, 200 micrograms, and 100 micrograms daily could reduce NTD incidence by 47%, 41% and 22% respectively.(21)

More recently, Wald and colleagues (24) used published data on “dose” (folic acid intake) and “response” (serum folate concentrations and risk of NTD) to develop a model with which to predict responses to specific increases in folic acid intake. They used data on the effects of folic acid supplementation on serum folate from 13 published studies and then attempted to relate doses to outcomes of NTDs based on serum folate levels from the Daly (20) study mentioned above. At an increased level of 0.2 mg/day, the % risk reduction of NTDs was calculated to be 36% for a woman with a background serum folate of 2.5 ng/mL, 23% with baseline folate of 5.0 ng/mL (typical western diet, according to authors), and 13% with a background of 10 ng/mL. The authors of this study assert that maximal benefit can be derived by taking an additional 5.0 mg per day (in the form of a supplement), which would reduce risk of NTDs by 85% in women with a background folate intake of 5.0 ng/mL. However, the authors discount concerns about adverse effects of high levels of folate supplementation, despite a lack of studies investigating harms of such doses.

Other investigators have also taken into account both folic acid supplementation and dietary folate. In one study, dietary and supplement information from 23 228 women in the northeastern United States was collected in the early second trimester of pregnancy (25). Accounting for differing bioavailability of folate from varying sources, the authors converted all sources of folate to dietary folate-equivalent units and estimated the prevalence of NTDs according to individual and total sources of folate. They identified a dose-response relationship between increasing folate equivalents per day and decreasing prevalence of NTDs (p-value for linear trend of 0.016). Thompson and colleagues (26) also attempted to relate the risk of NTDs to total intake. In a case-control study of 487 women, they demonstrated decreased risk of NTDs at the highest quartiles of total folate intake (0.880–3.125 mg/day) (OR 0.35, 95% CI 0.17–0.72), but no significant dose-response relationship with supplement dose alone.

## Benefits of Folic Acid Supplementation

New evidence from observational studies provides weight to previous evidence from controlled trials that folic acid supplementation provides benefit in reduction of risk from NTD-affected pregnancies. We found four studies of the benefits of supplementation, of fair or good quality, published since the previous 1996 USPSTF report. Odds ratios for reductions in NTDs associated with periconceptional folic acid supplementation ranged from 0.11 to 0.65 in cohort and case-control studies. A meta-analysis reported an OR for NTDs inversely associated with multivitamin use of 0.67 in case-control studies and 0.52 in RCTs and cohort studies.

A study that was excluded from our review because it was performed in a population not generalizable to the United States deserves discussion. This cohort study evaluated the pregnancy outcomes of 130 142 women in 3 provinces in China who were asked during their premarital medical examination to take a 0.4 mg daily folic acid supplement.(27) Periconceptional use of a folic acid supplement was associated with an approximately 40–80% reduction in risk of NTD-affected pregnancies; the reduction was greater in a region with higher pre-study rates of NTDs. While the direct applicability of these specific rate reductions to the United States population is limited by the differences in the two countries' nutritional levels, these results nevertheless lend additional strength to the evidence on benefit.

## Harms of Folic Acid Supplementation

The only RCT included in the 1996 USPSTF report on the prevention of first occurrence NTDs noted an increase in the risk of twinning among multivitamin users (28). These findings were not statistically significant when the data were re-analyzed and twin deliveries were considered as the outcome instead of twin births (29). In our current review, we attempted to identify all studies published since 1996 that examined twinning as an outcome. The one fair-quality study that was included found no association between preconceptional folic acid use and twinning; this study differed from previous studies because it accounted for both the high rate of underreporting of folic acid use (seen in many populations and studies) and the use of IVF. Another study, excluded based on population, that found no association with twinning was the prospective study from China discussed above, in which exposure assessment was likely fairly accurate and IVF and ovulation induction were not prevalent confounding factors (39).

One additional study that warrants discussion here was excluded from the systematic review because it was of a study type that did not meet inclusion criteria (31). The authors of this study used Australian pregnancy and birth and morbidity and mortality data as well as pooled estimates of relative risks for NTDs and twinning from previous trials to model the impact of periconceptional folate on NTDs and twinning in a hypothetical cohort of 100 000 pregnancies. They concluded that, although full supplementation could result in 119 fewer NTDs (95% CI, -74–141), it would result in approximately 1144 (95% CI, -200–3174) more twin births after 20 weeks' gestation. The estimated RR of twinning was from studies that did not address potential confounders such as IVF or ovulation induction. Although this study offers a unique perspective, its applicability to a United States population is limited.

Other potential concerns about folic acid supplementation include masking of vitamin B12 deficiency. Our current review yielded no evidence to support or refute this possible harm. However, given the low prevalence of vitamin B12 depletion in young women, it is unlikely that folic acid supplementation in women of childbearing age would result in a significant number of cases of neurological sequelae due to masking of vitamin B12 deficiency. In a study using data from NHANES and the Hispanic Health and Nutrition Examination Survey, the CDC National Center for Health Statistics reported in 1998 that under 1% of the total population between 4 and 50 years of age had serum vitamin B12 less than 100 pg/mL, the level below which vitamin B12 deficiency is likely.(32) Furthermore, in an ecologic study comparing patients in pre- and post- folic acid fortification periods, there was no evidence of an increase in low vitamin B12 levels without anemia.(33) Finally, folic acid supplementation is often given in the form of a multivitamin or prenatal vitamin that includes supplementation with B12, reducing the likelihood of masking of B12 deficiency in this population.

## Limitations

This review looked specifically for studies on NTDs and therefore does not include a comprehensive picture of how folic acid-containing supplements may prevent other congenital abnormalities. We did not review the evidence on counseling to increase dietary intake of folic acid. We reviewed the overall effect of folic acid on NTDs and did not comprehensively review the evidence on how the effect may differ among ethnic groups and among groups with genetic differences that may affect the metabolism of folic acid.

## Acknowledgements

The authors would like to express their gratitude to Gloria Washington, Coordinator of the USPSTF program, who spent many hours tracking down articles and keeping us organized. We would also like to thank AHRQ librarian, Caryn McManus, for her expert assistance in navigating PubMed and Endnote. We would especially like to acknowledge Mary Barton, Scientific Director of AHRQ's Center for Primary Care, Prevention and Clinical Practice, and the following Task Force members for their expert guidance during this review: Lucy Marion, Kimberly Gregory, and Tom DeWitt.