# Results

Our search for evidence from PubMed, Cochrane library, reference lists, and experts returned 810 articles. Details on reasons for exclusions are in Figure 2. The most common reason for exclusion was incorrect study type; most were letters, editorials, or non-systematic reviews. Many were also excluded because the studies were not on folic acid supplementation; most of these were on folic acid fortification of foodstuffs. There were several additional common reasons for exclusion: the study was in a setting that was not thought to be generalizable to the United States; the study was a subanalysis of previously included data; or the study did not report overall outcomes as benefits in the reduction of NTD or harms associated with folic acid. Four studies for the key question on benefits and one study for the key question on harms ultimately met inclusion criteria and were of appropriate methodological quality. Studies that initially met inclusion criteria, and that were abstracted and quality-rated but ultimately excluded are discussed in Table 1 (KQ1-benefits) and Table 2 (KQ2 - harms).

Figure 2. Search results and article flow

Table 1 Studies excluded after abstraction and quality rating - key question on benefits

Study | Methods | Notes/Reason for Exclusion
Czeizel, 1996 (34) | Case-control study of participants of the Hungarian Case Control Surveillance of Congenital Abnormalities from 1980 to 1991, exploring the relationship of folic acid with congenital anomalies Cases: 17 300 mothers of infants with congenital anomalies Population controls: 30 663 mothers of infants with no congenital abnormalities matched to cases by sex, birth week, residence Patient controls: 607 mothers of infants with Down Syndrome Exposure is folic acid supplementation: Dosing included folic acid (3 mg tablets, 1–3 times per day) or multivitamin (folic acid dose not reported) Timing included preconception, 1^st^ month of pregnancy, 2–3^rd^ month of pregnancy, 4–9^th^ month of pregnancy, and unknown | Retrospective exposure assessment poses potential recall bias. Differential measurement of exposure causes potential measurement bias. Lower response rate in controls No adjustment for smoking
Locksmith, 1998 (35) | Review of studies examining the use of supplemental folic acid for prevention of NTDs | Study type not included in review (not a systematic review)
Kallen, 2002 (36) | Cohort study of 5331 infants registered in the Swedish Medical Birth Registry between 1995 and 2001 whose mothers had reported use of folic acid in early pregnancy, examining the relationship of folic acid and congenital malformations Exposure is folic acid in early pregnancy (doses ranging from 0 to 5 mg of folic acid). Outcome is congenital malformations including NTDs. Subgroup analyses: women with subfertility problems and use of antiepileptic drugs | Used involuntary childlessness as proxy for infertility Exposure assessed by questionnaire at gestational week 10–12: drugs taken “since she became pregnant” No information about dose, timing
Lumley, 2001 (37) | Systematic review of randomized and quasi-randomized studies published until April 2001 relating to whether NTDs can be reduced by increased consumption of multivitamins or folate before pregnancy or in first two months of pregnancy | Studies included were not recent (many published prior to 1995 and included in USPSTF previous evidence report).
Medveczky, 2004 (38) | Case control study of participants in the Hungarian Case Control Surveillance of Congenital Abnormalities from 1980 to 1996, to explore the association between socioeconomic status, periconceptional folic acid/multivitamin supplementation and NTDs in Hungary Cases: 1202 mothers of infants or fetuses with NTDs Population controls: 38 151mothers of infants without congenital anomalies matched for sex, week of birth and district of residence Patient controls: 22 475 mothers of infants with congenital anomalies other than NTDs Exposure is periconceptional or pregnancy folic acid use and employment status classification | No information on overall effect of folic acid on NTDs
Moore, 2003 (25) | Prospective cohort study of 23 228 women predominantly from northeastern U.S. who were in early second trimester and had either serum alpha-fetoprotein screening test or amniocentesis to examine the effect of folic acid dose during early pregnancy Exposure: folate from food, supplements, or fortified grains (converted to dietary folate-equivalents (DFEs): 13 431 women had intake of 0 DFEs/day 2489 women had intake of 1–399 DFEs/d 1812 women had intake of 400–799 DFEs/d 5,494 women had intake of ≥800 DFEs/d Outcome: infant with NTD | This was a study of dose-response re-examining data from study reviewed in 1996 USPSTF report; no new information about overall benefits of folic acid supplementation
Shaw, 2002 (39) | Case-control study of live births and fetal deaths (at >20 weeks) from January 1987 to December 1989 in most California counties, to evaluate possible interactions of periconceptional vitamins with selected factors on congenital anomalies Cases: mothers of infants or fetuses with congenital anomalies (265 with NTDs) Controls: 734 mothers of infants without any major anomalies, randomly selected in same geographic area and time period Exposure: preconceptional vitamins in addition to smoking, fever, alcohol, race/ethnicity, education, BMI | No information on overall effect of folic acid on NTDs
Shaw, 1998 California (40) | Case-control study of live births and fetal deaths (at >20 weeks) and fetuses with NTDs that were electively terminated from 1987-1991 who were included in two previous studies by the California Birth Defects Monitoring Program to examine potential interaction between infant MTHFR C677T polymorphism and maternal use of vitamin supplements with folic acid Cases: mothers of infants or fetuses with NTDs Controls: mothers of infants without any major anomalies Exposure: Periconceptional or pregnancy use of folic acid and presence of MTHFR C677T polymorphism | No information on overall effect of folic acid on NTDs
Shaw, 2001 (41) | Case-control study of fetuses, live births, and fetuses with NTDs that were electively terminated from 1989 to 1991 in most California counties to examine the potential relationship between weight gain during pregnancy and risk of NTDs Cases: mothers of infants or fetuses with NTDs Controls: mothers of infants without any major anomalies Exposure: Periconceptional or pregnancy use of folic acid and weight gain during pregnancy | No information on overall effect of folic acid on NTDs
Shaw, 1996 (42) | Case-control study of fetuses, live births and fetuses with NTDs that were electively terminated from 1989 to 1991 in most California counties, to investigate the potential association between maternal obesity, folic acid supplementation, and NTD risk Cases: mothers of infants or fetuses with NTDs Controls: mothers of infants without any major anomalies Exposure: Periconceptional or pregnancy use of folic acid and prepregnancy BMI | No information on overall effect of folic acid on NTDs
Suarez, 2000 (43) | Case-control study of infants and fetuses in 14 Texas counties along the U.S.-Mexico border between 1995-1999, to examine the relationship between folic acid intake and NTDs Cases: 148 mothers of infants or fetuses with NTDs Controls: 158 mothers of infants without any congenital abnormalities Exposures are preconceptional supplement use (any use in 5.4% of cases and 3.2% of controls and daily use in 2% of cases and 2.5% of controls) and estimated dietary folate | Study performed in high-risk population

Table 2 Studies excluded after abstraction and quality rating - key question on harms

Study | Methods | Notes/Reason for Exclusion
Lumley, 2001 (31) | Modeling study based on relative risks for NTDS and twins after folic acid supplementation (in a hypothetical cohort of 100,000 women) Sources of data from registries in Victoria and Western Australia Hypothetical exposure: adequate folic acid supplementation in 100,000 women Outcomes: absolute difference in overall NTDs and twin gestations, perinatal and postnatal deaths | Study type not included in review
Ericson, 2001 (44) | Retrospective cohort study of 442 906 deliveries in Sweden between 1995 and 1999 Exposure: folic acid (n=2569) or multivitamin (n=1971) use since pregnancy reported at 10 weeks of gestation Outcome: twin gestation identified at delivery Subset analyses: women not reporting unwanted childlessness; unlike sex twin pairs | Potential confounding by patients undergoing IVF or ovulation stimulation; subgroup analysis on women without “period of involuntary childlessness”, but authors reported known underreporting of infertility history (40% of women who underwent IVF or ovulation stimulation did not report involuntary childlessness.) Measurement validity issues: exposure measured at 10 weeks; reported folic acid use was 0.6% in this study based on Birth Registry, as compared to 8% in concurrent study. No information on doses or timing of initiation of folic acid Potential differential recall based on knowledge of twin gestation by 8–10 weeks
Czeizel, 2004 (45) | Case-control study of 38 151 subjects from the Hungarian Case Control Surveillance of Congenital Abnormalities (HCCSCA) study between 1980 and 1996 who did not have any congenital abnormalities (the control group from the previous study) Cases: 395 twins Controls: 27 756 singleton pregnancies Exposure: folic acid use in pregnancy reported in prenatal log books and in questionnaire completed after delivery Including: no supplement, folic acid alone (dose range from 3–9 mg per day), multivitamin (folic acid dose range 0.1–1 mg per day), or folic acid and multivitamin | No adjustment for possible confounders: IVF, ovulation induction, smoking No information on doses or timing of initiation of folic acid Potential differential recall based on knowledge of twin gestation early in pregnancy or twin delivery
Kallen, 2004 (46) | Retrospective cohort study of 576 873 women registered in the Swedish Medical Birth Registry between 1995 and 2001, examining the relationship of folic acid and dizygotic twinning Exposure: folic acid use before conception or before first appointment (usually between 8–10 weeks) (n=6953) Outcome: unlike-sexed twin gestation identified at delivery Subset analysis: non-Swedish (by nationality or birth) women not reporting unwanted childlessness, use of ovulation induction or use of gestagens, | Incomplete information on doses (women likely took either 400 micrograms or 5 mg) or whether prenatal vitamins with folic acid were included in analysis No information on timing of initiation or duration of exposure Initial comparability of groups unknown Potential differential recall based on knowledge of twin gestation by 8–10 weeks Residual confounding possible if incomplete reporting of fertility treatments. Unclear how many women were included in the final analysis.

## KQ1: Does folic acid supplementation in women of childbearing age reduce the risk of a pregnancy affected by a neural tube defect?

### Summary of Study Results

Observational studies on the benefits of folic acid supplementation provide generally consistent evidence that folic acid supplementation in the periconceptional period reduces the risk of neural tube defects in offspring. This evidence was provided by three fair- or good-quality cohort, case-control, and meta-analytic studies that found statistically significant benefit; one small, fair-quality case-control study reported benefit that was not statistically significant. In addition to NTDs, the cohort and meta-analysis found reductions in cardiovascular congenital abnormalities associated with folic acid-containing multivitamins.

### Study Characteristics

The search for literature to answer this question returned four articles that met the inclusion/exclusion criteria, were published within the search timeframe, and were of appropriate methodological quality. Detailed study characteristics and outcomes are available in Table 3.

Table 3 Characteristics and results of studies included for key question 1: Folic acid supplementation and NTD reduction

Study | Methods | Participants | Interventions | Outcomes | Results (95% CI) | Notes
Czeizel, 2004 (47) | Cohort study of pregnant women who received folic acid-containing MVI prior to conception and women who did not take any supplements periconceptionally. USPSTF Level: II-2 | Hungary, May 1, 1993 to April 30, 1996 Supplemented group - 3981 women considering pregnancy recruited from Hungarian Periconceptional Service (HPS) originally created for the RCT of folate and NTD. Exclusions: 7 Unable to use MVI, 186 didn't want to use MVI, 15 had induced abortion, 15 ectopic, 488 had miscarriage prior to 14 weeks, 147 didn't take MVI. Outcomes couldn't be clarified in 54 (1.7%) Unsupplemented group - 3069 women recruited from regional antenatal care clinics between 8^th^ and 12^th^ gestational week who had not taken supplements. Outcomes couldn't be clarified in 47 (1.5%). 15% used supplements. Matched to supplemented group by age, quality of schools, employment status, and residence. Supplemented group more highly educated, higher employment status, less likely to smoke (8% vs 18%). Supplemented group more likely to have prior fetal and infant deaths and more likely to have family history of congenital anomalies. | Multivitamin tablets containing 0.8 mg of folic acid 1 month prior to planned conception and supplied every 3^rd^ month for up to 12 months. Compliance for supplemented group was assessed by personal interview at 4 separate visits, “tick-off” form for basal body temperature prior to conception, and counting unused tablets. Women were considered “fully supplemented” if they missed no more than one day for 28 days prior to conception and/or the 3^rd^ missed menstruation. “Partially supplemented” women missed 2 or more tablets. Unsupplemented group received routine care. | Presence of NTD, abnormalities of urinary tract, cardiovascular, limbs, pyloric stenosis, and orofacial clefts. | [underlined: NTD] 1 NTD in supplemented and 9 NTDs in unsupplemented group. aOR = 0.11 (0.01–0.91) [underlined: Urinary tract CAs] aOR = 0.71 (0.33–1.50) [underlined: Cardiovascular CAs] aOR = 0.60 (0.38–0.96) Orofacial clefts aOR = 1.63 (0.31–28.8) Adjusted ORs not calculated for pyloric stenosis or limb deficiencies. All ORs adjusted for birth order, chronic maternal disorder, history of previous fetal death or CAs. | Fair quality Measurement of exposure to supplements was different in the two groups. Women with personal, family, or offspring history of congenital abnormalities or fetal/infant loss likely self-selected into supplemented group. Collected information on SES but did not adjust for these and other potential confounders.
Goh, 2006 (48) | Meta-Analysis Searched up to July 2005 in Medline, PubMed, EMBASE, Toxline, HealthSTAR, and Cochrane in all languages. Search terms: “multivitamin,” “pregnancy,” and “malformation;” Reviewed reference lists of all collected articles for potential studies. Two reviewers assessed articles for possible inclusion. | Initial search returned 92 articles. 41 studies eligible based on inclusion criteria: 27 case control studies, 4 RCTs, and 10 cohort studies. Inclusion criteria: RCTs, case-control, or cohort study; reported pre- and periconceptional multivitamin intake; contained a control group; reported raw data of rates of outcomes. Exclusion criteria: studies on specific vitamins, exposures to known teratogens; review article, letters, abstracts. | Multivitamin use before or in first trimester of pregnancy | Risk of congenital malformations, including NTD, associated with multivitamin use before and in first trimester of pregnancy | [underlined: NTD] “Consistent protective effect” OR 0.67 (0.58–0.77) in CCS OR 0.52 (0.39–0.69) in RCTs/cohorts [underlined: Cleft palate] OR 0.76 (0.62–0.93) in CCS OR 0.42 (0.06–2.84) in RCTs/cohorts [underlined: Urinary tract anomalies] OR 0.48 (0.30–0.76) in CCS OR 0.68 (0.35–1.31) in RCTs/cohorts [underlined: Cardiovascular defects] OR 0.78 (0.67–0.92) in CCS OR 0.61 (0.40–0.92) in RCTs/cohorts [underlined: Limb defects] OR 0.48 (0.30–0.76) in CCS OR 0.57 (0.38–0.85) in RCTs/cohorts [underlined: Congenital hydrocephalus] OR 0.37 (0.24–0.56) in CCS OR 1.54 (0.53–4.50) in RCTs/cohorts | Fair quality Searched multiple databases and reference lists but did not include experts. No standard appraisal of included studies explicitly stated. Studies on folate-only supplementation were excluded. Included several studies that were excluded by us because of publication prior to 1995, because the studies were performed in special populations or did not report NTD as a specific outcomes. This limits applicability to the current review.
Shaw, 1995 (49) | Case Control Study exploring exposure to folic acid supplementation in cases of NTD and controls without a birth defect USPSTF Level: II-2 | Pregnant women and their offspring in California counties (except Los Angeles, Riverside, and Ventura) [underlined: NTD cases]: 665 ascertained; diagnosed prenatally and elective abortions during Feb 1989–Jan 1991 and NTD births: June 1989–May 1991; Ascertained from all hospitals and genetic clinics. [underlined: Controls]: - births without major structural malformations: June 1989–May 1991; selected in proportion to hospital's contribution to total births Exclusions: Not English or Spanish speaking (29 cases, 32 controls); prior NTD (11 cases and 1 control). Interviews conducted in 88.0% of cases, mothers at an average of 4.9 months after actual/estimated (for terminations) date of delivery and 88.2% of control mothers at an average of 4.6 months after date of delivery. 6.9% of cases refused to be interviewed and 5% could not be located; 6.2% of controls refused to be interviewed and 5% could not be located. Non-participants similar to study participants in race/ethnicity. Cases mothers more likely to be Hispanic, less than 25 years old and completed fewer years of school. | Folic acid from supplements or multivitamins in the 3 months before and the 3 months after conception. Amount of folic acid estimated from personal interview on type, brand, and frequency of use. Prenatal vitamins assumed to have 0.8 mg; multivitamins assumed to have 0.4 mg; if no information on frequency or type of supplement, folic acid intake considered to be zero. | Risk of NTD associated with folic acid-containing supplement | NTD risk and use of folic acid in 3 months before conception: OR = 0.65 (0.45–0.94) Use of folic acid in 3 months after conception: OR = 0.60 (0.46–0.79) | Good quality Accurate ascertainment of cases; selection of cases/controls appears nonbiased with exclusion criteria applied equally to both; response rates >80%; exposure measurement applied equally to each group; attention to appropriate covariates and confounding variables. Reporting bias explored: Women who thought “no effect” of vitamins on birth defects had larger reduction in risk (OR = 0.51, 0.31–0.85) for use 3 months prior to conception. Women who thought vitamins were “protective” = OR = 0.89 (0.46–1.7). Women who thought vitamins “causal” to birth defects = OR = 0.40 (0.04–7.6).
Thompson, 2003 (26) | Case Control Study exploring multivitamin folic acid use, dietary folate intake, and risk of NTDs. USPSTF Level: II-2 | Pregnant women residing in South Carolina who delivered in October 1992 through September 1997. Cases obtained through monitoring of amniocentesis programs, perinatal centers, all medical practitioners providing care to pregnant women, medical records from hospitals with delivery/newborn units and vital records. CDC surveillance team verified completeness of case ascertainment in years one and four of the study. Controls randomly selected from hospital in proportion to the hospital's estimated contribution to the total population of infants born. Selected concurrently with cases. First occurrence of singleton isolated NTD = 312 3 excluded because taking anticonvulsant medication. 2 women gave birth to twins excluded. 1 mother with NTD excluded.185 agreed to participate (72.3%) Controls = 398 eligible. 289 (72.6%) agreed to participate. 1 excluded because taking anticonvulsant medication. Cases and controls similar with respect to age, education, gravidity, month began PNC, previous NTD, BMI, smoking, ETOH, drug use, chronic conditions, MVI use. Higher proportion of cases were white (79.3% vs. 69.1%) and reported having been exposed to ETS (51.4% vs. 26.1%). | Average daily folic acid supplement intake in periconceptional period (3 months before and 3 months after conception) By maternal interview conducted within 2 weeks of discharge (liveborn control or NTD baby) and 4 weeks of termination. 77% of women with NTD affected pregnancies and 86% of controls interviewed within 6 months of delivery (means not given) Assumed Prenatal MVI = 0.8 mg Regular Use = 0.4 – 0.8 mg or more at least 3 times per week in periconceptional period. Some intake = less than 3 times per week or in partial months. No use = none at any time in periconceptional period. | Risk of NTD associated with folic acid-containing supplement | Regular use: 16 cases and 43 controls, a OR 0.55 (0.25–1.22) Some use: 123 cases and 188 controls, aOR = 0.92 (0.55–1.55) No use: 40 cases and 57 controls, reference Adjusted for age, race, BMI, ETS exposure and dietary folate | Fair quality Potential for selection bias: 25/71 women with NTD pregnancies chose not to participate, but participation rate similar for NTD patients as compared to controls. Measurement by interview of exposure assessed at different times for cases terminated versus controls/NTD babies creating potential for differential measurement bias. Sample size was small. Few took MVI regularly in 6 months periconceptionally. 6 month periconceptional period is not very precise timeframe for critical period of NTD.

Abbreviations: aOR = adjusted odds ration; CCS = case control studies; CA = congenital abnormalities; CI = confidence interval; ETS = environmental tobacco smoke; MVI = multivitamins; NTD = neural tube defects; RCT = randomized controlled trials

A 2004 cohort study by Czeizel and colleagues followed 3056 women considering pregnancy who were recruited from the Hungarian Periconceptional Service. Women in the supplemented group were given multivitamins containing 0.8 mg of folic acid one month prior to planned conception. Women were recruited into the cohort as unsupplemented controls and matched to the supplemented group by age, socio-economic status, and employment status if they arrived for their first prenatal visit between 8 and 12 weeks gestation and had not taken folic acid-containing supplements in the periconceptional period. The study design had some methodological problems that led to a fair rating. There was potential for self selection bias as evidenced by the higher maternal rate of personal, family, offspring congenital abnormalities and the higher rate of prior fetal and infant loss in the supplemented group. Measurement of exposure to folic acid was performed earlier in the pregnancy in the supplemented group than in the unsupplemented group.

Two case-control studies were found in the literature search. These studies explored the association between exposure to folic acid supplementation in the periconceptional period and NTD in women residing in two geographic areas—California counties and the state of South Carolina. Both studies ascertained cases in a comprehensive way through review of records from hospitals and genetic clinics, and controls were randomly selected from hospitals in proportion to their contribution to all births in the respective populations. The first case-control study by Shaw and colleagues in 1995 was rated good because of accurate ascertainment of cases, selection of cases and controls without obvious biases, response rates of 88% in both cases and controls, exposure measurement applied equally to cases and controls, and exploration of reporting bias by asking mothers whether they believed folic acid had protective, causal, or no effect on birth defects. The second case-control study, by Thompson and colleagues in 2003, had accurate ascertainment of cases and selection of cases and controls without obvious biases, but had a small sample size, differential measurement assessments, and differential response rates in the cases and controls. These methodological problems led to a fair rating.

The fourth study was a meta-analysis of studies on pre- and periconceptional multivitamin use and congenital malformations. This fair-quality meta-analysis was recent and relevant and searched several resources for evidence; however, it did not include expert consultations and did not report a standard appraisal of study methodology. In addition, the applicability of this meta-analysis to the current review is limited because it excluded studies on folate-only supplementation and included several studies that were excluded by us: studies that were published prior to 1995, that were performed in special populations or that did not report NTD as a separate outcome.

### Study Results

The Czeizel cohort study reported that 1 NTD and 9 NTDs occurred in the supplemented and unsupplemented women, respectively, for an adjusted odds ratio (aOR) of 0.11 (95% CI, 0.01–0.91); the odds ratio (OR) was adjusted for birth order, chronic maternal disorders, and history of previous fetal death or congenital abnormality. The meta-analysis also found a protective effect of folic acid-containing multivitamins in NTDs with an OR of 0.67 (95% CI, 0.58–0.77) in case-control studies and an OR of 0.52 (0.39–0.69) in RCTs and cohort studies. Both the Czeizel study and the meta-analysis found a statistically significant association between folic acid supplementation and a reduction in cardiovascular congenital abnormalities. In addition, there was a significant effect of folic acid-containing multivitamin use on congenital limb defects in the meta-analysis. No consistent effect of folic acid-containing multivitamins, either on orofacial clefts or on urinary tract congenital abnormalities, was seen in the Czeizel study or the meta-analysis.

The Shaw 1995 case-control study reported an OR of 0.65 (95% CI, 0.45–0.94) for use of folic acid-containing supplements in the 3 months before conception, and an OR of 0.60 (95% CI, 0.46–0.79) for supplement use in the 3 months after conception. The 2003 study by Thompson and colleagues reported an OR of 0.55 (0.25–1.22) for regular use, and an OR of 0.92 (0.55–1.55) for some use of folic acid-containing supplements, but neither of these findings was statistically significant.

Several differences in these case-control studies may explain differences in results. The 2003 Thompson study was smaller and adjusted for dietary folate intake. Additionally, the exposure timeframes were different: the Shaw study measured exposure in 2 time frames, 3 months before and 3 months after conception, while the Thompson study combined these same 6 months of periconception time into one measure of exposure.

## KQ2: Does folic acid supplementation in women of childbearing age increase the risk of any harmful outcomes for either the woman or the infant?

### Summary of Study Results

We found one study of fair quality on the harms of twinning that suggests that the association of folic acid supplementation with twinning may be the result of confounding by infertility treatment and by differential reporting of folic acid use. We found no clear, consistent evidence that preconceptional folic acid use results in increased rate of twinning. We did not find any studies on other previously suggested potential harms such as masking of vitamin B12 deficiency.

### Study Characteristics

We identified one study meeting the inclusion and quality criteria that addressed whether folic acid supplementation in women of childbearing age increases the risk of harmful outcomes for either the woman or the infant.(17) Details of this study are in Table 4. This retrospective cohort study examined the association between risk of twinning in 176 042 women who gave birth in Norway between December 1998 and December 2001 and their history of multivitamin or folic acid supplementation before or during pregnancy. Assessment of exposure was by birth attendant at the time of delivery, thus introducing potential problems with both measurement validity and differential recall. Overall, six percent of women in this study reported folic acid supplementation preconceptionally; however 24% of women who became pregnant through in vitro fertilization (IVF) reported supplementation. Given the concern for underreporting of folic acid use (calculated to be about 45% when the authors linked the pregnancies in this analysis to another large cohort study with more accurate assessment of folic acid exposure) and potential confounding by IVF, the authors included adjustment for these factors.

Table 4 Characteristics and results of studies included for key question 2: Folic acid supplementation and harms

Study | Methods | Participants | Interventions | Outcomes | Results (95% CI) | Notes
Vollset, 2005 (17) | Retrospective cohort study exploring association of twin gestation with folate use before or during pregnancy. | Norway, December 1998 to December 2001. All women giving birth in Norway between (n= 176,042). | Folic acid tablets contain either 0.2 mg or 0.4 mg. Multivitamins contain 0–0.2 mg folic acid per tablet. Folic acid use assessed by birth attendant who checks off use of multivitamin or folic acid before or during pregnancy. Preconception folate use in 6% (24% among IVF pregnancies.) | Risk of twin gestation after preconceptional folate use | OR: 1.59 (1.41–1.78) OR in subset of women who did not report IVF: 1.13 (0.97–1.33) OR for unlike sex pairs (proxy for dizygotic): 1.43 (1.12–1.83) When modeling the underreporting (12.7% unidentified IVF; 45% unidentified folate use): OR for twin delivery: 1.02 (0.85–1.24) In unlike sex pairs: 1.26 (0.91–1.73) Adjusted for age and parity | Fair quality Exposure measured at delivery; may be problems with recall and potential differential recall for twin gestations as compared to singletons; authors did model for underreporting of folate use and unidentified IVF pregnancies.

This study was rated fair, given its use of reasonable, albeit not the best, methods for exposure assessments, and its consideration of and accounting for most confounders, including IVF. Recall by mothers was likely imperfect, given that exposure was assessed at delivery, and there may have been differential recall of exposure by mothers with or without twin pregnancies. The exact dose, timing, and duration of the interventions were not clear, but all important outcomes were assessed.

### Study Results

After adjusting for age and parity, the authors reported an OR of 1.59 (95% CI 1.41–1.78) for twin delivery after preconceptional folic acid supplementation. In a subgroup analysis of women who did not report IVF, the risk of twinning was lower and non-significant (OR 1.13, 95% CI 0.97–1.33), as expected given the increase in multiple gestation associated with IVF and other assisted reproductive technologies. The odds of having twins of unlike sex, an outcome used as a proxy for dizygotic twinning, were increased in women taking folate, (OR 1.43, 95% CI 1.12–1.83). The authors then adjusted for both a 45% underreporting of supplementation as well as an estimated 12.7% of unidentified IVF pregnancies. When the likely underreporting for folic acid use and IVF were accounted for, the OR for twin delivery after preconceptional supplementation fell to 1.02, and was no longer statistically significantly greater than the risk for women who did not take folic acid (95% CI, 0.85–1.24).