# Methods

## Data Sources and Searches

We performed a systematic search for English language articles published between January 1, 1995, and November 30, 2007, through a MEDLINE search using the terms “neural tube defects,” “folic acid,” “pregnancy,” “twinning,” and “twins.” Additional studies were identified through a search of the Cochrane database, through discussions with experts, and by hand-searching of reference lists from included studies and major review articles and studies.

## Study Selection

Two reviewers independently reviewed the titles and abstracts and selected articles for inclusion based on predetermined inclusion and exclusion criteria. In general, studies were selected for benefits if they were RCTs, case-control studies, cohort studies or systematic reviews; and for harms if they were RCTs, case-control studies, cohort studies, systematic reviews or large observational studies; reported overall effect on reduction of neural tube defects or effect on harms in association with folic-acid containing supplements; and provided new evidence that was not in the 1996 USPSTF report. Studies were excluded if they included no new evidence since the 1996 review; were subanalyses of data without overall effect on NTD or harms; did not report effect of supplements separate from dietary effects; were letters, editorials, or non-systematic reviews; were performed in special or high-risk populations; or were performed in a country or population with widespread malnutrition or otherwise not generalizable to the United States. More details on search terms and inclusion/exclusion criteria are described in Appendix 1. Disagreements about inclusion of an article were discussed and selected based on consensus; if necessary a third reviewer was used for disagreements.

## Data Extraction and Quality Assessment

For all citations that met initial eligibility criteria, the full articles were reviewed, abstracted, and quality-rated independently by two reviewers. Studies were ultimately included if they were rated fair or good based on USPSTF criteria. Consensus about article abstraction data and quality was achieved through discussion by the two reviewers; disagreements were resolved by the involvement of a third reviewer. Data on the following items were extracted from the included studies: methods; exposure assessment; case ascertainment; selection of participants; dose of folic acid; sample size; size of effect on NTDs, other congenital abnormalities, and twinning; and information on confounders. Quality-rating of articles for all KQs was performed using standard USPSTF methodology on internal and external validity. We evaluated the quality of RCTs and cohort studies on the following items: initial assembly of comparable groups, maintenance of comparable groups, important differential loss to follow-up or overall high loss to follow-up, measurements (equality, reliability, and validity of outcome measurements), clear definition of the interventions, and appropriateness of outcomes. We evaluated systematic reviews and meta-analyses on the following items: comprehensiveness of sources considered, search strategy, standard appraisal of included studies, validity of conclusions, recency, and relevance. More complete criteria and definitions for USPSTF quality ratings are listed in the Appendix 2.

## Data Synthesis and Analysis

Data from studies included for KQ1 and KQ2 were synthesized qualitatively in tabular and narrative format. Synthesized evidence was organized by key question.

## Role of the Funding Source

The general work of the USPSTF is supported by the Agency for Healthcare Research and Quality. This specific review did not receive separate funding.