# Introduction

Neural tube defects (NTDs) are among the most common birth defects in the United States.(1) Estimates of disease burden are difficult to determine because affected pregnancies are sometimes spontaneously or electively aborted and are underreported on birth certificates.(2) The Centers for Disease Control and Prevention (CDC) estimates that the rates in 2005 for two of the most common NTDs, spina bifida and anencephaly, were 17.96 per 100 000 live births and 11.11 per 100 000 live births, respectively.(3)

NTDs cover a range of congenital malformations affecting the brain and spinal cord. This spectrum of congenital defects has been defined as:

“Anencephaly (the total or partial absence of the cranial vault, the covering skin and the brain tissue), spina bifida (non-closure of the spine resulting in herniation or exposure of the spinal cord, the meninges or both; in some cases together with hydrocephalus), encephalocoele (herniation of the meninges and brain tissue outside the cranium, covered by normal or atrophic skin).”(6)

The embryological events leading to NTDs occur early in pregnancy. These events begin at approximately the twenty-first day after conception, and neural tube closing occurs by approximately 28 days after conception.(5)

Although neural tube defects (NTDs) span a range of disorders and possible etiologies, a number of risk factors for the disorders have been identified. Two well-established risk factors are having a history of a previous fetus or child with NTD and/or a first-, second-, or third-degree relative with NTD.(7, 8) There are ethnic and racial variations in the prevalence: Hispanics and non-Hispanic whites have higher rates of NTDs than African-Americans and Asians.(9) In a large population-based study in California, the prevalence in Hispanic women was found to be 1.12 per 1000 women screened (95% CI 1.04–1.21), the prevalence in Caucasian women was 0.96 per 1000 (95% CI 0.89–1.04), in African-American women 0.75 per 1000 (95% CI 0.59–0.91) and in Asian women 0.75 per 1000 (95% CI 0.60–0.90).(10) There are likely environmental or diet-related differences that contribute to these differences in prevalence of NTDs; however, the prevalence of mutations in certain enzymes may also differ among these population groups. Two enzymes that have been linked to increased risk for certain NTDs are methylenetetrahydrofolate reductase (MTHFR) and methionine synthase (MTRR).(11)

Maternal medical conditions such as diabetes and obesity have been associated with an increased risk of NTDs. Women with epilepsy who take certain anti-epileptic medications, such as valproic acid or carbamazepine, are also at increased risk. The risk of an open NTD in a woman taking these medications in the first trimester of pregnancy is reportedly 1–2%. Other medications associated with NTDs include vitamin A and Warfarin.(11)

The effectiveness of folate in preventing NTDs has been reported in multiple studies.(6) The mechanism of action has not been established. However, a main function for folate is in one-carbon transfers, which are important in methylation reactions and in purine and pyrimidine synthesis. Folate is necessary for the regulation of DNA synthesis and function and therefore affects important events in embryogenesis that may lead to NTDs.

There are three main approaches to achieving adequate levels of folate in women who are capable of becoming pregnant in the United States: ensuring a healthy diet that includes foods fortified with folic acid; providing folic acid supplements; and providing a combination of supplements and a folic acid-rich diet. Despite the US recommendations and efforts in the United States to increase folic acid intake, in 1997 intake of supplements by women had not achieved desired levels: only about 30% of women reported taking a daily supplement containing folic acid.(12) Overall, 26% of women reported taking at least 400 micrograms of folic acid per day via supplements within the previous month and 34.3% of women of reproductive age reported consuming over 400 micrograms per day via a combination of fortified foods and supplements. Recently, the 2007 March of Dimes Gallup survey used a random-digit dialed telephone interview in women of childbearing age. Of this population, 40% reported taking folic acid daily, as compared to 32% in 2003, 40% in 2004, and 33% in 2005. When stratified by age, 47% women from 25–34 years of age reported taking a daily supplement with folic acid as compared to 30% of women aged 18–24.(13)

In 1998, the U.S. Food and Drug Administration (FDA) mandated fortification of all enriched grain products at the level of 0.14 mg/100 grams of grain.(1) In the United States, fortification was expected to add approximately 100 μg of folic acid per day to the average American diet and increase the percentage of women of childbearing age consuming at least 400 μg/day from 29% to 50%.(1) In reality, the first expectation was met but the second was not: the proportion of women of childbearing age who consume more than 400 μg/day of folate varies by race/ethnicity from 23% to 33%.(1) According to more recent data from the 2001-2002 National Health and Nutrition Examination Survey (NHANES 2001-2002), limited to non-pregnant female participants between 15 and 49 years of age, the adjusted mean daily consumption of folic acid via fortified foods was estimated at 128 micrograms and was found to be 18% lower in non-Hispanic black women (109 micrograms/day) than in non-Hispanic white women (133 micrograms/day). Consumption of more than 400 micrograms/day from fortified foods was reported by only 8% of women.(14) There were differences by race/ethnicity in intake: 40.5% of non-Hispanic white, 19% of non-Hispanic black women, and 21.0% of Hispanic women reported consuming over 400 micrograms per day from all sources.

Despite less than ideal population intake, the prevalence of NTDs reported on birth certificates in the United States decreased from 37.8 per 100 000 live births before fortification to 30.5 per 100 000 live births conceived after mandatory folic acid fortification, representing a 19% decline.(15) More recently, the CDC reported that 23 population-based surveillance systems showed an approximately 26% decline in NTD prevalence rates in the United States before and after mandated fortification.(16)

The last U.S. Preventive Services Task Force (USPSTF) recommendation on the use of folic acid in women of childbearing age was made in 1996. At that time the USPSTF recommended that all women planning a pregnancy or capable of conception take a supplement containing folic acid. They found insufficient evidence to recommend for or against counseling women to increase their dietary folate consumption as an alternative to taking a folic acid supplement.

The purpose of this review is to update the evidence on folic acid supplementation in women of childbearing age. The USPSTF decided to focus its new review on folic acid supplementation; therefore, this review does not include a review of the evidence on fortification, counseling to increase dietary intake, or on screening for neural tube defects. Because this current review is an update, it includes only new literature published since 1995. The analytic framework developed for this review following USPSTF methods is shown in Figure 1. The USPSTF developed 2 key questions (KQs) from the analytic framework to guide its consideration of the evidence on folic acid supplementation. The key questions are:

- KQ1: Does folic acid supplementation in women of childbearing age reduce the risk of a pregnancy affected by a neural tube defect?
- KQ2: Does folic acid supplementation in women of childbearing age increase the risk of any harmful outcomes for either the woman or the infant?

Figure 1. Analytic Framework for the USPSTF Review on Folate Supplementation for the Prevention of Neural Tube Defects

In addition to these key questions, which define the scope of this systematic review, the USPSTF requested that information be gathered to answer 2 additional questions to provide context for their recommendation. The 2 contextual questions are:

1 What is the current dietary intake of folic acid (average level of folate) in women of childbearing age?
2 What is the most effective dose of folic acid supplementation?

The results of these two contextual questions are discussed in the Introduction and Discussion sections of this report.