# References

1 Ries LA, Wingo PA, Miller DS, et al. The annual report to the nation on the status of cancer, 1973-1997, with a special section on colorectal cancer. Cancer. 2000;88:2398-2424. [pmid: 10820364].
2 SEER Cancer Statistics Review 1973-1997. Accessed January 15, 2001. National Cancer Institute Web Page. Available at: http://seer.cancer.gov/Publications. [pmid: 8766886].
3 Winawer SJ, Fletcher RH, Miller L, et al. Colorectal cancer screening: clinical guidelines and rationale. Gastroenterology. 1997;112(2):594-642. [pmid: 9024315]. [pmcid: 20297].
4 Stryker SJ, Wolff BG, Culp CE, Libbe SD, Ilstrup DM, MacCarty RL. Natural history of untreated colonic polyps. Gastroenterology. 1987;93(5):1009-1013. [pmid: 3653628]. [pmcid: 280609].
5 Rustgi AK. Hereditary gastrointestinal polyposis and nonpolyposis syndromes. N Engl J Med. 1994;331:1694-1702. [pmid: 7969362].
6 Fuchs CS, Giovannucci EL, Colditz GA, Hunter DJ, Speizer FE, Willett WC. A prospective study of family history and the risk of colorectal cancer. N Engl J Med. 1994;331:1669-1674. [pmid: 7969357].
7 Eaden JA, Mayberry JF. Colorectal cancer complicating ulcerative colitis: a review. Am J Gastroenterol. 2000;95:2710-2719. [pmid: 11051339].
8 Winawer SJ, Zauber AG, Gerdes H, et al. Risk of colorectal cancer in the families of patients with adenomatous polyps. National Polyp Study Workgroup. N Engl J Med. 1996;334:82-87. [pmid: 8531963].
9 Eisen GM, Sandler RS. Are women with breast cancer more likely to develop colorectal cancer? Critical review and meta-analysis. J Clin Gastroenterol. 1994;19:57-63. [pmid: 7930436]. [pmcid: 83865].
10 Weinberg DS, Newschaffer CJ, Topham A. Risk for colorectal cancer after gynecologic cancer. Ann Intern Med. 1999;131:189-193. [pmid: 10428735].
11 Rex D. Should we colonoscope women with gynecologic cancer?. Am J Gastroenterol. 2000;95:812-813. [pmid: 10710083].
12 Thune I. Assessments of physical activity and cancer risk. Eur J Cancer Prev. 2000;9:387-393. [pmid: 11201676]. [pmcid: 187586].
13 Lipkin M, Reddy B, Newmark H, Lamprecht SA. Dietary factors in human colorectal cancer. Annu Rev Nutr. 1999;19:545-586. [pmid: 10448536]. [pmcid: 181474].
14 Pignone MP, Rich M, Teutsch SM, Berg AO, Lohr KN, Rockville, Md. AHRQ 2001 320826
15 Pignone M, Saha S, Hoerger T, Krages K, Helfand M, Mandelblatt J. Report submitted to the Agency for Healthcare Research and Quality. 2001. [pmcid: 320826].
16 U.S. Preventive Services Task Force Guide to Clinical Preventive Services. 2nd ed, Alexandria, Va. International Medical Publishing 1996 190016
17 Harris RP, Helfand M, Woolf SH, et al. Current Methods of the US Preventive Services Task Force: A Review of the Process. Am J Prev Med. 2001;2 (3S). [pmcid: 60215].
18 Herrinton LJ, Selby JV, Friedman GD, Quesenberry CP, Weiss NS. Case-control study of digital-rectal screening in relation to mortality from cancer of the distal rectum. Am J Epidemiol. 1995;142:961-964. [pmid: 7572977].
19 Bini EJ, Rajapaksa RC, Weinshel EH. The findings and impact of nonrehydrated guaiac examination of the rectum (FINGER) study: a comparison of 2 methods of screening for colorectal cancer in asymptomatic average-risk patients. Arch Intern Med. 1999;159:2022-2026. [pmid: 10510987].
20 Eisner MS, Lewis JH. Diagnostic yield of a positive fecal occult blood test found on digital rectal examination. Does the finger count?. Arch Intern Med. 1991;151:2180-2184. [pmid: 1953220].
21 Ransohoff DF, Lang CA. Screening for colorectal cancer with the fecal occult blood test: a background paper. American College of Physicians. Annals of Internal Medicine. 1997;126:811-22. [pmid: 9148658]. [pmcid: 111171].
22 Walter SD. Estimation of test sensitivity and specificity when disease confirmation is limited to positive results. Epidemiol. 1999;10:67-72. [pmcid: 172915].
23 Wagner J, Tunis S, Brown M, Ching A, Almeida R. Cost-effectiveness of colorectal cancer screening in average-risk adults. In: Young G, Rozen P, Levin B, eds. Prevention and Early Detection of Colorectal Cancer. London: Saunders. 1996:321-356. [pmcid: 40230].
24 Mandel J, Bond J, Church T, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. N Engl J Med. 1993;328:1365-1371. [pmid: 8474513].
25 Mandel JS, Church TR, Bond JH, et al. The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. 2000;343:1603-1607. [pmid: 11096167].
26 Hardcastle J, Chamberlain J, Robinson M, et al. Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348:1472-1477. [pmid: 8942775].
27 Kronborg O, Fenger C, Olsen J, Jorgensen D, Sondergaard O. Randomised study of screening for colorectal cancer with faecal-occult-blood test. Lancet. 1996;348:1467-1471. [pmid: 8942774].
28 Eddy DM. Screening for colorectal cancer. Ann Intern Med. 1990;113:373-384. [pmid: 2200321]. [pmcid: 251640].
29 Ahlquist DA, Skoletsky JE, Boynton KA, et al. Colorectal cancer screening by detection of altered human DNA in stool: feasibility of a multitarget assay panel. Gastroenterology. 2000;119:1219-1227. [pmid: 11054379].
30 Mandel JS, Church TR, Ederer F, Bond JH Colorectal cancer mortality: effectiveness of biennial screening for fecal occult bloodJ Natl Cancer Inst1999 91 434 437 10070942 209509
31 Towler B, Irwig L, Glasziou P, Kewenter J, Weller D, Silagy C. A systematic review of the effects of screening for colorectal cancer using the faecal occult blood test, Hemoccult. BMJ. 1998;317:559-565. [pmid: 9721111]. [pmcid: 28648].
32 Vernon SW Participation in colorectal cancer screening: a reviewJ Natl Cancer Inst1997 89 1406 1422 9326910
33 Balas EA, Weingarten S, Garb CT, Blumenthal D, Boren SA, Brown GD. Improving preventive care by prompting physicians. Arch Intern Med. 2000;160:301-308. [pmid: 10668831].
34 Pignone M, Bucholtz D, Harris R. Patient preferences for colon cancer screening. J Gen Intern Med. 1999;14:432-437. [pmid: 10417601]. [pmcid: 149983].
35 Lieberman DA, Weiss DG, Bond JH, Ahnen DJ, Garewal H, Chejfec G. Use of colonoscopy to screen asymptomatic adults for colorectal cancer. Veterans Affairs Cooperative Study Group 380. N Engl J Med. 2000;343:162-168. [pmid: 10900274].
36 Imperiale TF, Wagner DR, Lin CY, Larkin GN, Rogge JD, Ransohoff DF. Risk of advanced proximal neoplasms in asymptomatic adults according to the distal colorectal findings. N Engl J Med. 2000;343:169-174. [pmid: 10900275].
37 Atkin WS, Hart A, Edwards R, et al. Uptake, yield of neoplasia, and adverse effects of flexible sigmoidoscopy screening. Gut. 1998;42:560-565. [pmid: 9616321]. [pmcid: 244057].
38 Lehman GA, Buchner DM, Lappas JC. Anatomical extent of fiberoptic sigmoidoscopy. Gastroenterology. 1983;84:803-808. [pmid: 6825990]. [pmcid: 277962].
39 Thiis-Evensen E, Hoff GS, Sauar J, Langmark F, Majak BM, Vatn MH. Population-based surveillance by colonoscopy: effect on the incidence of colorectal cancer: Telemark Poly Study I. Scand J Gastroenterol. 1999;34:414-420. [pmid: 10365903].
40 Kramer BS, Gohagan J, Prorok PC, Smart C. A National Cancer Institute sponsored screening trial for prostatic, lung, colorectal, and ovarian cancers. Cancer. 1993;71:589-593. [pmid: 8420681]. [pmcid: 145402].
41 Selby J, Friedman G, Quesenberry C, Weiss N. A case-control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. 1992;326:653-657. [pmid: 1736103].
42 Newcomb PA, Norfleet RG, Storer BE, Surawicz TS, Marcus PM Screening sigmoidoscopy and colorectal cancer mortalityJ Natl Cancer Inst1992 84 1572 1575 1404450
43 Nelson RL, Abcarian H, Prasad ML. Iatrogenic perforation of the colon and rectum. Dis Colon Rectum. 1982;25:305-308. [pmid: 7083975]. [pmcid: 265888].
44 Anderson JC, Pollack BJ, Shaw RD. Virtual colonoscopy. N Engl J Med. 2000;342:738; discussion 738-739.
45 Verne JE, Aubrey R, Love SB, Talbot IC, Northover JM. Population based randomized study of uptake and yield of screening by flexible sigmoidoscopy compared with screening by faecal occult blood testing. BMJ. 1998;317:182-185. [pmid: 9665902]. [pmcid: 28612].
46 Schoen RE, Weissfeld JL, Bowen NJ, Switzer G, Baum A. Patient satisfaction with screening flexible sigmoidoscopy. Arch Intern Med. 2000;160:1790-1796. [pmid: 10871972].
47 Winawer S Screening for colorectal cancer with fecal occult blood testing and sigmoidoscopyJ Natl Cancer Inst1993 85(16) 1311 1318 8340943 262777
48 Berry DP, Clarke P, Hardcastle JD, Vellacott KD. Randomized trial of the addition of flexible sigmoidoscopy to faecal occult blood testing for colorectal neoplasia population screening. Br J Surg. 1997;84:1274-1276. [pmid: 9313712]. [pmcid: 278058].
49 Rasmussen M, Kronborg O, Fenger C, Jorgensen OD. Possible advantages and drawbacks of adding flexible sigmoidoscopy to hemoccult-II in screening for colorectal cancer: a randomized study. Scand J Gastroenterol. 1999;34:73-78. [pmid: 10048736]. [pmcid: 288672].
50 Ott DJ, Scharling ES, Chen YM, Wu WC, Gelfand DW. Barium enema examination: sensitivity in detecting colonic polyps and carcinomas. South Med J. 1989;82:197-200. [pmid: 2644698]. [pmcid: 225898].
51 Beggs I, Thomas BM. Diagnosis of carcinoma of the colon by barium enema. Clin Radiol. 1983;34:423-425. [pmid: 6872448].
52 Rex DK, Rahmani EY, Haseman JH, Lemmel GT, Kaster S, Buckley JS. Relative sensitivity of colonoscopy and barium enema for detection of colorectal cancer in clinical practice. Gastroenterology. 1997;112:17-23. [pmid: 8978337]. [pmcid: 251376].
53 Johnson CD, Carlson HC, Taylor WF, Weiland LP. Barium enemas of carcinoma of the colon: sensitivity of double- and single-contrast studies. Am J Roentgenology. 1983;140:1143-1149.
54 Bloomfield JA. Reliability of barium enema in detecting colonic neoplasia. Med J Aust. 1981;1:631-633. [pmid: 7254054].
55 Teefey SA, Carlson HC. The fluoroscopic barium enema in colonic polyp detection. Am J Roentgenology. 1983;141:1279-1281. [pmcid: 293824].
56 Brady AP, Stevenson GW, Stevenson I. Colorectal cancer overlooked at barium enema examination and colonoscopy: a continuing perceptual problem. Radiology. 1994;192:373-378. [pmid: 8029400].
57 Strom E, Larsen JL. Colon cancer at barium enema examination and colonoscopy: a study from the county of Hordaland, Norway. Radiology. 1999;211:211-214. [pmid: 10189473].
58 Brekkan A, Kjartansson O, Tulinius H, Sigvaldason H. Diagnostic sensitivity of X-ray examination of the large bowel in colorectal cancer. Gastrointest Radiol. 1983;8:363-365. [pmid: 6642154]. [pmcid: 96064].
59 Glick S, Wagner JL, Johnson CD. Cost-effectiveness of double-contrast barium enema in screening for colorectal cancer. Am J Roentgenology. 1998;170:629-636.
60 Myllyla V, Paivansalo M, Laitinen S. Sensitivity of single and double contrast barium enema in the detection of colorectal carcinoma. Rofo: Fortschritte Auf Dem Gebiete Der Rontgenstrahlen Und Der Nuklearmedizin. 1984;140:393-397. [pmid: 6425161].
61 Winawer SJ, Stewart ET, Zauber AG, et al. A comparison of colonoscopy and double-contrast barium enema for surveillance after polypectomy. N Engl J Med. 2000;342(24):1766-1772. [pmid: 10852998]. [pmcid: 92108].
62 Winawer SJ, Zauber AG, Ho MN, et al. Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. 1993;329:1977-1981. [pmid: 8247072].
63 Kewenter J, Brevinge H. Endoscopic and surgical complications of work-up in screening for colorectal cancer. Dis Colon Rectum. 1996;39:676-680. [pmid: 8646956]. [pmcid: 348004].
64 Blakeborough A, Sheridan MB, Chapman AH. Complications of barium enema examinations: a survey of UK Consultant Radiologists 1992 to 1994. Clin Radiol. 1997;52:142-148. [pmid: 9043049]. [pmcid: 203416].
65 Steine S. Which hurts the most? A comparison of pain rating during double-contrast barium enema examination and colonoscopy. Radiology. 1994;191:99-101. [pmid: 8134605].
66 Van Ness MM, Chobanian SJ, Winters C Jr, Diehl AM, Esposito RL, Cattau EL Jr. A study of patient acceptance of double-contrast barium enema and colonoscopy. Which procedure is preferred by patients?. Arch Intern Med. 1987;147:2175-2176. [pmid: 3689069].
67 Newcomer MK, Shaw MJ, Williams DM, Jowell PS. Unplanned work absence following outpatient colonoscopy. J Clin Gastroenterology. 1999;29:76-78. [pmcid: 269706].
68 Rex DK, Cutler CS, Lemmel GT, et al. Colonoscopic miss rates of adenomas determined by back-to-back colonoscopies. Gastroenterology. 1997;112:24-28. [pmid: 8978338].
69 Rembacken BJ, Fujii T, Cairns A, et al. Flat and depressed colonic neoplasms: a prospective study of 1000 colonoscopies in the UK. Lancet. 2000;355:1211-1214. [pmid: 10770302].
70 Muller AD, Sonnenberg A. Protection by endoscopy against death from colorectal cancer. A case-control study among veterans. Arch Intern Med. 1995;155:1741-1748. [pmid: 7654107].
71 Frazier AL, Colditz GA, Fuchs CS, Kuntz KM. Cost-effectiveness of screening for colorectal cancer in the general population. JAMA. 2000;284:1954-1961. [pmid: 11035892].
72 Eckardt VF, Kanzler G, Schmitt T, Eckardt AJ, Bernhard G. Complications and adverse effects of colonoscopy with selective sedation. Gastrointest Endosc. 1999;49:560-565. [pmid: 10228252]. [pmcid: 366005].
73 Zubarik R, Fleischer DE, Mastropietro C, et al. Prospective analysis of complications 30 days after outpatient colonoscopy. Gastrointest Endosc. 1999;50:322-328. [pmid: 10462650]. [pmcid: 262176].
74 Wexner SD, Forde KA, Sellers G, et al. How well can surgeons perform colonoscopy?. Surg Endosc. 1998;12:1410-1414. [pmid: 9822468].
75 Farley DR, Bannon MP, Zietlow SP, Pemberton JH, Ilstrup DM, Larson DR. Management of colonoscopic perforations. Mayo Clinic Proc. 1997;72:729-733.
76 Foliente RL, Chang AC, Youssef AI, Ford LJ, Condon SC, Chen YK. Endoscopic cecal perforation: mechanisms of injury. Am J Gastroenterol. 1996;91:705-708. [pmid: 8677933].
77 Gibbs DH, Opelka FG, Beck DE, Hicks TC, Timmcke AE, Gathright JBJ. Postpolypectomy colonic hemorrhage. Dis Colon Rectum. 1996;39:806-810. [pmid: 8674375]. [pmcid: 162633].
78 Ure T, Dehghan K, Vernava AM III, Longo WE, Andrus CA, Daniel GL. Colonoscopy in the elderly. Low risk, high yield. Surg Endosc. 1995;9:505-508. [pmid: 7676371]. [pmcid: 119996].
79 Lo AY, Beaton HL. Selective management of colonoscopic perforations. J Am Coll Surg. 1994;179:333-337. [pmid: 8069431].
80 Rosen L, Bub DS, Reed JF III, Nastasee SA. Hemorrhage following colonoscopic polypectomy. Dis Colon Rectum. 1993;36:1126-1131. [pmid: 8253009].
81 DiPrima RE, Barkin JS, Blinder M, Goldberg RI, Phillips RS. Age as a risk factor in colonoscopy: fact versus fiction. Am J Gastroenterol. 1988;83:123-125. [pmid: 3341334].
82 Nivatvongs S. Complications in colonoscopic polypectomy: lessons to learn from an experience with 1576 polyps. Am Surg. 1988;54:61-63. [pmid: 3341645].
83 Brynitz S, Kjaergard H, Struckmann J. Perforations from colonoscopy during diagnosis and treatment of polyps. Annales Chirurgiae Et Gynaecologiae. 1986;75:142-145. [pmid: 3740781].
84 Webb WA, McDaniel L, Jones L. Experience with 1000 colonoscopic polypectomies. Ann Surg. 1985;201:626-632. [pmid: 3873221].
85 Macrae FA, Tan KG, Williams CB. Towards safer colonoscopy: a report on the complications of 5000 diagnostic or therapeutic colonoscopies. Gut. 1983;24:376-383. [pmid: 6601604]. [pmcid: 325486].
86 Leard L, Savides T, Ganiats T. Patient preferences for colorectal cancer screening. J Fam Pract. 1997;45:211-218. [pmid: 9300000]. [pmcid: 281507].
87 Halligan S, Fenlon HM. Science, medicine, and the future: virtual colonoscopy. BMJ. 1999;319:1249-1252. [pmid: 10550093].
88 Pescatore P, Glucker T, Delarive J, et al. Diagnostic accurarcy and interobserver agreement of CT colonography (virtual colonoscopy). Gut. 2000;47:126-130. [pmid: 10861274].
89 Pignone MP, Saha S, Hoerger T, Mandelblatt J, Krages K, Helfand M Systematic Review of Cost-Effectiveness Analyses for Colorectal Cancer Screening, Rockville, Md. Agency for Healthcare Research and Quality forthcoming
90 Khandker RK, Dulski JD, Kilpatrick JB, Ellis RP, Mitchell JB, Baine WB. A decision model and cost-effectiveness analysis of colorectal cancer screening and surveillance guidelines for average-risk adults. Int J Technol Assess Health Care. 2000;16:799-810. [pmid: 11028135]. [pmcid: 437953].
91 Sonnenberg A, Delco F, Inadomi JM. Cost-effectiveness of colonoscopy in screening for colorectal cancer. Ann Intern Med. 2000;133:573-584. [pmid: 11033584].